# Medicamentos para tratar condiciones de salud mental

Revisión de las investigaciones para adultos y personas que ayudan al cuidado

## ¿Es esta información apropiada para mí?

### Esta información es para usted si

- Un médico ha sugerido que usted o la persona a quien cuida tome uno de los medicamentos de la lista siguiente. Estos medicamentos se llaman “antipsicóticos” porque se hicieron para tratar enfermedades mentales graves, como la psicosis. Ahora, los antipsicóticos se usan para tratar muchas condiciones y síntomas de salud mental y no sólo la psicosis.
  - Aripiprazol (Abilify^®^)
  - Olanzapina (Zyprexa^®^)
  - Quetiapina (Seroquel^®^)
  - Risperidona (Risperdal^®^)
  - Ziprasidona (Geodon^®^)
- Un médico ha dicho que usted o la persona a quien cuida tiene una de estas condiciones:
  - Demencia
  - Trastornos de la alimentación (anorexia nerviosa)
  - Trastorno de ansiedad generalizada
  - Trastorno obsesivo-compulsivo (OCD, por su sigla en inglés)
  - Trastorno de estrés postraumático (PTSD, por su sigla en inglés)
  - Depresión grave
  - Abuso de drogas y bebidas alcohólicas

La evidencia sobre el uso de los antipsicóticos en algunas de estas condiciones es limitada. Vea en las páginas 6 y 7 si existe información respecto a su condición. Las definiciones de estas condiciones se encuentran en la página 2.

### Esta información puede no ser útil para usted si

- Un médico no le ha recomendado un antipsicótico a usted o a la persona a quien cuida.
- Su médico ha recomendado un antipsicótico distinto a los listados arriba, tales como la asenapina (Saphris^®^), la iloperidona (Fanapt^®^) y la paliperidona (Invega^®^). No existe suficiente investigación sobre estos medicamentos para tratar condiciones distintas a la psicosis o el trastorno bipolar.
- Está tomando el antipsicótico clozapina (Clozaril^®^, FazaClo^®^).
- Este medicamento puede tener un efecto secundario grave y requiere especial cuidado por parte de su médico.
- Tiene menos de 18 años de edad. Esta información proviene de investigación realizada en adultos.

### ¿Qué aprenderé con este resumen?

Este resumen le informa de las investigaciones realizadas sobre la eficacia de ciertos medicamentos antipsicóticos para el tratamiento de condiciones distintas a la psicosis o el trastorno bipolar. Le informa también de lo que dicen las investigaciones sobre el riesgo de tener efectos secundarios con estos medicamentos.

### ¿De dónde proviene la información de este resumen?

La información de este resumen proviene de un informe sobre el uso de los antipsicóticos para el tratamiento de una variedad de condiciones. Para elaborar el informe, se revisaron 170 estudios publicados antes de mayo de 2011 acerca de la eficacia de estos medicamentos. Se revisaron también 180 estudios publicados antes de mayo de 2011 acerca de los efectos secundarios de estos medicamentos. Esta información puede ayudarle a hablar con su médico sobre qué medicamento puede ser adecuado para usted.

## Conozca los antipsicóticos

### ¿Por qué las personas toman medicamentos antipsicóticos?

Los medicamentos antipsicóticos se crearon para ayudar a las personas que tienen psicosis, un síntoma de enfermedades mentales graves, como la esquizofrenia o el trastorno bipolar. Estos medicamentos se utilizan actualmente para tratar muchas otras condiciones (que se mencionan a continuación). Estos medicamentos no se hicieron para curar esas condiciones, sino para ayudar a aliviar los síntomas y a mejorar la calidad de vida.

- Demencia: Problemas para pensar, con la memoria, la comunicación o el movimiento. La demencia hace a veces que la persona grite, pelee o vea cosas que no existen.
- Trastornos de la alimentación: La anorexia nerviosa (cuando uno no come lo suficiente, por creer que tiene sobrepeso, a pesar de estar bajo de peso y muy delgado).
- Trastorno de ansiedad generalizada: Sentimientos frecuentes e intensos de miedo y preocupación superiores al nivel usual de estrés que sienten las personas.
- Trastorno obsesivo-compulsivo (OCD, por su sigla en inglés): Sensación de angustia por pensamientos y temores (obsesiones) que ocasionan que uno repita acciones (compulsiones) sin una buena razón. Son ejemplos: lavarse las manos repetidamente por temor a los microbios o revisar reiteradamente la cerradura de la puerta por temor a los intrusos.
- Trastorno de estrés postraumático (PTSD, por su sigla en inglés): Ansiedad, pánico o depresión debido a un suceso traumático vivido.
- Depresión grave: Sentimientos constantes de tristeza, desesperanza y falta de autoestima.
- Abuso de drogas y bebidas alcohólicas: Consumo excesivo o con tendencia a depender de bebidas alcohólicas, drogas u otras sustancias.

Quizás esté tomando también otros medicamentos para tratar esas condiciones, como antidepresivos u otros medicamentos para la ansiedad. Para ayudar a tratar su condición, los antipsicóticos pueden añadirse a esos medicamentos o pueden sustituirse si no funcionan.

### ¿Qué dicen las investigaciones sobre la eficacia de los antipsicóticos para tratar otras condiciones diferentes?

Los medicamentos antipsicóticos que se estudiaron en las investigaciones para este resumen son:

- Aripiprazol (Abilify^®^)
- Olanzapina (Zyprexa^®^)
- Quetiapina (Seroquel^®^)
- Risperidona (Risperdal^®^)
- Ziprasidona (Geodon^®^)

Los medicamentos antipsicóticos que NO se incluyen en este resumen son:

- La clozapina (Clozaril^®^, FazaClo^®^) debido a que puede causar un efecto secundario grave y requiere de cuidado especial por parte del médico.
- La asenapina (Saphris^®^), la iloperidona (Fanapt^®^) y la paliperidona (Invega^®^), debido a que no existen suficientes investigaciones sobre su uso en condiciones diferentes a la psicosis.

No todos los medicamentos antipsicóticos se han estudiado en todas las condiciones. En el caso de algunos medicamentos, los investigadores pueden señalar cuántas personas observaron un beneficio durante los estudios de esos medicamentos. Esta información puede ayudarle a entender qué tan probable es que usted obtenga el mismo beneficio.

Beneficios de los antipsicóticos por condición

Condición | ¿Qué beneficio? | ¿Cuál medicamento? | ¿Qué tan probable es el beneficio?
Demencia | Alivió síntomas tales como agresión, delirios (creer cosas que no son verdad o no son lógicas) o alucinaciones (ver cosas u oír voces que no existen) NO mejoró los problemas para pensar o la memoria | - Todos los antipsicóticos incluidos en este resumen, a excepción de la ziprasidona (Geodon^®^); - No existen suficientes estudios sobre la ziprasidona (Geodon^®^) para saber si alivia los síntomas | Aunque es posible que los médicos observen pequeñas mejorías en las pruebas para la evaluación de los síntomas, no existe la investigación suficiente para saber cuántos tendrán la probabilidad de experimentar el mismo resultado.
Trastorno de ansiedad generalizada | Alivió los síntomas cerca de un 50 por ciento | - Quetiapina (Seroquel^®^) | De cada 8 personas que tomaron este medicamento, 1 observó este beneficio.
Depresión grave^*^ | Alivió los síntomas por lo menos en un 50 por ciento o los hizo desaparecer por completo | - Aripiprazol (Abilify^®^), olanzapina (Zyprexa^®^), quetiapina (Seroquel^®^) o risperidona (Risperdal^®^) combinados con un antidepresivo; - Quetiapina XR (Seroquel XR^®^) tomada sola | En las investigaciones para elaborar este resumen se evaluó la posibilidad de ese beneficio solamente en el caso de la risperidona (Risperdal^®^) y la quetiapina XR (Seroquel XR^®^):; - De cada 7 personas que tomaron risperidona (Risperdal^®^), 1 notó alivio de los síntomas.; - De cada 8 personas que tomaron risperidona (Risperdal^®^), 1 notó que desaparecieron todos los síntomas.; - De cada 6 personas que tomaron quetiapina XR (Seroquel XR^®^), 1 notó alivio de los síntomas.; - De cada 13 personas que tomaron quetiapina XR (Seroquel XR^®^), 1 notó que desaparecieron todos los síntomas.
Trastorno de estrés postraumático (PTSD, por su sigla en inglés y relacionado con el combate militar) | Ligero alivio de los síntomas | - Risperidona (Risperdal^®^), combinada con un antidepresivo | Aunque algunas personas observaron cierto beneficio, no existe suficiente investigación para saber cuántas tendrán la probabilidad de observar el mismo resultado.
Trastorno obsesivo-compulsivo | Alivió los síntomas por lo menos en un 25 a 35 por ciento | - Risperidona (Risperdal^®^), combinada con un antidepresivo | De cada 5 personas que tomaban este medicamento, 1 notó este beneficio.
Trastornos de la alimentación (anorexia nerviosa) | NO ayudó a las personas a subir de peso | - Olanzapina (Zyprexa^®^) | No hubo mucha diferencia entre los que tomaron este medicamento y los que no lo tomaron.
Abuso de drogas y bebidas alcohólicas | NO ayudó a las personas a reducir la cantidad de bebidas alcohólicas o drogas que consumían, ni la cantidad de tiempo que permanecían sin usarlas | - Todos los antipsicóticos incluidos en este resumen | No hubo gran diferencia entre los que tomaron un antipsicótico y los que no lo tomaron.

* La Food and Drug Administration (Administración de Alimentos y Medicamentos de Estados Unidos; FDA, por su sigla en inglés) aprobó que se añadan los antipsicóticos aripiprazol (Abilify^®^), olanzapina (Zyprexa^®^) y quetiapina (Seroquel^®^) a otros medicamentos, para el tratamiento de la depresión grave.

XR = liberación prolongada

### ¿Qué dicen las investigaciones sobre los efectos secundarios o los riesgos de los antipsicóticos?

Los antipsicóticos producen muchos efectos secundarios o riesgos. Algunos de esos efectos secundarios y riesgos son graves.

Efectos secundarios o riesgos de los antipsicóticos

¿Qué efecto secundario o riesgo? | ¿Cuál medicamento? | | ¿Qué tan probable es el efecto secundario o el riesgo?
Muerte en ancianos^*^ con demencia | - Todos los antipsicóticos incluidos en este resumen, a excepción de la ziprasidona (Geodon^®^); - No existen suficientes estudios sobre la ziprasidona (Geodon^®^) para saber si produce este efecto secundario | | De cada 100 personas que tomaron uno de estos medicamentos, 1 experimentó este efecto secundario.
Derrame cerebral en ancianos^*^ | - Risperidona (Risperdal^®^) | | De cada 34 personas que tomaron este medicamento, 1 experimentó este efecto secundario.
Movimientos incontrolables, como temblores o tics | En los ancianos^*^:; - Olanzapina (Zyprexa^®^); - Risperidona (Risperdal^®^) | En los adultos de 18 a 64 años:; - Aripiprazol (Abilify^®^)^†^; - Quetiapina (Seroquel^®^)^†^; - Ziprasidona (Geodon^®^)^†^ | En los ancianos^*^:; - De cada 10 personas que tomaron olanzapina (Zyprexa^®^), 1 experimentó este efecto secundario.; - De cada 20 personas que tomaron risperidona (Risperdal^®^), 1 experimentó este efecto secundario.; En los adultos de 18 a 64 años:; - De cada 11 personas que tomaron aripiprazol (Abilify^®^), 1 experimentó este efecto secundario.; - De cada 36 personas que tomaron quetiapina (Seroquel^®^), 1 experimentó este efecto secundario.; - De cada 24 personas que tomaron ziprasidona (Geodon^®^), 1 experimentó este efecto secundario.
Aumento de peso | - Todos los antipsicóticos incluidos en este resumen, excepto la ziprasidona (Geodon^®^)^†^; - Las personas que tomaron olanzapina (Zyprexa^®^) tuvieron el mayor riesgo de subir de peso | | - Olanzapina (Zyprexa^®^): De cada 3 personas que tomaron este medicamento, 1 experimentó este efecto secundario.; - Los demás antipsicóticos incluidos en este resumen, excepto la ziprasidona (Geodon^®^): De cada 25 personas que tomaron uno de estos medicamentos, 1 experimentó este efecto secundario.
Sueño excesivo, cansancio y poca alerta | - Todos los antipsicóticos incluidos en este resumen | | En los ancianos^*^:; - De cada 12 personas que tomaron un antipsicótico, 1 sintió sueño; - De cada 19 personas que tomaron un antipsicótico, 1 sintió cansancio; En los adultos de 18 a 64 años:; - De cada 7 personas que tomaron un antipsicótico, 1 sintió sueño. Las personas que tomaron quetiapina (Seroquel^®^) tuvieron sueño excesivo con más frecuencia.; - De cada 17 personas que tomaron un antipsicótico, 1 sintió cansancio.
Infecciones e incontinencia^‡^ urinaria en los ancianos^*,†^ | - Olanzapina (Zyprexa^®^); - Quetiapina (Seroquel^®^); - Risperidona (Risperdal^®^); - No existen suficientes estudios sobre la ziprasidona (Geodon^®^) y el aripiprazol (Abilify^®^) para saber si producen estos efectos secundarios | | Aunque algunas personas experimentaron estos efectos secundarios, no existe suficiente investigación para saber cuántas tendrán la probabilidad de tener el mismo resultado.

* Anciano = persona de 65 años o más.

† Así lo indicaron algunos estudios, pero no existe suficiente investigación para poder afirmarlo con certeza.

‡ La incontinencia es una condición en la que la persona siente un fuerte impulso de orinar o se le escapa la orina al toser, reír o caminar.

### ¿Cuáles son otros efectos secundarios posibles?

Los antipsicóticos pueden causar otros efectos secundarios que no se incluyeron en estas investigaciones. Están incluidos en la lista de la Food and Drug Administration (Administración de Alimentos y Medicamentos, FDA por su sigla en inglés).

¿Qué efecto secundario? | ¿Cuáles medicamentos?
Colesterol alto | - Aripiprazol (Abilify^®^); - Olanzapina (Zyprexa^®^); - Quetiapina (Seroquel^®^)
Hinchazón de tobillos y pantorrillas | - Olanzapina (Zyprexa^®^); - Risperidona (Risperdal^®^)
Presión arterial baja | Todos los antipsicóticos incluidos en este resumen
Mareo o sensación de desmayo | Todos los antipsicóticos incluidos en este resumen
Dolores de cabeza | Todos los antipsicóticos incluidos en este resumen
Estreñimiento | - Aripiprazol (Abilify^®^); - Olanzapina (Zyprexa^®^); - Quetiapina (Seroquel^®^); - Risperidona (Risperdal^®^)
Resequedad de la boca | - Olanzapina (Zyprexa^®^); - Quetiapina (Seroquel^®^); - Risperidona (Risperdal^®^)
Aumento de la cantidad de la hormona llamada prolactina en el cuerpo^*^ | - Olanzapina (Zyprexa^®^); - Quetiapina (Seroquel^®^; - Risperidona (Risperdal^®^); - Ziprasidona (Geodon^®^)

* El aumento de la prolactina puede causar problemas de la función sexual y agrandamiento de los senos en hombres y mujeres.

## Tome una decisión

### ¿En qué debo pensar al tomar mi decisión?

Se deben considerar varios factores al momento de decidir si un medicamento antipsicótico es adecuado para usted o la persona a quien cuida. Solamente usted y su médico podrán decidir si la capacidad que tenga cualquier medicamento de ayudarle compensa el riesgo de tolerar un efecto secundario grave. Cada persona responde de manera diferente a los diversos medicamentos antipsicóticos. Su médico puede probar con varios medicamentos antes de encontrar el correcto.

Usted y su médico deben hablar de:

- Qué tan bien funcionan o podrían funcionar para aliviar los síntomas, otros medicamentos que no son antipsicóticos.
- El riesgo de un efecto secundario grave, tomando en cuenta sus antecedentes médicos y el tiempo que podría durar el efecto secundario.
- Cómo sopesar los beneficios y los efectos secundarios específicos de cada medicamento, en usted o la persona a quien cuida.
- La probabilidad de que los medicamentos causen aumento de peso o requieran cambios en su estilo de vida.
- Las maneras en que el médico puede ayudarle a identificar los efectos secundarios, de modo que estos puedan tratarse o el medicamento que está tomando se pueda cambiar.
- El costo de cada medicamento.
- Otros medicamentos y suplementos que esté tomando y cómo pueden afectar su tratamiento.

#### ¿Cuánto cuestan los medicamentos?

Los precios de mayoreo de los antipsicóticos con receta se proporcionan en la página siguiente. Los precios de mayoreo son los precios que pagan las farmacias. Estos precios se muestran aquí para que pueda usted comparar los costos de los distintos medicamentos.

El costo que cada medicamento tenga para usted dependerá de su seguro médico, de la dosis (cantidad) que necesite y si el medicamento existe en forma genérica.

Costos de mayoreo de los antipsicóticos con receta

Nombre del medicamento | Dosis diaria | Forma | Precio del genérico por mes^*^ | Nombre comercial | Precio del de marca por mes^*^
Aripiprazol | 2 mg | Tableta | ND | Abilify^®^ | $657
Aripiprazol | 5 mg | Tableta | ND | Abilify^®^ | $654
Aripiprazol | 10 mg | Tableta | ND | Abilify^®^ | $657
Aripiprazol | 15 mg | Tableta | ND | Abilify^®^ | $657
Aripiprazol | 20 mg | Tableta | ND | Abilify^®^ | $928
Aripiprazol | 30 mg | Tableta | ND | Abilify^®^ | $928
Olanzapina | 2.5 mg | Tableta | $336 | Zyprexa^®^ | $373
Olanzapina | 5 mg | Tableta | $423 | Zyprexa^®^ | $441
Olanzapina | 7.5 mg | Tableta | $482 | Zyprexa^®^ | $536
Olanzapina | 10 mg | Tableta | $622 | Zyprexa^®^ | $664
Olanzapina | 15 mg | Tableta | $918 | Zyprexa^®^ | $996
Olanzapina | 20 mg | Tableta | $1,213 | Zyprexa^®^ | $1,328
Quetiapina | 25 mg | Tableta | ND | Seroquel^®^ | $116
Quetiapina | 50 mg | Tableta | ND | Seroquel^®^ | $232
Quetiapina | 100 mg | Tableta | ND | Seroquel^®^ | $381
Quetiapina | 200 mg | Tableta | ND | Seroquel^®^ | $398
Quetiapina | 400 mg | Tableta | ND | Seroquel^®^ | $750
Quetiapina | 600 mg | Tableta | ND | Seroquel^®^ | $983
Quetiapina | 800 mg | Tableta | ND | Seroquel^®^ | $1,156
Risperidona | 0.25 mg | Tableta | $117 | Risperdal^®^ | $166
Risperidona | 0.5 mg | Tableta | $128 | Risperdal^®^ | $182
Risperidona | 1 mg | Tableta | $136 | Risperdal^®^ | $194
Risperidona | 2 mg | Tableta | $228 | Risperdal^®^ | $323
Risperidona | 3 mg | Tableta | $267 | Risperdal^®^ | $380
Risperidona | 4 mg | Tableta | $360 | Risperdal^®^ | $510
Risperidona | 6 mg | Tableta | $534 | Risperdal^®^ | $759
Ziprasidona | 40 mg | Cápsula | ND | Geodon^®^ | $548
Ziprasidona | 60 mg | Cápsula | ND | Geodon^®^ | $332
Ziprasidona | 80 mg | Cápsula | ND | Geodon^®^ | $457
Ziprasidona | 160 mg | Cápsula | ND | Geodon^®^ | $665

* Los precios son los precios promedio de mayoreo según el RED BOOK Online^®^. Los precios del medicamento genérico son el valor medio de los precios fijados por los diferentes fabricantes. Los precios reales de los medicamentos pueden ser más altos o más bajos que los mostrados aquí, dependiendo del fabricante al que compre su farmacia.

ND = no disponible

#### Pregunte a su médico

- ¿Cuáles son sus razones para recomendar que yo o la persona a quien cuido tome un antipsicótico o agregue uno al tratamiento?
- ¿De qué otra forma podemos tratar la condición sin usar antipsicóticos?
- ¿Cuánto tiempo tardará en empezar a hacer efecto el medicamento?
- ¿A qué efectos secundarios debo prestar atención y cuándo debo avisarle si aparecen?
- ¿Cómo llevaremos un control de mi peso, colesterol y riesgo de padecer de diabetes?
- ¿Un antipsicótico interferirá con otros medicamentos que estoy tomando?

Otras preguntas:

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

Anote aquí las respuestas:

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

## Fuente

La información de este resumen proviene del informe Off-Label Use of Atypical Antipsychotics: An Update (Antipsicóticos atípicos y usos distintos a los señalados en la etiqueta: actualización), septiembre de 2011.

El informe fue producido por el Southern California Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia del Sur de California), con financiamiento de la Agency for Healthcare Research and Quality (Agencia para la Investigación y Calidad de la Atención Médica; AHRQ, por su sigla en inglés).

Para obtener una copia del informe o más información sobre la AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atención Médica), visite www.effectivehealthcare.ahrq.gov/offlabelantipsych.cfm (disponible sólo en inglés). Se obtuvo información adicional de la página web de MedlinePlus^®^, un servicio de la National Library of Medicine (Biblioteca Nacional de Medicina) y de los National Institutes of Health (Institutos Nacionales de la Salud) de Estados Unidos. Esta página web está disponible en http://www.nlm.nih.gov/medlineplus/spanish/medlineplus.html

Este resumen fue preparado por el John M. Eisenberg Center for Clinical Decisions and Communications Science at Baylor College of Medicine (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas, en la Facultad de Medicina de Baylor) en Houston, Texas. Este resumen fue revisado por pacientes y personas que cuidan a pacientes que toman antipsicóticos aprobados por la Food and Drug Administration (Administración de Alimentos y Medicamentos, FDA por su sigla en inglés) pero con un uso distinto al presentado en la etiqueta (off-label drugs como se conoce en inglés).

Esta guía fue traducida de la publicación en inglés titulada Treating Mental Health Conditions: A Review of the Research for Adults and Caregivers.