# Medicamentos antipsicóticos para tratar la esquizofrenia y el trastorno bipolar

Revisión de las investigaciones para adultos y personas que ayudan al cuidado

## ¿Es esta información apropiada para mí?

### Sí, esta información es apropiada para usted si

- Un médico ha dicho que usted o la persona a quien cuida tiene esquizofrenia o trastorno bipolar.
- Un médico ha recomendado uno de los medicamentos de la lista a continuación.^*^ Estos medicamentos se llaman “antipsicóticos” porque se crearon para tratar enfermedades mentales graves, como la psicosis. Ahora los antipsicóticos se usan para tratar muchas condiciones y síntomas de salud mental, no sólo la psicosis. Existen dos generaciones de antipsicóticos: los antiguos y los nuevos.

#### Antipsicóticos antiguos

- Clorpromazina (Thorazine^®^)
- Flufenazina (Prolixin^®^)
- Haloperidol (Haldol^®^)
- Perfenazina (Trilafon^®^)
- Tioridazina (Mellaril^®^)
- Trifluoperazina (Stelazine^®^)

#### Antipsicóticos nuevos

- Aripiprazol (Abilify^®^)
- Asenapina (Saphris^®^)
- Clozapina (Clozaril^®^, FazaClo^®^)
- Olanzapina (Zyprexa^®^)
- Quetiapina (Seroquel^®^)
- Risperidona (Risperdal^®^)
- Ziprasidona (Geodon^®^)

- Usted tiene 18 años o más. La información de este resumen proviene de investigaciones en adultos.

### ¿Qué aprenderé con este resumen?

Este resumen habla de un tipo de medicamentos—los antipsicóticos—que se utilizan para tratar la esquizofrenia y el trastorno bipolar. Le explicará lo que dicen las investigaciones sobre las diferencias entre los antipsicóticos antiguos y los nuevos para tratar la esquizofrenia y el trastorno bipolar en adultos. Tenga en cuenta que los estudios acerca del uso de antipsicóticos para tratar el trastorno bipolar son limitados y que se requiere más investigación. Este resumen explica también los efectos secundarios posibles de los antipsicóticos. Puede ayudarle a hablar con su médico para saber si alguno de estos medicamentos sería apropiado para usted.

Aparte de los antipsicóticos, este resumen no habla de otros medicamentos para tratar la esquizofrenia o el trastorno bipolar, como los estabilizadores del estados de ánimo o los antidepresivos. El resumen no habla tampoco de tratamientos sin medicamentos, como la psicoterapia.

### ¿De dónde proviene la información?

Investigadores financiados por la Agency for Healthcare Research and Quality (Agencia para la Investigación y Calidad de la Atención Médica; AHRQ, por su sigla en inglés), una agencia de investigación del Gobierno Federal, revisaron 114 estudios sobre el uso de medicamentos antipsicóticos para tratar la esquizofrenia y 12 estudios para tratar el trastorno bipolar, publicados hasta julio de 2011. El informe fue revisado por clínicos, investigadores, expertos y el público. El informe puede leerse en www.effectivehealthcare.ahrq.gov/antipsychotics-adult.cfm (disponible sólo en inglés).

## Conozca su condición

### ¿Qué es la esquizofrenia?

La esquizofrenia es un trastorno grave del cerebro que hace que la persona pueda oír voces o ver cosas que no son reales. Los científicos no están seguros sobre qué causa la esquizofrenia, pero el trastorno puede presentarse en varias generaciones de una misma familia. La estructura o la química cerebral de una persona y el ambiente en que vive pueden también contribuir al desarrollo de la esquizofrenia. En Estados Unidos, aproximadamente 1 de cada 100 personas tiene esquizofrenia.

Aunque los síntomas de la esquizofrenia pueden variar de una persona a otra, los más frecuentes son:

- Alucinaciones: ver u oír cosas que no existen
- Delirios: creer cosas que son irracionales o no son ciertas.
  - Son ejemplos de delirio la idea de que otros pueden leerle la mente, la creencia de que otros intentan controlar su mente, o la preocupación constante de que otros estén tratando de hacerle daño.
- Dificultad para comunicarse y decir cosas que no tienen sentido
- Problemas de movimiento: repetir movimientos constantemente o no moverse en absoluto
- Dificultad para mostrar las emociones: hablar con voz inexpresiva y no mostrar expresiones faciales, como sonreír o fruncir el ceño
- Dificultad para interactuar con otras personas
- Dificultad para prestar atención y tomar decisiones
- Pensamientos suicidas

### ¿Cómo se trata la esquizofrenia?

- La esquizofrenia puede tratarse con medicamentos y psicoterapia (hablar con un terapeuta capacitado). Los medicamentos antipsicóticos se usan a menudo para tratar los síntomas de esquizofrenia. Estos medicamentos no curan la esquizofrenia, pero pueden ayudar a mejorar su capacidad para funcionar y su calidad de vida. Cada persona responde de manera diferente a los diversos medicamentos antipsicóticos. Es posible que deba probar varios medicamentos antes de encontrar el más eficaz para usted.
- Su médico también puede sugerirle otros tratamientos sin medicamentos que pueden ayudarle a hacer frente a su enfermedad y síntomas. Esos tratamientos pueden consistir en: consejería, grupos de autoayuda y programas para aprender a controlar su enfermedad.
- En ocasiones, los médicos sugerirán la hospitalización para ayudar a controlar los síntomas de la persona con esquizofrenia.

Nota: Este resumen se ocupa solamente de los medicamentos antipsicóticos que se usan para tratar la esquizofrenia. No habla de los tratamientos sin medicamentos ni de la hospitalización.

### ¿Qué es el trastorno bipolar?

El trastorno bipolar, conocido también como enfermedad maniacodepresiva, es un trastorno cerebral grave que causa cambios repentinos e intensos en el estado de ánimo. Las personas con trastorno bipolar pasan de sentirse muy contentas y llenas de energía, a sentirse sin esperanzas y muy deprimidas; y este ciclo vuelve y se repite. Estas “subidas” (llamadas manía) y “bajadas” (llamadas depresión) son mucho más intensas que los altibajos normales que todos experimentamos de vez en cuando. Los científicos piensan que el trastorno bipolar puede presentarse en varias generaciones de una misma familia. También la estructura cerebral de las personas puede contribuir al desarrollo del trastorno bipolar.

De cada 100 personas en los Estados Unidos, entre menos de 1 y hasta 3 padecen de trastorno bipolar.

Aunque los síntomas varían de una persona a otra, a continuación se dan ejemplos de síntomas frecuentes de manía y depresión.

#### Son síntomas de manía

- Sentirse muy animado o con mucha energía
- Sentirse nervioso, agitado o irritable
- Sentirse invencible; como si nada pudiera hacerle daño
- Enfurecerse fácilmente
- Estar demasiado activo
- Hablar rápidamente y cambiar pronto de tema
- Sentir poca necesidad de dormir
- Actuar imprudentemente o correr riesgos (por ejemplo, consumir drogas, tener relaciones sexuales sin protección o gastar mucho dinero)

#### Son síntomas de depresión

- Sentirse desanimado o triste
- Sentirse muy preocupado, sin esperanzas o sin autoestima
- Tener dificultad para concentrarse y para recordar las cosas
- Perder el interés en actividades que solía disfrutar
- Sentirse cansado y volverse mucho menos activo
- Comer mucho más o mucho menos que lo usual
- Tener dificultad para dormir
- Pensar a menudo en la muerte o considerar el suicidio

### ¿Cómo se trata el trastorno bipolar?

- El trastorno bipolar puede tratarse con medicamentos o psicoterapia (hablar con un terapeuta capacitado). Entre los medicamentos para tratar el trastorno bipolar están los estabilizadores del ánimo (como el litio), los medicamentos antipsicóticos y los medicamentos antidepresivos. Cada persona responde de manera diferente a los diversos medicamentos antipsicóticos. Es probable que necesite probar varios medicamentos o combinaciones de ellos antes de encontrar el más eficaz para usted.
- Su médico también puede sugerirle otros tratamientos sin medicamentos que puedan ayudarle a sobrellevar su enfermedad y los síntomas. Entre esos tratamientos están la consejería o los grupos de apoyo.
- En ocasiones, los médicos recomendarán la hospitalización para ayudar a las personas con trastorno bipolar a estabilizar su ánimo.

Nota: Este resumen describe el tratamiento del trastorno bipolar solamente con medicamentos antipsicóticos. No se refiere a otros medicamentos, tratamientos sin medicamentos ni la hospitalización.

## Conozca los antipsicóticos

### ¿Qué son los medicamentos antipsicóticos?

Los medicamentos antipsicóticos se crearon para ayudar a las personas que tienen enfermedades mentales graves, como la psicosis. Los antipsicóticos se utilizan ahora para tratar muchas condiciones y síntomas de salud mental, no sólo la psicosis. Actúan mediante la modificación del efecto que tienen ciertas sustancias en el cerebro. Los medicamentos antipsicóticos no curan las enfermedades mentales; más bien se utilizan para ayudar a aliviar los síntomas y mejorar la calidad de vida.

Los medicamentos antipsicóticos se dividen en dos “generaciones”. Los médicos suelen referirse a ellos como antipsicóticos “antiguos” (llamados también “típicos”) o antipsicóticos “nuevos” (o “atípicos”). Los medicamentos antipsicóticos se presentan en forma de pastillas que deben tomarse todos los días. Algunos antipsicóticos vienen también en inyecciones y se aplican en el consultorio médico o en el hospital.

Medicamentos antipsicóticos

Antipsicóticos antiguos
Nombre comercial | Nombre del medicamento | ¿Existe en genérico?
Haldol^®^ | Haloperidol | Sí
Mellaril^®^ | Tioridazina | Sí
Navane^®^* | Tiotixeno^*^ | Sí
Prolixin^®^ | Flufenazina | Sí
Stelazine^®^ | Trifluoperazina | Sí
Thorazine^®^ | Clorpromazina | Sí
Trilafon^®^ | Perfenazina | Sí
Antipsicóticos nuevos
Nombre comercial | Nombre del medicamento | ¿Existe en genérico?
Abilify^®^ | Aripiprazol | No
Clozaril^®^; FazaClo^®^ | Clozapina | Sí
Fanapt^®^* | Iloperidona^*^ | No
Geodon^®^ | Ziprasidona | Sí
Invega^®^* | Paliperidona^*^ | No
Latuda^®^* | Lurasidona^*^ | No
Risperdal^®^ | Risperidona | Sí
Saphris^®^ | Asenapina | No
Seroquel^®^ | Quetiapina | Sí
Zyprexa^®^ | Olanzapina | Sí

* Estos medicamentos no se estudiaron en la investigación para este resumen.

### ¿Qué dicen las investigaciones sobre cómo se comparan los antipsicóticos antiguos y los nuevos?

Tanto los antipsicóticos antiguos como los nuevos sirven para tratar los síntomas de la esquizofrenia y el trastorno bipolar. Sin embargo, estudios de investigación en los que se compararon los antipsicóticos nuevos con el antipsicótico antiguo haloperidol (Haldol^®^)^*^ encontraron sólo algunas diferencias en cuanto a beneficios.

#### Esquizofrenia

Para tratar los síntomas de esquizofrenia, como alucinaciones, delirios, dificultad para comunicarse y problemas de movimiento:

- El nuevo antipsicótico olanzapina (Zyprexa^®^) actúa casi con la misma eficacia que el antipsicótico antiguo haloperidol (Haldol^®^).

Para tratar los síntomas de esquizofrenia consistentes en dificultad para mostrar las emociones y dificultad para interactuar con otros:

- Los antipsicóticos nuevos aripiprazol (Abilify^®^), olanzapina (Zyprexa^®^) y risperidona (Risperdal^®^) son más eficaces que el antipsicótico antiguo haloperidol (Haldol^®^).

Para tratar los síntomas generales de salud mental (como ansiedad, culpa, tensión, atención deficiente y poco juicio) en las personas con esquizofrenia:

- El antipsicótico nuevo olanzapina (Zyprexa^®^) es más eficaz que el antipsicótico antiguo haloperidol (Haldol^®^).

#### Trastorno bipolar

Para tratar los síntomas de manía del trastorno bipolar:

- Los antipsicóticos nuevos aripiprazol (Abilify^®^), olanzapina (Zyprexa^®^) y risperidona (Risperdal^®^) parecen tener la misma eficacia que el antipsicótico antiguo haloperidol (Haldol^®^), pero se necesita investigar más para saberlo con certeza.

### ¿Cuáles son los posibles efectos secundarios de los medicamentos antipsicóticos?

La Food and Drug Administration (Administración de Alimentos y Medicamentos, FDA; por su sigla en inglés) de Estados Unidos lista los siguientes efectos secundarios posibles de los medicamentos antipsicóticos.^*^

Los antipsicóticos antiguos y nuevos pueden causar:

- Movimientos incontrolables, como tics y temblores (el riesgo es mayor con los antipsicóticos antiguos)
- Sueño excesivo
- Mareos
- Inquietud
- Aumento de peso (el riesgo es mayor con los antipsicóticos nuevos)
- Resequedad de la boca
- Estreñimiento
- Náusea
- Vómito
- Visión borrosa
- Presión arterial baja
- Convulsiones
- Número bajo de glóbulos blancos (células que combaten infecciones)

Todos los medicamentos antipsicóticos considerados en este resumen, excepto el aripiprazol (Abilify^®^) y la clozapina (Clozaril^®^ o FazaClo^®^), pueden causar un aumento de la hormona del cuerpo llamada prolactina. El aumento de la prolactina puede ocasionar problemas en la función sexual y agrandamiento de los senos en hombres y mujeres.

Posibles efectos secundarios graves de los medicamentos antipsicóticos

- Los antipsicóticos antiguos y nuevos pueden causar una condición que provoque movimientos musculares incontrolables. En ocasiones, esa condición desaparece al interrumpir el medicamento, pero otras veces es permanente. El riesgo de desarrollar esta condición puede ser mayor con los antipsicóticos antiguos que con los nuevos.
- Los antipsicóticos antiguos y nuevos pueden causar una reacción potencialmente mortal llamada “síndrome neuroléptico maligno”, aunque es un muy raro. Los síntomas incluyen fiebre alta, sudor excesivo, variaciones amplias de la presión arterial y rigidez de los músculos.
- En algunas personas, el antipsicótico nuevo clozapina (Clozaril^®^ o FazaClo^®^) puede causar una condición grave en la sangre que consiste en una disminución severa de los glóbulos blancos. Su médico necesitará hacer pruebas de sangre frecuentes para detectar la aparición de esta condición. La clozapina también puede causar inflamación del músculo del corazón.
- Los investigadores no saben si el uso de antipsicóticos durante el embarazo podría dañar al feto. Si está usted embarazada o tiene planeado embarazarse, consulte a su médico antes de tomar un medicamento antipsicótico.

## Tome una decisión

### ¿En qué debo pensar al tomar mi decisión?

Se deben considerar varios factores al momento de decidir si un medicamento antipsicótico es adecuado para usted o la persona a quien cuida. Solamente usted y su médico podrán decidir si la capacidad que tenga algún medicamento de ayudar compensa el riesgo de tener un efecto secundario grave. Cada persona responde de manera diferente a los diversos medicamentos antipsicóticos. El médico puede probar con varios medicamentos antes de encontrar el correcto. Lo más importante es encontrar el medicamento que le sea más eficaz.

Usted y su médico deberán hablar de:

- Los posibles beneficios de tomar un medicamento antipsicótico.
- Qué medicamento antipsicótico sería mejor para usted o la persona a quien cuida.
- Los efectos secundarios posibles de tomar un medicamento antipsicótico y lo que esto representa para usted.
- El riesgo de que se presente un efecto secundario grave.
- Formas para ayudarle a reconocer los efectos secundarios, para poder tratarlos o para cambiar el medicamento.
- Qué tratamiento se adapta mejor a sus preferencias y valores personales.
- El costo de cada medicamento.

### ¿Cuánto cuestan los medicamentos?

Los precios de mayoreo de los medicamentos antipsicóticos con receta se presentan a continuación. Los precios de mayoreo son los precios que pagan las farmacias. Los precios se dan aquí para que pueda usted comparar el costo de los distintos medicamentos, de modo que sepa cuáles cuestan más y cuáles menos. El costo que cada medicamento tenga para usted dependerá de su seguro médico, de la dosis (cantidad) que necesite y si el medicamento existe en forma genérica.

Costos de mayoreo de los antipsicóticos con receta

Nombre comercial | Dosis diaria | Forma | Costo del de marca por mes^*^ | Nombre del medicamento | Costo del genérico por mes
Antipsicóticos antiguos
Haldol^®^ | 1 a 30 mg | Tableta | NM | Haloperidol | ND
Mellaril^®^ | 200 a 800 mg | Tableta | NM | Tioridazina | ND
Prolixin^®^ | 1 a 5 mg | Tableta | NM | Flufenazina | $6–$12
Stelazine^®^ | 10 a 20 mg | Tableta | NM | Trifluoperazina | $65–$95
Thorazine^®^ | 50 a 800 mg | Tableta | NM | Clorpromazina | $60–$350
Trilafon^®^ | 8 a 32 mg | Tableta | NM | Perfenazina | ND
Antipsicóticos nuevos
Abilify^®^ | 10 a 15 mg | Tableta | $760 | Aripiprazol | NG
Clozaril^®^; FazaClo^®^ | 300 a 600 mg | Tableta | $975–$1,950; $645–$1,290 | Clozapina | $300–$595
Geodon^®^ | 40 a 160 mg | Cápsula | $600–$725 | Ziprasidona | $530–$645
Risperdal^®^ | 1 a 6 mg | Tableta | $210–$835 | Risperidona | $140–$270
Saphris^®^ | 10 a 20 mg | Tableta sublingual | $750 | Asenapina | NG
Seroquel^®^ | 150 a 300 mg | Tableta | $690–$720 | Quetiapina | $590–$620
Zyprexa^®^ | 10 a 15 mg | Tableta | $665–$995 | Olanzapina | $600–$900

* Los precios son los precios promedio de mayoreo según el REDBOOK Online^®^, redondeados a los $5 más cercanos. Los precios del medicamento genérico son el valor medio del margen de precios publicados de los distintos fabricantes. Los precios reales de los medicamentos pueden ser más altos o más bajos que los mostrados aquí, dependiendo del fabricante al que compre su farmacia.

ND = no disponible; NM = ya no se fabrica el de marca; NG = no existe forma genérica

### Pregunte a su médico

- ¿Qué medicamento antipsicótico está usted considerando para mí o la persona a quien cuido? ¿Por qué?
- ¿Cuánto tiempo tardará en empezar a funcionar el medicamento?
- ¿Por cuánto tiempo deberé usar el medicamento?
- ¿Qué síntomas puede aliviar el medicamento?
- ¿Qué efectos secundarios graves debo buscar y cuándo debo avisarle si aparecen?
- ¿Qué tanto puedo subir de peso por tomar un medicamento antipsicótico? ¿Cuándo debo llamarle en relación con mi aumento de peso?
- ¿Hay riesgo de que me suba el colesterol o padezca de diabetes si tomo uno de los medicamentos antipsicóticos nuevos?
- ¿Qué haremos si el medicamento no funciona? ¿Qué pasa si el medicamento deja de funcionar después de un tiempo y reaparecen los síntomas?
- ¿Puede interactuar un medicamento antipsicótico con otros que esté tomando?
- ¿Hay otros medicamentos o tratamientos sin medicamentos que puedan ayudarme?

## Fuente

La información de este resumen proviene del informe First-Generation Versus Second-Generation Antipsychotics in Adults: Comparative Effectiveness (Antipsicóticos de primera y segunda generaciones en adultos: eficacia comparada). El informe fue producido por el University of Alberta Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia de la Universidad de Alberta), con financiamiento de la Agency for Healthcare Research and Quality (Agencia para la Investigación y Calidad de la Atención Médica; AHRQ, por su sigla en inglés).

Para obtener una copia del informe o más información sobre la AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atención Médica), visite www.effectivehealthcare.ahrq.gov/antipsychotics-adult.cfm (disponible sólo en inglés). Se obtuvo información adicional de la página web MedlinePlus^®^, un servicio de la National Library of Medicine (Biblioteca Nacional de Medicina) y de los National Institutes of Health (Institutos Nacionales de la Salud) de Estados Unidos. Esta página está disponible en www.nlm.nih.gov/medlineplus/spanish.

Este resumen fue preparado por el John M. Eisenberg Center for Clinical Decisions and Communications Science at Baylor College of Medicine (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas, en la Facultad de Medicina de Baylor) en Houston, Texas. Revisaron este resumen pacientes con esquizofrenia o trastorno bipolar, o las personas responsables de su cuidado.

Esta guía fue traducida de la publicación en inglés titulada Antipsychotic Medicines for Treating Schizophrenia and Bipolar Disorder; A Review of the Research for Adults and Caregivers.

* Existen otros medicamentos antipsicóticos, aparte de los que se mencionan aquí. Estos son los que se estudiaron en las investigaciones para este resumen.

* El haloperidol (Haldol^®^) puede no ser representativo de todos los antipsicóticos antiguos. No existe suficiente investigación para saber con certeza cómo se comparan otros antipsicóticos antiguos a los nuevos.

* Si desea información sobre la probabilidad que tienen varios medicamentos antipsicóticos nuevos de causar determinados efectos secundarios, consulte el resumen de investigación para el consumidor titulado Medicamentos para tratar condiciones de salud mental: Revisión de las investigaciones para adultos y personas que ayudan al cuidado. Si desea una copia gratis, llame al 800-358-9295 y pida la Publicación de AHRQ N° 11(13)-EHC087-B, o bien, descargue e imprima una copia en http://effectivehealthcare.ahrq.gov/search-for-guides-reviews-and-reports/?pageaction=displayProduct&productID=1336.