# Guía para pacientes que están en tratamiento de una cardiopatía coronaria estable

## ¿Es esta guía apropiada para mí?

### Esta guía es para usted, si…

- tiene cardiopatía coronaria (enfermedad coronaria), una enfermedad que afecta las arterias del corazón. Tal vez tuvo un ataque al corazón o le da un dolor en el pecho cuando hace ejercicio, pero sus síntomas no cambian.
- su cardiopatía coronaria está en estado “estable”. Eso significa que sus síntomas no han cambiado ni han empeorado.
- su médico recomienda agregar un medicamento llamado inhibidor de la ECA (en inglés ACE Inhibitor) o un bloqueador BRA (en inglés ARB).
- no toma medicamentos para la presión arterial alta, también llamada “hipertensión”.

### Esta guía no le ayudará, si…

- está tomando decisiones sobre otros medicamentos que podría tomar para su cardiopatía coronaria.

Se creó esta guía tras la revisión de muchos estudios de investigación realizados sobre este tema. La información que aquí se ofrece tiene la finalidad de ayudarle a elegir entre las varias opciones basándose en la evidencia disponible.

## Conozca su enfermedad

### ¿Qué es la cardiopatía coronaria?

La imagen muestra cómo se ve una cardiopatía coronaria. Las arterias que llevan la sangre al músculo cardiaco se han ido estrechando u obstruyendo. Cuando eso sucede, se dificulta la entrada de sangre y oxígeno al corazón. Cuando un vaso se obstruye, usted puede sentir alguna molestia en el pecho (como dolor, presión u opresión) al hacer algún esfuerzo físico o ejercicio. Es lo que los médicos llaman “angina de pecho”.

### ¿Cuáles son los posibles problemas?

Las personas con cardiopatía coronaria pueden sufrir problemas graves, tales como:

- ataque al corazón
- insuficiencia cardiaca (problemas cardiacos)
- derrame

Cualquiera de estos problemas puede causar la muerte o requerir mucho tiempo de recuperación e impedirle trabajar o realizar otras actividades.

## Conozca el tratamiento de la cardiopatía coronaria

### ¿Cómo puedo protegerme de los posibles problemas?

Aunque no existe cura para la cardiopatía coronaria, algunos medicamentos ayudan a protegerlo de ataques al corazón, insuficiencia cardiaca o derrames.

Su médico puede pedirle que tome uno o varios medicamentos, tales como:

- aspirina en dosis baja o medicamentos que eviten que las plaquetas en la sangre se mantengan agrupadas.
- medicamentos para bajar los niveles de colesterol.
- medicamentos que ayudan a reducir la frecuencia cardiaca (latidos del corazón por minuto) y la presión arterial, como los bloqueadores beta.
- medicamentos que evitan que la sangre se coagule, como la warfarina.
- otros medicamentos para tratar la presión arterial alta o la diabetes.

### ¿Qué me conviene saber sobre los inhibidores de la ECA y los bloqueadores BRA?

Estos dos tipos de medicamentos, los inhibidores de la ECA y los bloqueadores BRA, se han estudiado para saber si también pueden ayudar a evitar otros problemas en las personas con cardiopatía coronaria estable. Ambos tipos de medicamentos bajan la presión arterial alta y se han usado para tratar la insuficiencia cardiaca.

- Inhibidores de la ECA. Su médico puede también llamar a estos medicamentos “inhibidores de la enzima convertidora de angiotensina” o “inhibidores de la ECA”.
- Bloqueadores BRA. Su médico puede también llamar a estos medicamentos “bloqueadores de los receptores de la angiotensina”.

## Conozca sus opciones

Usted y su médico podrán decidir si deben agregar a sus otros medicamentos un inhibidor de la ECA o un bloqueador BRA, una vez que:

- entiendan y comparen los beneficios del medicamento, y
- decidan si los beneficios del medicamento son mayores que los posibles efectos secundarios.

### ¿Es el inhibidor de la ECA adecuado para mí?

Es posible que usted y su médico prefieran agregar un inhibidor de la ECA a sus otros medicamentos para la cardiopatía coronaria, debido a que:

- los médicos conocen mejor los beneficios y efectos secundarios de los inhibidores de la ECA que de los bloqueadores BRA.
- en la mayoría de las personas que toman inhibidores de la ECA, los efectos secundarios sólo son leves.

### ¿Cuáles son los beneficios de agregar un inhibidor de la ECA?

El añadir un inhibidor de la ECA a sus otros medicamentos contra la cardiopatía coronaria puede ofrecer al paciente cuatro beneficios posibles:

- Disminuye su riesgo de morir a causa de un ataque al corazón o una insuficiencia cardiaca.
- Reduce su riesgo de sufrir un ataque al corazón no mortal.
- Reduce su riesgo de ser hospitalizado a causa de insuficiencia cardiaca.
- Reduce su riesgo de necesitar cirugía u otros procedimientos para aumentar el flujo de sangre hacia el músculo cardiaco. Es lo que se llama “revascularización”.

### ¿Cuántos beneficios puedo esperar?

En las dos gráficas siguientes se comparan los resultados observados en 100 personas que agregaron y no agregaron un inhibidor de la ECA a sus otros medicamentos en un periodo de cuatro años.

#### ¿Qué puede pasar si no agrego un inhibidor de la ECA?

De cada 100 personas que toman otros medicamentos para tratar la cardiopatía coronaria sin inhibidores de la ECA, 92 no morirán de un ataque al corazón ni de insuficiencia cardiaca en cuatro años ( [image]), mientras que 8 morirán por estas causas ( [image]).

#### ¿Qué puede pasar si agrego un inhibidor de la ECA?

De cada 100 personas que agregan un inhibidor de la ECA a sus otros medicamentos para tratar la cardiopatía coronaria, 93 no morirán de un ataque al corazón ni de insuficiencia cardiaca en cuatro años ( [image]), mientras que 7 morirán por estas causas ( [image]).

Eso significa, que al haber añadido un inhibidor de la ECA a sus medicamentos contra la cardiopatía coronaria durante cuatro años, una persona más de cada 100 ( [image]) habrá evitado morir a causa de un ataque al corazón o una insuficiencia cardiaca.

La cantidad de beneficios es casi la misma en cuanto a prevenir un ataque al corazón, ser hospitalizado por insuficiencia cardiaca o necesitar cirugía u otro procedimiento para aumentar el flujo de sangre al músculo cardiaco.

#### ¿Cuáles son los posibles efectos secundarios?

Algunas personas que toman un inhibidor de la ECA tienen estos problemas:

- tos.
- desmayo repentino.
- exceso de potasio en la sangre. Puede causar problemas con los latidos del corazón o el ritmo cardiaco. Estos problemas no son comunes.

Algunas personas que toman un inhibidor de la ECA y luego tienen una cirugía para abrir un vaso sanguíneo obstruido tienen más riesgo de:

- otra operación para abrir algún otro vaso sanguíneo obstruido.
- presión arterial baja.

ADVERTENCIA: Algunos estudios indican que los inhibidores de la ECA pueden causar inflamación repentina de lengua, labios, garganta, manos o pies. Es lo que se llama “angioedema” o “angiedema”. Llame a su médico inmediatamente si esto le ocurre. Los inhibidores de la ECA pueden también causar defectos congénitos graves. Si usted está embarazada o cree que puede embarazarse y está tomando un inhibidor de la ECA, informe a su médico y pregúntele qué debe hacer.

### ¿Debo agregar un bloqueador BRA?

Usted podría estar entre las personas que tienen uno o más de los efectos secundarios de los inhibidores de la ECA. En ese caso es posible que usted y su médico decidan agregar a sus otros medicamentos un bloqueador BRA, en lugar de un inhibidor de la ECA.

#### ¿Cuáles son los beneficios de agregar un bloqueador BRA?

Los estudios demuestran que los pacientes que agregan un bloqueador BRA a sus otros medicamentos (al no poder tomar un inhibidor de la ECA) tienen menor riesgo de morir a causa de problemas del corazón o de tener un ataque al corazón o derrame no mortales.

#### ¿Cuáles son los posibles efectos secundarios?

En algunas personas que toman bloqueadores BRA, el potasio en la sangre puede aumentar demasiado, lo cual puede causar problemas del latido o el ritmo cardiaco. No parecen ser problemas comunes. Los bloqueadores BRA pueden causar también angioedema y defectos congénitos (de nacimiento).

#### ¿Necesito un inhibidor de la ECA y un bloqueador BRA?

Un estudio de investigación demostró que tomar ambos tipos de medicamentos no ayuda más que tomar un inhibidor de la ECA solamente. Asimismo, el uso de ambos medicamentos puede causar más efectos secundarios graves; por ejemplo:

- desmayos.
- presión arterial baja.
- problemas de los riñones.

## Decida lo que es mejor para usted

### De los inhibidores de la ECA o bloqueadores BRA, ¿cuál es el mejor para mí?

Existen muchos medicamentos que son inhibidores de la ECA y bloqueadores BRA. Estos medicamentos son fabricados por diferentes compañías. No hay diferencias químicas mayores entre los diversos inhibidores de la ECA ni entre los bloqueadores BRA, pero las dosis y los costos varían.

### ¿Cuánto cuestan?

La cantidad que tendrá que pagar depende de:

- si toma un medicamento genérico o uno de nombre comercial.
- la cantidad de medicamento que toma.
- la cantidad de su copago según su plan de seguro.

La mayoría de los inhibidores de la ECA y bloqueadores BRA existen en presentación genérica. Los medicamentos genéricos generalmente cuestan menos que los de nombre comercial.

Pídale a su médico que le ayude a elegir el medicamento que le resulte más eficaz y que mejor se ajuste a su presupuesto.

Nombres genéricos y comerciales de los inhibidores de la ECA y los bloqueador BRA

Inhibidores de la ECA | Bloqueadores de los receptores de la angiotensina
benazepril (Lotensin) | candesartán (Atacand)
captopril (Capoten) | eprosartán (Tevetan)
enalapril (Vasotec) | irbesartán (Avapro)
fosinopril (Monopril) | losartán (Cozaar)
lisinopril (Prinivil, Zestril) | olmesartán (Benicar)
perindopril (Aceon) | telmisartán (Micardis)
quinapril (Accupril) | valsartán (Diovan)
ramipril (Altace)
trandolapril (Mavik)

### Su médico puede ayudarle a decidir

#### Pregunte a su médico

1. ¿El inhibidor de la ECA o el bloqueador BRA me reducirá el riesgo de muerte, ataque al corazón, o derrame?
2. ¿Los efectos secundarios o posibles daños por tomar estos medicamentos son mayores que los beneficios que obtendré?
3. ¿Necesito que me operen para abrir los vasos alrededor del corazón? ¿Qué tanto cambia esto alguna decisión que podamos tomar sobre el uso de estos dos tipos de medicamentos?
4. ¿Interactuará un inhibidor de la ECA o un bloqueador BRA con los otros medicamentos que tomo?

Otras preguntas que necesita hacer a su médico:

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

Escriba aquí las respuestas a sus preguntas:

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

### Anote sus medicamentos

Utilice esta tabla para llevar un control de los nombres de sus medicamentos, las cantidades y cuándo los toma.

#### Registro de medicamentos

Nombre del medicamento | Cuánto tomo | Cuándo lo tomo

### Otras maneras que ayudan a reducir su riesgo de tener problemas del corazón

Puede reducir su riesgo de tener un ataque al corazón, una insuficiencia cardiaca o un derrame, si usted…

- baja de peso.
- hace ejercicio periódicamente.
- come alimentos bajos en grasa y colesterol.
- no fuma.

Pida a su médico que le ayude a establecer sus metas y empezar a hacer los cambios. MedLine Plus, una página web del gobierno de Estados Unidos, tiene muchos recursos para ayudarle. La página web se encuentra en:

www.nlm.nih.gov/medlineplus/spanish/heartdiseasesprevention.html

## ¿Cuál es la fuente de esta guía?

La información de esta guía deriva del informe Comparative Effectiveness of Angiotensin Converting Enzyme Inhibitors or Angiotensin II Receptor Blockers Added to Standard Medical Therapy for Treating Stable Ischemic Heart Disease (Comparación de la efectividad de los inhibidores de la enzima convertidora de angiotensina y los bloqueadores de los receptores de la angiotensina cuando se añaden al tratamiento médico estándar de la cardiopatía isquémica estable). Fue producida por el University of Connecticut/Hartford Hospital Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia de la Universidad de Connecticut/Hospital Hartford) mediante el financiamiento de la Agency for Healthcare and Research Quality (Agencia para la Investigación y la Calidad de la Atención Médica, AHRQ, por sus siglas en inglés). Para obtener una copia del informe o información sobre la AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atención Médica) visite http://www.effectivehealthcare.ahrq.gov/index.cfm/informacion-en-espanol/. La información adicional deriva de la página web de MedLine Plus, un servicio de la U.S. National Library of Medicine (Biblioteca Nacional de Medicina de Estados Unidos) y los National Institutes of Health (Institutos Nacionales de Salud). Esta página está disponible en http://www.nlm.nih.gov/medlineplus/spanish/medlineplus.html.

La información complementaria deriva de un informe de 2007 titulado Comparative Effectiveness of Angiotensin Converting Enzyme Inhibitors (ACEIs) and Angiotensin II Receptor Antagonists (ARBs) for Treating Essential Hypertension (Comparación de la efectividad de los inhibidores de la enzima convertidora de angiotensina (ECA) y los bloqueadores de los receptores de la angiotensina (bloqueadores BRA) para tratar la hipertensión primaria), AHRQ Pub. No. 08-EHC003-EF, November 2007.

Esta guía abreviada fue preparada por el John M. Eisenberg Center for Clinical Decisions and Communications Science at Baylor College of Medicine (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas, en la Universidad de Medicina de Baylor) en Houston, Texas.