# Vacunas y gotas contra la alergia para adultos y niños

Revisión de los estudios de investigación

## ¿Es esta información apropiada para mí?

### Esta información puede ser útil para usted si

- Su médico^*^ le ha dicho que usted o su niño tienen alergias o asma leve debido a alergias causadas por cosas presentes en el aire, como el polen, el polvo, la caspa de animales domésticos o el moho.
- Usted está considerando usar vacunas contra la alergia o gotas contra la alergia que se ponen bajo la lengua (las vacunas y las gotas contra la alergia se llaman “inmunoterapia para la alergia”).
- Usted quiere saber qué dicen las investigaciones sobre la eficacia de las vacunas y las gotas contra la alergia para aliviar la alergia y los síntomas de asma.

Nota: Este resumen trata solamente de las alergias a las partículas presentes en el aire. La información de este resumen no abarca las alergias alimentarias, alergias a cosas que entran en contacto con la piel (como el látex, los detergentes, los metales o los colorantes para el cabello), las alergias a las picaduras de insectos o las alergias a los medicamentos.

La información contenida en este resumen no es para personas que tengan asma grave.

En la investigación realizada para este resumen, los adultos con asma:

- Tenían asma entre leve y moderadamente grave en los estudios sobre las vacunas contra la alergia
- Tenían asma leve en los estudios con gotas contra la alergia

Nota: Las gotas contra la alergia (llamadas también “inmunoterapia sublingual”) son un líquido que se pone debajo de la lengua. No son gotas para los ojos.

### ¿Qué cubrirá este resumen?

Este resumen cubrirá:

- Lo que son las alergias
- Cómo se tratan las alergias
- Qué han descubierto los investigadores sobre la eficacia de las vacunas y las gotas contra la alergia
- Efectos secundarios posibles de las vacunas y las gotas contra la alergia

Este resumen puede ayudarle a hablar con su médico para determinar si las vacunas o las gotas contra la alergia son apropiadas para usted o para su niño.

### ¿De dónde proviene la información?

Investigadores financiados por la Agency for Healthcare Research and Quality (Agencia para la Investigación y la Calidad de la Atención Médica; AHRQ, por su sigla en inglés), una agencia de investigación del gobierno federal, revisaron 142 estudios acerca de la inmunoterapia específica de alérgeno para tratar alergias o asma leve por alergias, publicados entre enero de 1967 y mayo de 2012. El informe fue revisado por clínicos, investigadores, expertos y el público. El informe puede leerse en www.effectivehealthcare.ahrq.gov/allergy-asthmaimmunotherapy.cfm (disponible sólo en inglés).

## Conozca su condición

### ¿Qué son las alergias?

Una alergia es una reacción que tiene el cuerpo a una sustancia presente en el ambiente.

Este resumen habla de las alergias a partículas presentes en el aire, como el polen, el polvo, la caspa de animales domésticos o el moho. Las alergias ocurren cuando su sistema inmunológico (el sistema que protege al cuerpo de los gérmenes) reacciona a una de estas partículas (llamadas “alérgenos”).

Esta reacción del sistema inmunológico es la que causa los síntomas de alergia. Los síntomas de alergia por los alérgenos presentes en el aire (alérgenos que se transportan con el aire) pueden incluir:

- Estornudos
- Congestión o goteo nasal
- Picazón en la nariz y garganta
- Tos
- Goteo de moco hacia la garganta
- Comezón, lagrimeo o hinchazón de los ojos
- Sensación de presión en la nariz, las mejillas y la frente
- Sarpullido o picazón en la piel

En algunas personas, las alergias pueden también causar síntomas de asma (sibilancia, tos, falta de aire u opresión en el pecho).

Algunas alergias, como las alergias al polen, ocurren solamente en ciertas épocas del año (por ejemplo, cuando los árboles y la hierba sueltan su polen). Se las llama “alergias estacionales” o “fiebre del heno”. Otras, como las alergias al polvo, pueden ocurrir todo el año. Se denominan “alergias perennes”. Una persona puede tener solamente alergias estacionales, solamente alergias perennes o tener ambos tipos de alergias.

### ¿Qué tan frecuentes son las alergias y el asma por alergias?

- En Estados Unidos, aproximadamente 20 de cada 100 personas tienen alergias.
- En Estados Unidos, aproximadamente 9 de cada 100 personas tienen asma.
  - En más de la mitad de las personas con asma, ésta se desencadena por una alergia.

## Conozca sus opciones

### ¿Cómo se tratan las alergias?

Para empezar, su médico posiblemente hablará con usted acerca de sus síntomas y antecedentes médicos y lo examinará para saber qué alergias tiene. Es probable que su médico le recomiende usar medicamentos contra la alergia para ayudar a tratar los síntomas de alergia. Quizá le sugiera también formas de evitar los alérgenos que pueden causarle alergia.

#### Medicamentos contra la alergia

Entre los medicamentos contra la alergia comunes están los antihistamínicos de venta sin receta, como la fexofenadina (Allegra^®^), la loratadina (Claritin^®^) o la cetirizina (Zyrtec^®^). Su médico puede recetarle esteroides que vienen en forma de aerosol nasal, como el propionato de fluticasona (Flonase^®^) o el furoato de mometasona (Nasonex^®^).

#### Formas de evitar los alérgenos

Su médico puede también sugerir formas de evitar los alérgenos (partículas presentes en el aire que pueden causar alergias); por ejemplo, limpieza frecuente de alfombras y cortinas, uso de filtros para aire o uso de cubrecolchones y fundas especiales para almohadas, a fin de reducir la cantidad de alérgenos del polvo que usted inhala mientras duerme.

Si los medicamentos contra la alergia y el esfuerzo por evitar los alérgenos no disminuyen los síntomas en grado suficiente, su médico puede ordenar estudios para identificar la causa de sus alergias. Se pueden hacer pruebas en la piel o de sangre para ver qué alérgenos causan una reacción. Una vez que se descubre la causa de su alergia, su médico puede sugerir vacunas o gotas contra la alergia.

#### Vacunas o gotas contra la alergia

Este tipo de tratamiento funciona de manera diferente a los medicamentos contra la alergia. Las vacunas y las gotas contra la alergia tienen la función de disminuir la reacción del cuerpo a un alérgeno. Su médico puede sugerir vacunas o gotas contra la alergia para que sus síntomas sean menos frecuentes o menos fuertes.

- Vacunas contra la alergia: vacunas que se aplican debajo de la piel (a menudo en la parte superior del brazo), por lo general en el consultorio
- Gotas contra la alergia: un líquido que se pone bajo la lengua y que puede administrárselo en su casa (se llama “inmunoterapia sublingual”)

### ¿Qué son las vacunas y las gotas contra la alergia?

Las vacunas y las gotas contra la alergia ayudan a que su sistema inmunológico se vuelva menos sensible a los alérgenos. Las vacunas y las gotas contienen una cantidad minúscula de los alérgenos que causan sus alergias. Por ejemplo, si usted es alérgico al polen del roble, sus vacunas o gotas contendrán una cantidad minúscula de polen de roble. Tanto las vacunas como las gotas contra la alergia contienen los alérgenos que causan sus alergias. La diferencia entre ambas es, simplemente, la forma en que se administran.

La cantidad del alérgeno presente en las vacunas o gotas contra la alergia es tan pequeña que muy probablemente su sistema inmunológico no tendrá una reacción fuerte. Su médico le explicará lo que debe hacer si tiene una reacción fuerte.

Su médico aumentará poco a poco la cantidad del alérgeno en sus vacunas o gotas, hasta que su sistema inmunológico se vuelva menos sensible al alérgeno. Esto significa que su sistema inmunológico ya no tendrá una reacción fuerte cuando inhale usted el alérgeno. Con el tiempo, su sistema inmunológico comenzará a tolerar el alérgeno y sus síntomas de alergia disminuirán.

Nota: Es posible que algunas personas no puedan tratarse con vacunas o gotas contra la alergia. Debe avisarle a su médico si:

- Usted (o su niño) tiene asma grave
- Usted (o su niño) toma un tipo de medicamento llamado “bloqueador beta”, que se usa para tratar la presión arterial alta
- Usted (o su niño) tiene problemas del corazón
- Está embarazada o está considerando embarazarse
- Está considerando el uso de vacunas o gotas contra la alergia para un niño menor de 5 años de edad

Comparación entre las vacunas y las gotas contra la alergia

| Vacunas contra la alergia | Gotas contra la alergia
¿Cómo se administran? | Las vacunas se aplican debajo de la piel (a menudo en la parte superior del brazo), por lo general en el consultorio. | Las gotas líquidas se ponen debajo de la lengua y suelen administrarse en casa.
¿Con qué frecuencia se administran? | Una o más inyecciones cada vez que acude usted al consultorio:; - Una o dos veces por semana los primeros meses; - Una o dos veces por mes en lo sucesivo | Unas veces por semana o todos los días
¿Durante cuánto tiempo se administran? | 3 a 5 años (a veces más) | En general, 3 a 5 años (a veces más)
¿Están aprobadas por la Food and Drug Administration (Administración de Alimentos y Medicamentos; FDA, por su sigla en inglés) de Estados Unidos para tratar las alergias y el asma causados por alergias? | Sí | La FDA no ha aprobado aún ningún tipo de gotas contra la alergia^*^, pero están aprobadas y se usan comúnmente en Europa y otras partes del mundo. Las gotas contra la alergia se consiguen en Estados Unidos y los médicos están empezando a recetarlas.

* Debido a que las gotas contra la alergia aún no han sido aprobadas por la FDA, es posible que no estén cubiertas por su seguro médico.

### ¿Qué han descubierto los investigadores sobre la eficacia de las vacunas y las gotas contra la alergia?

En los adultos:

- Tanto las vacunas como las gotas contra la alergia mejoran la alergia y los síntomas leves de asma.
- Tanto las vacunas como las gotas contra la alergia disminuyen la necesidad de tomar medicamentos para la alergia y el asma.
- Tanto las vacunas como las gotas contra la alergia mejoran la calidad de vida.

En los niños:

- Tanto las vacunas como las gotas contra la alergia mejoran la alergia y los síntomas leves de asma.
- Las gotas contra la alergia disminuyen la necesidad de tomar medicamentos para la alergia y el asma.
- Al parecer, las vacunas contra la alergia también disminuyen la necesidad de tomar medicamentos contra la alergia y el asma, pero se requiere más investigación para saberlo con certeza.

Los investigadores encontraron también que:

- No existe suficiente investigación para saber si las vacunas contra la alergia son más eficaces que las gotas contra la alergia.

### ¿Cuáles son los posibles efectos secundarios de las vacunas y las gotas contra la alergia?

Las vacunas y las gotas contra la alergia son seguras y los efectos secundarios suelen ser leves.

Algunos efectos secundarios comunes de las vacunas contra la alergia son:

- Picazón, hinchazón y enrojecimiento en el sitio donde se aplicó la vacuna
- Dolor de cabeza
- Tos
- Cansancio
- Goteo de moco hacia la garganta
- Estornudos

Algunos efectos secundarios comunes de las gotas contra la alergia son:

- Irritación de garganta
- Picazón o hinchazón leve en la boca

Nota: Aunque es raro, las vacunas y gotas contra la alergia pueden causar una reacción alérgica que pone en peligro la vida, llamada “anafilaxia”. Los síntomas de anafilaxia pueden incluir una gran hinchazón de la cara, la garganta o la lengua; comezón; salpullido; dificultad para respirar; opresión en el pecho; sibilancias; mareo; náusea; diarrea o pérdida de la conciencia.

Si usted o su niño tienen alguno de estos síntomas después de recibir una vacuna o gotas contra la alergia, llame enseguida a su médico. La anafilaxia debe tratarse inmediatamente con una inyección de epinefrina, hormona que regula el ritmo cardiaco y las vías respiratorias.

### ¿Cuáles son los costos de las vacunas y las gotas contra la alergia?

Los costos para usted de las vacunas y las gotas contra la alergia dependen de su seguro médico. Debido a que las gotas contra la alergia aún no han sido aprobadas por la Food and Drug Administration (Administración de Alimentos y Medicamentos; FDA, por su sigla en inglés) de Estados Unidos, es posible que no estén cubiertas por su seguro médico. Los costos también dependen de la cantidad de alérgenos que contengan las vacunas o gotas contra la alergia. Como las vacunas contra la alergia suelen administrarse en el consultorio, puede que tenga que pagar la consulta cada vez que vaya a aplicarse una.

## Tome una decisión

### ¿En qué debo pensar al tomar mi decisión?

Se deben considerar muchos aspectos al decidir si las vacunas o las gotas contra la alergia son lo más apropiado para usted o para su niño. Tal vez desee hablar con su médico sobre:

- Qué tan graves son los síntomas de alergia o asma de usted (o de su niño)
- Qué tanto puede evitar o reducir los alérgenos en su ambiente (por ejemplo, limpieza de alfombras y cortinas o uso de un filtro de aire, cubrecolchón o funda especial para almohada)
- Qué tan eficaces son los medicamentos contra la alergia (antihistamínicos o aerosol nasal de esteroides) para mejorar sus síntomas (o los del niño)
- Los beneficios y efectos secundarios posibles de las vacunas o las gotas contra la alergia
- Qué es más eficaz, las vacunas o las gotas contra la alergia, para mejorar sus síntomas de alergia o asma (o los del niño)
- Qué método se adapta mejor a sus preferencias y estilo de vida, las vacunas o las gotas contra la alergia
  - Por ejemplo, ¿le sería más fácil ponerse diariamente las gotas contra la alergia o ir algunos días al consultorio a aplicarse la vacuna?
- Los costos de las vacunas o de las gotas contra la alergia

### Pregunte a su médico

- ¿Cuáles son las mejores formas de evitar o disminuir los alérgenos en mi ambiente?
- ¿Me ayudarían a mí (o a mi niño) las vacunas o las gotas contra la alergia?
- ¿Acaso alguna condición médica mía (o de mi niño) afectaría la posibilidad de usar vacunas o gotas contra la alergia?
- ¿Qué cree usted que sea mejor, las vacunas o las gotas contra la alergia?
- ¿Cuánto tiempo tardarán las vacunas o las gotas contra la alergia en empezar a tener efecto?
- ¿Cuánto tiempo necesitaré (o necesitará mi niño) utilizar las vacunas o las gotas contra la alergia?
- ¿Por cuánto tiempo las vacunas o las gotas contra la alergia mejorarán los síntomas de alergia o asma?
- ¿Cuánto costarán las vacunas contra la alergia? ¿Cuánto costarán las gotas contra la alergia?
- ¿Hay efectos secundarios por los que deba llamarle inmediatamente o tenga que acudir a la sala de emergencia? Si los hay, ¿cuáles son? ¿Qué deberé hacer? ¿Cuándo es probable que ocurran?

## Fuente

La información de este resumen proviene del informe Allergen-Specific Immunotherapy for the Treatment of Allergic Rhinoconjunctivitis and/or Asthma: Comparative Effectiveness Review (Inmunoterapia específica de alérgeno para el tratamiento de la rinoconjuntivitis alérgica y el asma: revisión de eficacia comparada), publicado en marzo de 2013. El informe fue producido por el Johns Hopkins University Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia de la Universidad Johns Hopkins) con financiamiento de la Agency for Healthcare Research and Quality (Agencia para la Investigación y la Calidad de la Atención Médica; AHRQ, por su sigla en inglés).

Para obtener una copia del informe o más información sobre la AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atención Médica), visite www.effectivehealthcare.ahrq.gov/allergy-asthma-immunotherapy.cfm (disponible sólo en inglés). Se obtuvo información adicional de la página web MedlinePlus^®^, un servicio de la National Library of Medicine (Biblioteca Nacional de Medicina) y de los National Institutes of Health (Institutos Nacionales de la Salud) de Estados Unidos. Esta página está disponible en www.nlm.nih.gov/medlineplus/spanish.

Este resumen fue preparado por el John M. Eisenberg Center for Clinical Decisions and Communications Science at Baylor College of Medicine (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas, en la Facultad de Medicina de Baylor) en Houston, Texas. Este resumen fue revisado por personas con alergias a alérgenos presentes en el aire.

Esta guía fue traducida de la publicación en inglés titulada Allergy Shots and Allergy Drops for Adults and Children: A Review of the Research.

* En este resumen, el término “médico” se refiere al profesional de la atención médica que lo atiende a usted (o a su niño), como puede ser su médico familiar, pediatra, alergólogo, otorrinolaringólogo (médico de oídos, nariz y garganta), enfermera o asistente médico.