# Opciones de tratamiento para niños y adolescentes con déficit de atención

Revisión de las investigaciones para los padres y personas que ayudan al cuidado

## ¿Es este resumen apropiado para mí?

### Es apropiado si

- Un médico dijo que su niño o adolescente tiene “trastorno de déficit de atención e hiperactividad” (TDAH).
- Usted desea saber lo que dicen las investigaciones acerca de los tratamientos del TDAH para niños y adolescentes.

### ¿Qué cubre este resumen?

En este resumen se analizan los diversos tipos de tratamiento para el TDAH. Se explica lo que indican las investigaciones sobre cómo mejora los síntomas cada tratamiento y los riesgos que implica cada uno de ellos. Puede ayudarle a hablar con el médico acerca del TDAH y de su hijo.

### ¿De dónde proviene la información de este resumen?

Investigadores financiados por la Agency for Healthcare Research and Quality (Agencia para la Investigación y Calidad de la Atención Médica; AHRQ, por su sigla en inglés), una agencia de investigación del gobierno federal, revisaron 223 estudios acerca de los tratamientos para el TDAH, publicados entre enero de 1980 y mayo de 2010. El informe fue revisado por clínicos, investigadores, expertos y el público. El informe puede leerse en www.effectivehealthcare.ahrq.gov/adhdtreatment.cfm.

## Conozca la condición de su hijo

### ¿Qué es el trastorno de déficit de atención e hiperactividad (TDAH)?

El TDAH es un trastorno que tiene tres diferentes tipos de síntomas:

- Dificultad para prestar atención o concentrarse en ciertas tareas
- Ser demasiado activo (o hiperactivo)
- Actuar por impulso (sin pensar)

Los niños o los adolescentes con TDAH pueden:

- Distraerse fácilmente y olvidarse a menudo de las cosas
- Pasar demasiado pronto de una actividad a la siguiente
- Tener dificultad para seguir indicaciones
- Soñar despierto demasiado
- Tener dificultad para acabar las labores, como las tareas escolares o los quehaceres domésticos
- Perder con mucha frecuencia juguetes, libros y útiles escolares
- Ser inquietos y moverse con mucha intranquilidad o nerviosismo
- Hablar sin parar e interrumpir a la gente
- Corretear mucho
- Agarrar y jugar con todo lo que ven
- Ser muy impacientes
- Decir de repente comentarios inoportunos
- Tener problemas para controlar sus emociones

Los niños pueden desarrollar los primeros síntomas de TDAH a una edad temprana (entre 3 y 6 años de edad). Sin embargo, el TDAH se descubre y se trata con mayor frecuencia en la escuela primaria (entre los 7 y 9 años de edad).

Los síntomas de TDAH, como la hiperactividad, pueden disminuir a medida que el niño tiene más edad. Sin embargo, los síntomas pueden no desaparecer del todo y persistir hasta la edad adulta.

### ¿Cómo saben los médicos si un niño o adolescente tiene TDAH?

No existe ningún examen médico o físico que indique si alguien tiene TDAH. Por lo general, el padre, el profesor u otro adulto explican al médico los comportamientos que observan. Su pediatra o su médico familiar pueden sugerirle llevar al niño a ver a un especialista experto, con capacitación y experiencia en trastornos del desarrollo infantil y la salud mental.

A veces el niño tiene TDAH al mismo tiempo que otros problemas, como ansiedad, problemas de aprendizaje por discapacidad, trastorno de oposición desafiante (condición en que los niños o adolescentes discuten, contestan irrespetuosamente, desobedecen y desafían a padres, profesores y a otros adultos) o problemas con el alcohol y las drogas. El médico puede buscar otros problemas médicos que podrían explicar los síntomas de su niño.

### ¿Qué tan frecuente es el TDAH?

Actualmente, el TDAH se encuentra en niños preescolares, adolescentes y adultos con mayor frecuencia que en el pasado.

- Alrededor de 5 por ciento de los niños en el mundo muestran signos de falta de atención e hiperactividad.
- Cerca del doble de los niños que de las niñas tienen TDAH.
- El TDAH afecta a niños de todas las razas y clases sociales.

## Conozca sus opciones

### ¿Cómo se trata el TDAH?

Es frecuente que los niños tengan más de un problema de aprendizaje y/o emocional. El TDAH puede ser sólo uno de estos problemas. Para poder decidir sobre el tratamiento, es importante que el médico haga una evaluación completa.

No existe cura para el TDAH, pero hay tratamientos que pueden ayudar a aliviar los síntomas. Tal vez haya oído usted de algunos tratamientos, como ciertos cambios en la alimentación, el uso de suplementos o vitaminas y otros. No existe suficiente investigación para saber qué tan bien funcionan estos tratamientos, así que no se incluyen en este resumen. Los dos tratamientos siguientes están respaldados por muchas más investigaciones:

- Tratamientos sin medicamentos: Capacitación conductual para padres, terapia psicosocial y programas escolares
- Medicamentos

Las familias pueden utilizar simultáneamente tratamientos con y sin medicamentos.

### Tratamientos sin medicamentos

Se han utilizado varios tipos de tratamientos sin medicamentos para los niños con TDAH. A veces, toda la familia participa en estos tratamientos.

### Capacitación conductual para padres

- Los programas de capacitación conductual para padres les enseñan formas mejores de ayudar a sus niños o adolescentes.
- A menudo, los padres y el niño acuden juntos a las sesiones de capacitación conductual.
- Por lo general, los programas se enfocan primeramente en lograr que haya un vínculo sano entre los padres y el niño.
- Los programas enseñan a los padres a entender la conducta del niño. Los padres aprenden técnicas para ayudar a su niño a evitar problemas de conducta antes de que empiecen.
- Los padres pueden aprender a organizar las tareas de la forma que sea más fácil para que su niño o adolescente las complete.
- Los programas de capacitación conductual para padres les enseñan a crear un sistema de recompensas y de consecuencias.
- Las sesiones del programa por lo general se realizan en un consultorio y pueden haber sesiones semanales por un periodo de varias semanas o meses.
- Por lo general, en estos programas se cobra una cuota. Algunos de estos costos pueden estar cubiertos por su seguro.

### Terapia psicosocial

- Un terapeuta capacitado puede hablar con su niño y otros miembros de la familia para controlar las conductas, emociones y mejorar la forma como se relaciona con otros compañeros.
- Por lo general las sesiones de tratamiento se realizan en un consultorio. El terapeuta puede sugerir sesiones semanales durante varias semanas, meses o años, de acuerdo con las necesidades del niño.
- Los terapeutas por lo general cobran una tarifa por hora de tratamiento. Algunos de estos costos pueden estar cubiertos por su seguro.

### Programas en la escuela

- El Individuals with Disabilities Education Act (Ley para la Educación de las Personas con Discapacidades, IDEA por su sigla en inglés) exige a las escuelas públicas brindar servicios de educación especial a los niños que la requieran. Los niños con TDAH suelen estar incluidos.
- Los especialistas en educación de las escuelas ayudan a los estudiantes con TDAH a tener éxito académico y a progresar con su aprendizaje. Ellos pueden colaborar con el niño, los padres y los profesores para hacer modificaciones al salón de clases, actividades escolares o tareas escolares.
- Se crea un programa educativo individualizado (IEP, por su sigla en inglés) con especialistas en educación, profesores y padres. El IEP especifica las acciones que se toman en la escuela para ayudar al niño a tener éxito. Estos planes se revisan al terminar el año y se le entregan al siguiente profesor del niño.
- Estos servicios pueden ser gratuitos para las familias que viven dentro del distrito escolar.

### ¿Qué dicen las investigaciones acerca de los tratamientos sin medicamentos?

Los investigadores observaron que:

- Ayudar a los padres a adquirir nuevas habilidades que sirvan para mejorar el comportamiento del niño (capacitación conductual para padres) reduce los síntomas de TDAH y los trastornos de conducta disruptiva en niños menores de 6 años con TDAH.
  - En algunos estudios, las mejorías en la conducta disruptiva duraron hasta 2 años.
  - Los padres que acuden a más sesiones de capacitación conductual para padres observan más mejoría en el comportamiento de su niño.

No existe suficiente investigación para saber:

- Si la combinación de más de un tipo de tratamiento sin medicamentos ayuda a tratar a los niños preescolares con trastornos de conducta disruptiva o TDAH.
- Si la terapia conductual o psicosocial sola funciona después de 12 meses para mejorar el TDAH en niños de 6 años y mayores.
- Si la capacitación conductual para padres o los programas escolares mejoran los síntomas de TDAH por más de 12 meses en los niños de 6 años y mayores.

### Medicamentos

Existen dos tipos de medicamentos para tratar los síntomas del TDAH: estimulantes y no estimulantes. Hay muchos tipos y marcas distintas de estos medicamentos. Todos los medicamentos para tratar el TDAH tienen posibles efectos secundarios. Se piensa que estos medicamentos funcionan cambiando la cantidad de ciertas sustancias químicas del cerebro.

Medicamentos para el TDAH

Tipo de medicamento | Nombre comercial | ¿Cómo se toma? | ¿Existe en genérico?
Estimulantes
Sales mixtas de anfetamina | Adderall^®^ | Pastilla | Sí, en algunas dosis
Sales mixtas de anfetamina | Adderall XR^®^ | Pastilla | Sí, en algunas dosis
Dextroanfetamina | Dexedrine^®^ | Pastilla | Sí
Lisdexanfetamina^*^ | Vyvanse^®^* | Pastilla | Sí
Metilfenidato | Concerta^®^ | Pastilla | Sí
Metilfenidato | Daytrana^®^† | Parche para la piel | Sí
Metilfenidato | Focalin^®^* | Pastilla | Sí
Metilfenidato | Focalin XR^®^* | Pastilla | Sí, en algunas dosis
Metilfenidato | Metadate ER^®^ | Pastilla | Sí, en algunas dosis
Metilfenidato | Metadate CD^®^ | Pastilla | Sí, en algunas dosis
Metilfenidato | Methylin^®^ | Pastilla | Sí
Metilfenidato | Methylin ER^®^ | Pastilla | Sí, en algunas dosis
Metilfenidato | Ritalin^®^ | Pastilla | Sí
Metilfenidato | Ritalin LA^®^ | Pastilla | Sí, en algunas dosis
Metilfenidato | Ritalin SR^®^ | Pastilla | Sí, en algunas dosis
No estimulantes
Atomoxetina | Strattera^®^ | Pastilla | No
Clorhidrato de clonidina | Kapvay^®^* | Pastilla | Sí
Guanfacina ER | Intuniv^®^ | Pastilla | Sí

CD, ER, LA, SR y XR se refieren todos a las fórmulas de liberación prolongada del medicamento. Esto significa que el medicamento dura más y el niño puede no necesitar tomar tantas pastillas cada día.

* No se cuenta con estudios de buena calidad sobre este medicamento.

† No se dispone de investigaciones sobre este medicamento en la forma de parche para la piel.

### Estimulantes

- Los estimulantes pueden ser de acción breve (actúan de 4 a 6 horas) o de acción prolongada (actúan de 8 a 12 horas).
- Los niños y adolescentes por lo general toleran bien estos medicamentos.
- Pueden administrarse por vía oral o por medio de un parche en la piel.
- Existen varios tipos diferentes de estimulantes. Es posible que su médico necesite probar varios antes de encontrar el que le funcione mejor a su niño. Los estimulantes se han estudiado muy poco en niños menores de 6 años. Su médico debe revisar la etiqueta de la Food and Drug Administration (Administración de Alimentos y Medicamentos; FDA, por su sigla en inglés) para ver si estos medicamentos pueden utilizarse en niños menores de 6 años.

### No estimulantes

#### Atomoxetina (nombre comercial: Strattera^®^)

- El efecto de la atomoxetina puede aumentar la sustancia llamada norepinefrina en el cerebro.
- La atomoxetina está aprobada por la FDA para niños de 6 años y mayores y se toma por vía oral.

#### Guanfacina ER (nombre comercial: Intuniv^®^)

- La guanfacina de liberación prolongada interactúa con la parte del cerebro que controla la atención y el impulso.
- Está aprobada por la FDA para niños de 6 años y mayores. Se toma por vía oral.

### ¿Qué dicen las investigaciones comparativas de estos medicamentos?

Algunos estudios encontraron que:

- Todos los estimulantes parecen mejorar los síntomas de TDAH en los niños de 6 años y mayores por períodos de meses a años, con pocos efectos secundarios, pero no existe suficiente investigación para saberlo con certeza.
- El estimulante metilfenidato (Ritalin^®^ y Concerta^®^, entre otros) funciona y por lo general es seguro para tratar los síntomas de TDAH, pero no existe suficiente investigación para saber si es seguro para niños preescolares (menores de 6 años) por más de 1 año.
- La atomoxetina (Strattera^®^) es segura y parece funcionar bien para tratar los síntomas de TDAH en niños de 6 años y mayores durante varios años, pero no existe suficiente investigación para saberlo con certeza.

No existe suficiente investigación para saber:

- Qué tan bien funciona la guanfacina de liberación prolongada (Intuniv^®^) durante varios años para tratar los síntomas de TDAH en los niños de 6 años y mayores.

### Efectos secundarios comunes de los medicamentos para el TDAH

Estos efectos secundarios se mencionan en las etiquetas de la FDA de cada medicamento y en las investigaciones médicas estudiadas para este resumen.

Medicamentos | Efectos secundarios | Información adicional
Todos los estimulantes (fórmulas regulares o de liberación prolongada)
Adderall^®^ Concerta^®^ Daytrana^®^ Dexedrine^®^ Focalin^®^ Metadate^®^ Methylin^®^ Ritalin^®^ Vyvance^®^ | - Menos apetito; - Empeoró los tics (movimientos incontrolables); - Dificultad para conciliar el sueño; - Dolores de cabeza, dolores de estómago e irritabilidad; - Aumento de la frecuencia cardiaca | Los niños o adolescentes con problemas del corazón de cualquier tipo deben mantenerse bajo vigilancia médica para detectar efectos secundarios. Cada niño reacciona de manera diferente a los estimulantes y estos efectos secundarios pueden ser leves o fuertes.
No estimulantes (fórmulas regulares o de liberación prolongada)
Atomoxetina (Strattera^®^) | - Aumento de ideas de suicidio (en comparación con los niños que no toman el medicamento); - Menos apetito; - Aumento de la frecuencia cardiaca; - Dolores de cabeza, dolores de estómago e irritabilidad | Los padres deben estar atentos a signos de pensamientos suicidas. Este medicamento se ha vinculado con problemas del corazón y puede no ser seguro en niños o adolescentes con antecedentes de problemas graves del corazón.
Guanfacina (Intuniv^®^) | - Letargo, fatiga y sueño; - Dolores de cabeza, dolores de estómago e irritabilidad; - Los efectos secundarios posibles para el corazón incluyen presión arterial baja, frecuencia cardiaca lenta u otros cambios en el ritmo del corazón. Estos efectos secundarios pueden necesitar la supervisión atenta del médico. | Este medicamento no se debe interrumpir repentinamente, ya que al hacerlo puede elevarse la presión arterial.

### ¿Qué dicen las investigaciones sobre el uso combinado de tratamientos con y sin medicamentos?

Algunos estudios encontraron que:

- Los estimulantes, sea que se usen solos o junto con la terapia conductual, pueden ayudar a los niños de 6 años y mayores con TDAH, pero no existe suficiente investigación para saberlo con certeza.

## Tome una decisión

### ¿En qué debo pensar al tomar mi decisión?

Se deben considerar varias cosas a la hora de decidir sobre los tratamientos con o sin medicamentos para su niño o adolescente con TDAH.

- Si decide utilizar un tratamiento sin medicamentos, deberá considerar cómo programar o participar en las sesiones de tratamiento con su hijo.
- Deberá considerar también los costos de los tratamientos continuos sin medicamentos y el compromiso de permanecer en sesiones de terapia o de capacitación conductual para padres por un periodo largo.
- Al considerar si el niño debe tomar un medicamento, sólo usted y el médico podrán decidir si los beneficios de algún medicamento justifican el riesgo de tener un efecto secundario.
- Cada persona responde de manera diferente a los distintos medicamentos, y el médico puede probar varios de ellos y distintas dosis (cantidades) antes de hallar el más indicado.

Usted y el médico deben hablar sobre:

- Si los tratamientos sin medicamentos podrían ser útiles para su niño o adolescente.
- Qué tipos de tratamientos sin medicamentos están disponibles en su área.
- Los beneficios y los efectos secundarios de tomar un medicamento.
- Las maneras en que el médico puede ayudarle a identificar algún efecto secundario, de modo que éste pueda tratarse o el medicamento pueda cambiarse.
- El costo de cada opción de tratamiento.

The National Resource Center on ADHD (Centro Nacional de Recursos sobre TDAH), un programa para Niños y Adultos con Trastorno de Déficit de Atención e Hiperactividad (CHADD^®^ por su sigla en inglés), respaldado por los Centers for Disease Control and Prevention (Centros para el Control y la Prevención de Enfermedades, CDC por su sigla en inglés), tiene información y muchos recursos. Puede ver información en español tanto en la página de Internet del centro o comunicarse con una operadora marcando la línea gratuita:

www.help4adhd.org 1-800-233-4050

### ¿Cuáles son los costos del tratamiento?

El costo de los programas de tratamiento sin medicamentos puede variar entre $300 y $2,000, dependiendo del terapeuta o programa específico y del tiempo necesario. Hay algunos servicios disponibles por medio de las escuelas y el gobierno federal.

El costo para usted de los medicamentos para tratar el TDAH depende de:

- Su seguro médico.
- La dosis (cantidad) del medicamento que necesita tomar su niño o adolescente.
- Si el medicamento está disponible en forma genérica.

Costo de mayoreo de los medicamentos con receta para el TDAH

Nombre comercial | Dosis | Precio del de nombre comercial por mes^*^ | Nombre genérico | Precio del genérico por mes^*^
Estimulantes
Adderall^®^ | 5 mg | $113 | Sales mixtas de anfetamina | $45
Adderall^®^ | 10 mg | $113 | Sales mixtas de anfetamina | $45
Adderall^®^ | 20 mg | $113 | Sales mixtas de anfetamina | $45
Adderall^®^ | 30 mg | $113 | Sales mixtas de anfetamina | $45
| | | Sales mixtas de anfetamina
Adderall XR^®^ | 10 mg | $236 | Sales mixtas de anfetamina | $184
Adderall XR^®^ | 20 mg | $236 | Sales mixtas de anfetamina | $184
Adderall XR^®^ | 30 mg | $236 | Sales mixtas de anfetamina | $184
Concerta^®^ | 18 mg | $197 | Clorhidrato de metilfenidato | $186
Concerta^®^ | 27 mg | $202 | Clorhidrato de metilfenidato | $191
Concerta^®^ | 36 mg | $208 | Clorhidrato de metilfenidato | $197
Concerta^®^ | 54 mg | $226 | Clorhidrato de metilfenidato | $214
Daytrana^®^ Parche (9 horas por dosis) | 10 mg | $212 (todas las dosis) | Metilfenidato | ND
Daytrana^®^ Parche (9 horas por dosis) | 15 mg | $212 (todas las dosis) | Metilfenidato | ND
Daytrana^®^ Parche (9 horas por dosis) | 20 mg | $212 (todas las dosis) | Metilfenidato | ND
Daytrana^®^ Parche (9 horas por dosis) | 30 mg | $212 (todas las dosis) | Metilfenidato | ND
Dexedrine^®^ | 5 mg | ND | Dextroanfetamina | $206
Dexedrine^®^ | 10 mg | ND | Dextroanfetamina | $206
Dexedrine^®^ | 20 mg | ND | Dextroanfetamina | $412
Dexedrine^®^ | 30 mg | ND | Dextroanfetamina | $412
Focalin^®^ | 2.5 mg | $22 | Clorhidrato de dexmetilfenidato | $20
Focalin^®^ | 5 mg | $32 | Clorhidrato de dexmetilfenidato | $29
Focalin^®^ | 10 mg | $46 | Clorhidrato de dexmetilfenidato | $42
| | | Clorhidrato de dexmetilfenidato
Focalin XR^®^ | 10 mg | $200 | Clorhidrato de dexmetilfenidato | ND
Focalin XR^®^ | 20 mg | $206 | Clorhidrato de dexmetilfenidato | ND
Focalin XR^®^ | 30 mg | $216 | Clorhidrato de dexmetilfenidato | ND
Focalin XR^®^ | 40 mg | $227 | Clorhidrato de dexmetilfenidato | ND
Metadate CD^®^ | 10 mg | $171 | Clorhidrato de metilfenidato | $15
Metadate CD^®^ | 20 mg | $171 | Clorhidrato de metilfenidato | $26
Metadate CD^®^ | 30 mg | $171 | Clorhidrato de metilfenidato | $138
Metadate CD^®^ | 40 mg | $234 | Clorhidrato de metilfenidato | ND
Metadate CD^®^ | 50 mg | $288 | Clorhidrato de metilfenidato | ND
Metadate CD^®^ | 60 mg | $288 | Clorhidrato de metilfenidato | ND
Metadate ER^®^ | 20 mg | $53 | Clorhidrato de metilfenidato (continuación) | ND
| | | Clorhidrato de metilfenidato (continuación)
Methylin^®^ | 2.5 mg | $105 | Clorhidrato de metilfenidato (continuación) | ND
Methylin^®^ | 5 mg | $150 | Clorhidrato de metilfenidato (continuación) | ND
Methylin^®^ | 10 mg | $214 | Clorhidrato de metilfenidato (continuación) | ND
| | | Clorhidrato de metilfenidato (continuación)
Methylin ER^®^ | 10 mg | ND | Clorhidrato de metilfenidato (continuación) | ND
Methylin ER^®^ | 20 mg | ND | Clorhidrato de metilfenidato (continuación) | ND
| | | Clorhidrato de metilfenidato (continuación)
Ritalin^®^ | 5 mg | $18 | Clorhidrato de metilfenidato (continuación) | ND
Ritalin^®^ | 10 mg | $30 | Clorhidrato de metilfenidato (continuación) | ND
Ritalin^®^ | 20 mg | $53 | Clorhidrato de metilfenidato (continuación) | ND
| | | Clorhidrato de metilfenidato (continuación)
Ritalin LA^®^ | 10 mg | $165 | Clorhidrato de metilfenidato (continuación) | ND
Ritalin LA^®^ | 20 mg | $165 | Clorhidrato de metilfenidato (continuación) | ND
Ritalin LA^®^ | 30 mg | $169 | Clorhidrato de metilfenidato (continuación) | ND
Ritalin LA^®^ | 40 mg | $173 | Clorhidrato de metilfenidato (continuación) | ND
| | | Clorhidrato de metilfenidato (continuación)
Ritalin SR^®^ | 20 mg | $80 | Clorhidrato de metilfenidato (continuación) | ND
Vyvanse^®^ | 20–70 mg | $205 (todas las dosis) | Dimesilato de lisdexanfetamina | ND
No estimulantes
Intuniv^®^ | 1 mg | $194 (todas las dosis) | Guanfacina | $27 (1 mg)
Intuniv^®^ | 2 mg | $194 (todas las dosis) | Guanfacina | $40 (2 mg)
Intuniv^®^ | 3 mg | $194 (todas las dosis) | Guanfacina
Intuniv^®^ | 4 mg | $194 (todas las dosis) | Guanfacina
Kapvay^®^ | 1 mg | $104 | Clorhidrato de clonidina | $8
Kapvay^®^ | 2 mg | ND | Clorhidrato de clonidina | $9
Kapvay^®^ | 3 mg | ND | Clorhidrato de clonidina | $16
Strattera^®^ | Según peso del niño | $206–$241 | Atomoxetina | ND

CD, ER, LA, SR y XR se refieren todos a las fórmulas de liberación prolongada del medicamento.

ND = no está disponible el precio del producto genérico.

* Los precios son el promedio de los precios de mayoreo reproducidos de RED BOOK Online^®^. Los precios del medicamento genérico son el promedio de los precios fijados por los diferentes fabricantes. Los precios reales de los medicamentos pueden ser más altos o más bajos que los mostrados aquí, dependiendo del fabricante al que compre su farmacia.

### Pregunte a su médico

- En su opinión, ¿beneficiarían a mi niño o adolescente los tratamientos sin medicamentos, con medicamentos o de ambos tipos?
- ¿Qué tipo de cambios puedo esperar? ¿Cuánto tiempo tardarán en ocurrir?
- ¿Qué programas de tratamiento sin medicamentos están disponibles en mi área?
- ¿Hay algún terapeuta o programa que usted me recomiende? ¿Por qué?
- ¿Cómo sabré si mi niño o adolescente tiene un efecto secundario grave y necesita cambiar de medicamento?
- ¿Hay grupos de apoyo locales que podrían ayudarme?

Otras preguntas:

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

Anote aquí las respuestas:

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

## Fuente

La información de este resumen proviene del informe Attention Deficit Hyperactivity Disorder: Effectiveness of Treatment in At-Risk Preschoolers; Long-term Effectiveness in All Ages; and Variability in Prevalence, Diagnosis, and Treatment (Trastorno de déficit de atención e hiperactividad: eficacia del tratamiento en preescolares en riesgo; eficacia a largo plazo en todas las edades; y variabilidad en la prevalencia, diagnóstico y tratamiento), de octubre de 2011.

El informe fue producido por el McMaster University Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia de la Universidad McMaster), con financiamiento de la Agency for Healthcare Research and Quality (Agencia para la Investigación y Calidad de la Atención Médica; AHRQ, por su sigla en inglés).

Para obtener una copia del informe o más información sobre la AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atención Médica), visite www.effectivehealthcare.ahrq.gov/adhdtreatment.cfm (disponible sólo en inglés). Se obtuvo información adicional de la página web MedlinePlus^®^, un servicio de la National Library of Medicine (Biblioteca Nacional de Medicina) y de los National Institutes of Health (Institutos Nacionales de la Salud) de Estados Unidos. Esta página está disponible en www.nlm.nih.gov/medlineplus/spanish.

Este resumen fue preparado por el John M. Eisenberg Center for Clinical Decisions and Communications Science at Baylor College of Medicine (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas, en la Facultad de Medicina de Baylor) en Houston, Texas. Este resumen fue revisado por padres y personas que ayudan al cuidado de niños o adolescentes con TDAH.

Esta guía fue traducida de la publicación en inglés titulada Treatment Options for ADHD in Children and Teens: A Review of Research for Parents and Caregivers.