# Cómo escoger medicamentos para la presión arterial alta

Revisión de las investigaciones sobre IECA, BRA e IDR

## ¿Es esta información apropiada para mí?

### Es apropiada si

- Su médico dice que usted tiene presión arterial alta.
- Su médico le pidió que considerara tomar uno o más de estos medicamentos:
  □ Inhibidores de la enzima convertidora de angiotensina (ECA).
  □ Bloqueadores o antagonistas del receptor de la angiotensina II (BRA).
  □ Inhibidor directo de la renina (IDR). Actualmente, hay solamente un IDR, un medicamento llamado aliskirén.

Es más probable que a algunas personas se les recete un IECA, BRA o IDR para tratar la presión arterial alta. Estas personas incluyen también aquellas que tienen diabetes tipo 2, insuficiencia cardiaca congestiva o enfermedad de los riñones.

### No es apropiada si

- Su presión arterial no es lo suficientemente alta como para que un médico le sugiera tomar medicamentos para controlarla.
- Su médico le sugiere tomar otros medicamentos que no son IECA, BRA ni IDR para tratar su presión arterial alta.
- Usted tiene menos de 18 años. Las investigaciones se han hecho solamente en adultos.

### ¿Qué cubre este resumen?

Usted podrá aprender lo que dicen las investigaciones acerca de tres tipos de medicamentos para la presión arterial alta, su eficacia, cómo se comparan entre sí y sus efectos secundarios. Esta información puede ayudarle a hablar con su médico para decidir qué IECA, BRA o IDR es mejor para usted.

### ¿De dónde proviene la información?

La información proviene de un informe que evaluó 110 estudios sobre estos medicamentos. La revisión fue efectuada por un equipo investigador en la Duke University (Universidad de Duke) y financiado por la Agency for Healthcare Research and Quality (Agencia para la Investigación y Calidad de la Atención Médica, AHRQ por su sigla en inglés), organismo de investigación del gobierno federal. Usted puede leer el informe detallado en www.effectivehealthcare.ahrq.gov/acearbhbp.cfm (disponible sólo en inglés).

Nombres de medicamentos IECA, BRA e IDR

Tipo | Nombre del medicamento (nombre comercial) | ¿Disponible en genérico?
IECA | Benazepril (Lotensin^®^) | Sí
IECA | Captopril (Capoten^®^) | Sí
IECA | Enalapril (Vasotec^®^) | Sí
IECA | Fosinopril (Monopril^®^) | Sí
IECA | Lisinopril (Prinivil^®^ o Zestril^®^) | Sí
IECA | Moexipril (Univasc^®^) | Sí
IECA | Perindopril (Aceon^®^) | Sí
IECA | Quinapril (Accupril^®^) | Sí
IECA | Ramipril (Altace^®^) | Sí
IECA | Trandolapril (Mavik^®^) | Sí
BRA | Candesartán (Atacand^®^) | No
BRA | Eprosartán (Teveten^®^) | No
BRA | Irbesartán (Avapro^®^) | No
BRA | Losartán (Cozaar^®^) | Sí
BRA | Olmesartán medoxomilo (Benicar^®^) * | No
BRA | Telemisartán (Micardis^®^) | No
BRA | Valsartán (Diovan^®^) | No
IDR | Aliskirén (Tekturna^®^) | No

* Este BRA no fue incluido en ninguno de los estudios.

## Acerca de su condición

### ¿Qué es la presión arterial alta?

- “Presión arterial” es la fuerza que ejerce la sangre en las arterias cuando el corazón bombea sangre. Esta presión se mide con dos números:
- El número de arriba, o presión “sistólica”, es la fuerza producida cuando el corazón late.
- El número de abajo, o presión “diastólica”, es la fuerza producida cuando el corazón se relaja entre latidos.
- Usualmente, estos números se indican juntos.

La presión arterial aumenta y disminuye un poco durante el día, pero los médicos pueden determinar observando lecturas en un período de tiempo, si su presión arterial promedio es más alta de lo normal. La presión arterial normal es de menos de 120/80. Esto significa que la fuerza de la sangre es de 120 cuando su corazón late y de 80 cuando su corazón está entre los latidos.

El término presión arterial alta o “hipertensión” suele referirse a la presión arterial de 140/90 o más.

### ¿Que tan común es la presión arterial alta?

La presión arterial alta es uno de los problemas de salud más frecuentes en Estados Unidos. Aunque la presión arterial alta puede afectar a personas de todas las edades, es más común en las personas mayores de 65 años. El National Center for Health Statistics (Centro Nacional de Estadísticas de Salud) indica que los afroamericanos suelen padecer de presión arterial alta con mayor frecuencia y a una edad más temprana, que otras razas. La condición es más frecuente en las mujeres afroamericanas que en hombres. La presión arterial alta es más común en las personas que tienen sobrepeso, comen alimentos salados, toman muchas bebidas alcohólicas, fuman tabaco o no hacen ejercicio regularmente.

### ¿Por qué debe tratarse la presión arterial alta?

La presión arterial alta hace que el corazón trabaje demasiado, puede causar que las arterias se estrechen y puede dar lugar a enfermedad del corazón, ataque cardiaco, enfermedad de los riñones y derrames.

### ¿Dónde puedo aprender más sobre la presión arterial alta?

Para obtener más información general sobre la presión arterial alta, puede leer Your Guide to Lowering High Blood Pressure (Su guía para reducir la presión arterial alta) en www.nhlbi.nih.gov/hbp/ (disponible sólo en inglés). El National Heart, Lung, and Blood Institute (Instituto Nacional del Corazón, el Pulmón y la Sangre) publica la guía.

## Acerca de sus opciones

### ¿Cómo se trata la presión arterial alta?

Además de hacer ejercicio, comer sanamente, dejar de fumar y tomar menos bebidaa alcohólicas, tal vez su médico quiera que tome uno o más medicamentos para ayudar a controlar su presión arterial.

Muchos medicamentos ayudan a tratar la presión arterial alta. Cada tipo funciona en forma diferente para bajar la presión arterial.

### IECA, BRA e IDR

Estos tres tipos de medicamentos para controlar la presión arterial alta trabajan de manera similar:

Funcionan con el sistema “renina-angiotensina”, encargado de aumentar la presión arterial.

- Inhibidores de la enzima convertidora de angiotensina (IECA)
- Bloqueadores o antagonistas del receptor de la angiotensina II (BRA)
- Inhibidor directo de la renina (IDR)

A algunas personas es más probable que se les recete un IECA, BRA o IDR. Estas personas también incluyen aquellas que tienen diabetes tipo 2, insuficiencia cardiaca congestiva o enfermedad de los riñones.

Todos estos medicamentos se toman en forma de pastillas. Para obtenerlos se necesita la receta de su médico. Muchos están disponibles en forma genérica, que cuesta menos.

### ¿Cuál es mejor?

La revisión de las investigaciones sobre estos medicamentos encontró que:

- Todos los IECA y los BRA ayudan a disminuir la presión arterial en un grado similar.
- Todos los IECA y los BRA protegen en grado similar los riñones.
- Los medicamentos IECA y BRA no tienen efecto (bueno o malo) en los niveles de azúcar o de colesterol (grasa) en la sangre.
- Los IDR son medicamentos nuevos, así que no existe todavía suficiente investigación para poder compararlos con los IECA y los BRA

### ¿Qué efectos secundarios pueden causar estos medicamentos?

- Los efectos secundarios más frecuentes de estos medicamentos son tos seca, dolor de cabeza y mareos. Los tres tipos de medicamentos causan casi la misma cantidad de dolores de cabeza y mareos.
- La tos seca es más probable en las personas que toman IECA que en las que toman BRA.

En cerca de 9 de cada 100 personas que toman un IECA se presenta tos seca.

Cerca de 2 de cada 100 personas que toman un BRA presentan tos seca.

- Aunque es muy raro, los IECA, BRA y los IDR pueden causar hinchazón repentina en la lengua, labios, garganta, manos o pies. Esto se conoce como “angioedema”. Si eso sucede, llame inmediatamente a su médico. Podría tratarse de una emergencia.

Los IECA, los BRA y los IDR pueden causar defectos congénitos graves. Si está usted embarazada o piensa estarlo, avise a su médico y pregúntele qué debe hacer.

## Tome una decisión

Usted y su médico pueden decidir juntos qué IECA, BRA o IDR puede ser mejor para usted. Hable sobre:

- Lo que dicen las investigaciones acerca de los beneficios y efectos secundarios de estos medicamentos.
- Cómo el medicamento para la presión arterial puede afectar otras condiciones que tenga, como enfermedades del corazón o diabetes.
- Los costos de los medicamentos.
- Cómo los efectos secundarios pueden afectar su vida diaria.
- Cómo estos medicamentos pueden interactuar con otros que esté tomando o con ciertos alimentos.

Para que el medicamento funcione, es importante que lo tome todos los días. Pregunte a su médico o enfermera cuál es la mejor hora para tomar su medicamento y otras maneras para acordarse de tomarlo diariamente.

### ¿Cuáles son los costos?

La cantidad que tendrá que pagar depende de:

- Si toma un medicamento genérico o uno de nombre comercial.
- La cantidad de medicamento que necesite tomar.
- El copago según su plan de seguro.

IECA

Nombre del medicamento genérico | Nombre comercial | Dosis para la presión arterial alta^1^ | Precio por el suministro para 1 mes
Nombre del medicamento genérico | Nombre comercial | Dosis para la presión arterial alta^1^ | Genérico^2^ | Comercial^3^
Benazepril | Lotensin^®^ | 10 mg al día | $30 | $65
Benazepril | Lotensin^®^ | 20 mg al día | $50 | $65
Benazepril | Lotensin^®^ | 40 mg al día | $40 | $65
Captopril | Capoten^®^ | 25 mg dos veces al día | $55 | $130
Captopril | Capoten^®^ | 50 mg dos veces al día | $80 | $170
Enalapril | Vasotec^®^ | 5 mg al día | $45 | $90
Enalapril | Vasotec^®^ | 10 mg al día | $50 | $100
Enalapril | Vasotec^®^ | 20 mg al día | $65 | $140
Enalapril | Vasotec^®^ | 20 mg dos veces al día | $135 | $280
Fosinopril | Monopril^®^ | 10 mg al día | $80 | $55
Lisinopril | Prinivil^®^; Zestril^®^ | 10 mg al día | $30 | $40; $50
Lisinopril | Prinivil^®^; Zestril^®^ | 20 mg al día | $40 | $40; $50
Lisinopril | Prinivil^®^; Zestril^®^ | 40 mg al día | $50 | $80; $75
Moexipril | Univasc^®^ | 7.5 mg al día | $45 | $75
Moexipril | Univasc^®^ | 15 mg al día | $50 | $80
Moexipril | Univasc^®^ | 15 mg dos veces al día | $100 | $160
Perindopril | Aceon^®^ | 2 mg al día | $60 | $70
Perindopril | Aceon^®^ | 4 mg al día | $70 | $80
Perindopril | Aceon^®^ | 8 mg al día | $85 | $100
Quinapril | Accupril^®^ | 10 mg al día | $40 | $60
Quinapril | Accupril^®^ | 20 mg al día | $40 | $60
Ramipril | Altace^®^ | 2.5 mg al día | $55 | $80
Ramipril | Altace^®^ | 5 mg al día | $60 | $85
Ramipril | Altace^®^ | 10 mg al día | $70 | $100
Trandolapril | Mavik^®^ | 1 mg al día | $35 | $50
Trandolapril | Mavik^®^ | 2 mg al día | $35 | $50

1 Las dosis son similares a las utilizadas en estudios de investigación.

2 Mediana del precio promedio de mayoreo del medicamento genérico en dólares, tomado del Red Book: Pharmacy's Fundamental Reference, 2011.

3 Precio promedio de mayoreo del medicamento de marca comercial en dólares, redondeado a los $5 más cercanos, tomado del Red Book: Pharmacy's Fundamental Reference, 2011.

BRA

Nombre del medicamento genérico | Nombre comercial | Dosis para la presión arterial alta^1^ | Precio por el suministro para 1 mes
Nombre del medicamento genérico | Nombre comercial | Dosis para la presión arterial alta^1^ | Genérico^2^ | Comercial^3^
Candesartán | Atacand^®^ | 4 mg al día | | $80
Candesartán | Atacand^®^ | 8 mg al día | ND | $80
Candesartán | Atacand^®^ | 16 mg al día | | $80
Eprosartán | Teveten^®^ | 400 mg al día | | $100
Eprosartán | Teveten^®^ | 600 mg al día | ND | $115
Eprosartán | Teveten^®^ | 400 mg dos veces al día | | $195
Irbesartán | Avapro^®^ | 150 mg al día | ND | $95
Irbesartán | Avapro^®^ | 300 mg al día | | $115
Losartán | Cozaar^®^ | 25 mg al día | $50 | $65
Losartán | Cozaar^®^ | 50 mg al día | $70 | $85
Losartán | Cozaar^®^ | 100 mg al día | $95 | $115
Olmesartán | Benicar^®^ | 20 mg al día | ND | $90
Olmesartán | Benicar^®^ | 40 mg al día | | $125
Telmisartán | Micardis^®^ | 20 mg al día | | $110
Telmisartán | Micardis^®^ | 40 mg al día | ND | $110
Telmisartán | Micardis^®^ | 80 mg al día | | $110
Valsartán | Diovan^®^ | 80 mg al día | ND | $90
Valsartán | Diovan^®^ | 160 mg al día | | $100
IDR
Aliskirén | Tekturna^®^ | 150 mg al día | ND | $100
Aliskirén | Tekturna^®^ | 300 mg al día | | $120

1 Son dosis similares a las utilizadas en estudios de investigación.

2 Mediana del precio promedio de mayoreo del medicamento genérico en dólares, tomado del Red Book: Pharmacy's Fundamental Reference, 2011.

3 Precio promedio de mayoreo del medicamento de marca comercial en dólares, redondeado a los $5 más cercanos, tomado del Red Book: Pharmacy's Fundamental Reference, 2011.

Abreviaturas: ND = no disponible

### ¿Qué más puedo hacer para bajar mi presión arterial?

Puede hacer otras cosas para controlar su presión arterial, además de tomar medicamentos:

- Baje de peso.
- Haga ejercicio regularmente.
- Tome menos bebidas alcohólicas.
- No fume.

Pida a su médico o enfermera que le ayuden a hacer cambios.

### Pregunte a su médico

- ¿Cómo afectará este medicamento mi trabajo y mi vida diaria?
- ¿Cómo sabremos si el medicamento me está bajando la presión arterial?
- ¿Cuando debo avisarle si se presenta un efecto secundario del medicamento y qué podemos hacer en tal caso?
- ¿Este medicamento afectará otros medicamentos que tomo?
- ¿Hay alimentos que no debo comer mientras use este medicamento?
- ¿Puedo elegir un IECA, BRA o IDR que se ajuste a mi presupuesto, o hay razones por las que deba tomar uno en particular?

#### Escriba otras preguntas aquí

_______________________________________________________________________

_______________________________________________________________________

_______________________________________________________________________

_______________________________________________________________________

_______________________________________________________________________

#### Anote aquí las respuestas

_______________________________________________________________________

_______________________________________________________________________

_______________________________________________________________________

_______________________________________________________________________

_______________________________________________________________________

## Fuente

La información proviene del informe Angiotensin-Converting Enzyme Inhibitors (ACEIs), Angiotensin II Receptor Antagonists (ARBs), and Direct Renin Inhibitors for Treating Essential Hypertension: An Update. (Inhibidores de la enzima convertidora de angiotensina [IECA], antagonistas del receptor de la angiotensina II [BRA] e inhibidores directos de la renina para el tratamiento de la hipertensión esencial: actualización). El informe fue producido por el Duke University Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia de la Universidad Duke), con financiamiento de la Agency for Healthcare Research and Quality (AHRQ, por su sigla en inglés). Para obtener una copia del informe o más información sobre la AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atención Médica), visite www.effectivehealthcare.ahrq.gov (disponible sólo en inglés). Se obtuvo información adicional de la página web Medline-Plus^®^, un servicio de la National Library of Medicine (Biblioteca Nacional de Medicina) y de los National Institutes of Health (Institutos Nacionales de la Salud) de Estados Unidos. Esta página está disponible en www.nlm.nih.gov/medlineplus/spanish/medlineplus.html.

Esta guía abreviada fue preparada por el John M. Eisenberg Center for Clinical Decisions and Communications Science at Baylor College of Medicine (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas, en la Facultad de Medicina de Baylor), de Houston, TX.