# Comparación de dos tipos de pastillas para la presión arterial alta: ACEI y ARB

Guía para adultos

## Hechos resumidos

- Las ACEI y las ARB son dos de los muchos tipos de pastillas que existen para reducir la presión arterial.
- Ambos tipos de pastillas (ACEI y ARB) son eficaces para reducir la presión arterial.
- En casos poco frecuentes, las ACEI y las ARB ocasionan problemas graves. La principal diferencia en los efectos secundarios es que las ACEI producen tos seca con más frecuencia que las ARB.
- Ni las ACEI ni las ARB afectan los niveles de colesterol ni los niveles de azúcar en la sangre.
- Algunas ACEI se venden también en la forma de medicamentos genéricos, que cuestan menos.

## ¿Qué cubre esta guía?

La presión arterial alta se trata con diferentes tipos de pastillas, como los diuréticos (que ayudan a orinar), los bloqueadores beta, los inhibidores de las ACE (ACEI), y de las ARB. De hecho, a menudo se toma más de un tipo de pastilla para bajar la presión arterial.

Esta guía le ayudará a hablar con su médico o enfermera sobre dos de los muchos tipos de pastillas que se usan para disminuir la presión arterial. Aquí se comparan los beneficios, efectos secundarios, y precios de los medicamentos que se identifican con las siglas ACEI y ARB.

La información proviene de una revisión financiada por el gobierno acerca de estudios en los que se comparan las ACEI y las ARB.

## ¿Qué son las pastillas ACEI y ARB?

Las ACEI y las ARB relajan los vasos sanguíneos, y lo cual disminuye la presión arterial. Los nombres de los medicamentos ACEI y ARB se enumeran en la siguiente tabla. Si no encuentra su medicamento en la tabla, probablemente esté tomando un tipo de pastilla para la presión arterial que no se incluye en esta guía.

ACEI | | | ARB
NOMBRE GENÉRICO | NOMBRE DE LA MARCA | ¿EXISTE EN GENÉRICO? | NOMBRE GENÉRICO | NOMBRE DE LA MARCA | ¿EXISTE EN GENÉRICO?
Benazepril | Lotensin^®^ | Sí | Candesartán | Atacand^®^ | No
Captopril | Capoten^®^ | Sí | Eprosartán | Teveten^®^ | No
Enalapril | Vasotec^®^ | Sí | Irbesartán | Avapro^®^ | No
Fosinopril | Monopril^®^ | Sí | Losartán | Cozaar^®^ | No
Lisinopril | Prinivil^®^, Zestril^®^ | Sí | Olmesartán | Benicar^®^ | No
Moexipril | Univasc^®^ | No | Telmisartán | Micardis^®^ | No
Perindopril | Aceon^®^ | No | Valsartán | Diovan^®^ | No
Quinapril | Accupril^®^ | Sí
Ramipril | Altace^®^ | No
Trandolapril | Mavik^®^ | No

## ¿Por qué debe tratarse la presión arterial alta?

La presión arterial alta es uno de los problemas médicos más frecuentes. La mayoría de las personas con presión arterial alta no tienen síntomas. Por esa razón se la llama “el asesino silencioso”.

La presión arterial es la tensión que la sangre ejerce en la pared interna de las arterias (los vasos sanguíneos) al circular por el cuerpo. La presión arterial alta significa que la sangre empuja con demasiada fuerza los vasos sanguíneos. Si la presión alta no se trata, la persona puede sufrir un infarto cerebral (embolia o derrame), un ataque cardíaco, o problemas de los riñones.

En algunos casos la presión arterial disminuye si se adoptan hábitos más sanos. Para eso es beneficioso bajar de peso, comer sanamente, y hacer actividad física. La mayoría de las personas necesitan también medicamentos para poder controlar su presión arterial. Consulte a su médico o enfermera para identificar los medicamentos que más le convengan.

## ¿Cómo se comparan los beneficios de las ACEI y las ARB?

- Cuando se toman regularmente, tanto las ACEI como las ARB son eficaces para reducir la presión arterial. Las ACEI y las ARB tienen la misma eficacia.
- No afectan los niveles de colesterol ni los de azúcar en la sangre.
- En casos muy raros ocasionan problemas graves.

La elección del mejor medicamento para usted depende de lo que usted piense sobre los efectos secundarios y el costo.

## ¿Cómo se comparan los costos?

El costo suele ser una consideración importante al escoger un medicamento. Las tablas abajo le ayudarán a comparar los costos de estas pastillas. Si su seguro médico cubre medicamentos con receta, consulte cuál sería el costo para usted.

- Las ACEI y las ARB de fabricación comercial tienen un costo similar.
- Algunas ACEI existen en forma de medicamentos genéricos, que cuestan menos.

ACEI

NOMBRE GENÉRICO | NOMBRE DE LA MARCA | DOSIS PARA BAJAR LA PRESIÓN ALTA^1^ | | COSTO PARA PROVISIÓN DE 1 MES^2^
NOMBRE GENÉRICO | NOMBRE DE LA MARCA | DOSIS PARA BAJAR LA PRESIÓN ALTA^1^ | | GENÉRICO | MARCA
Benazepril | Lotensin^®^ | 10 | mg una vez al día | $30 | $45
Benazepril | Lotensin^®^ | 20 | mg una vez al día | $30 | $45
Benazepril | Lotensin^®^ | 40 | mg una vez al día | $30 | $45
Captopril | Capoten^®^ | 25 | mg dos veces al día | $40 | $115
Captopril | Capoten^®^ | 50 | mg dos veces al día | $75 | $200
Enalapril | Vasotec^®^ | 5 | mg una vez al día | $30 | $45
Enalapril | Vasotec^®^ | 10 | mg una vez al día | $30 | $45
Enalapril | Vasotec^®^ | 20 | mg una vez al día | $45 | $65
Enalapril | Vasotec^®^ | 20 | mg dos veces al día | $90 | $135
Fosinopril | Monopril^®^ | 10 | mg una vez al día | $35 | $45
Lisinopril | Prinivil^®^, Zestril^®^ | 10 | mg una vez al día | $30 | $35
Lisinopril | Prinivil^®^, Zestril^®^ | 20 | mg una vez al día | $30 | $40
Lisinopril | Prinivil^®^, Zestril^®^ | 40 | mg una vez al día | $45 | $55
Moexipril | Univasc^®^ | 7.5 | mg una vez al día | No existe genérico | $45
Moexipril | Univasc^®^ | 15 | mg una vez al día | No existe genérico | $50
Moexipril | Univasc^®^ | 15 | mg dos veces al día | No existe genérico | $95
Perindopril | Aceon^®^ | 2 | mg una vez al día | No existe genérico | $50
Perindopril | Aceon^®^ | 4 | mg una vez al día | No existe genérico | $55
Perindopril | Aceon^®^ | 8 | mg una vez al día | No existe genérico | $70
Quinapril | Accupril^®^ | 10 | mg una vez al día | $35 | $45
Quinapril | Accupril^®^ | 20 | mg una vez al día | $35 | $45
Ramipril | Altace^®^ | 2.5 | mg una vez al día | No existe genérico | $50
Ramipril | Altace^®^ | 5 | mg una vez al día | No existe genérico | $50
Ramipril | Altace^®^ | 10 | mg una vez al día | No existe genérico | $60
Trandolapril | Mavik^®^ | 1 | mg una vez al día | No existe genérico | $40
Trandolapril | Mavik^®^ | 2 | mg una vez al día | No existe genérico | $40

1 Las dosis son similares a las utilizadas en estudios de investigación.

2 El costo promedio al por mayor proviene del Drug Topics Redbook, 2007.

ARB

NOMBRE GENÉRICO | NOMBRE DE LA MARCA | DOSIS PARA BAJAR LA PRESIÓN ALTA^1^ | | COSTO PARA PROVISIÓN DE 1 MES^2^
NOMBRE GENÉRICO | NOMBRE DE LA MARCA | DOSIS PARA BAJAR LA PRESIÓN ALTA^1^ | | GENÉRICO | MARCA
Candesartán | Atacand^®^ | 4 | mg una vez al día | No existe genérico | $55
Candesartán | Atacand^®^ | 8 | mg una vez al día | No existe genérico | $55
Candesartán | Atacand^®^ | 16 | mg una vez al día | No existe genérico | $55
| | | | No existe genérico
Eprosartán | Teveten^®^ | 400 | mg una vez al día | No existe genérico | $65
Eprosartán | Teveten^®^ | 600 | mg una vez al día | No existe genérico | $75
Eprosartán | Teveten^®^ | 400 | mg dos veces al día | No existe genérico | $130
| | | | No existe genérico
Irbesartán | Avapro^®^ | 150 | mg una vez al día | No existe genérico | $55
Irbesartán | Avapro^®^ | 300 | mg una vez al día | No existe genérico | $70
| | | | No existe genérico
Losartán | Cozaar^®^ | 25 | mg una vez al día | No existe genérico | $55
Losartán | Cozaar^®^ | 50 | mg una vez al día | No existe genérico | $60
Losartán | Cozaar^®^ | 100 | mg una vez al día | No existe genérico | $80
| | | | No existe genérico
Olmesartán | Benicar^®^ | 20 | mg una vez al día | No existe genérico | $50
Olmesartán | Benicar^®^ | 40 | mg una vez al día | No existe genérico | $60
| | | | No existe genérico
Telmisartán | Micardis^®^ | 20 | mg una vez al día | No existe genérico | $50
Telmisartán | Micardis^®^ | 40 | mg una vez al día | No existe genérico | $60
Telmisartán | Micardis^®^ | 80 | mg una vez al día | No existe genérico | $65
| | | | No existe genérico
Valsartán | Diovan^®^ | 80 | mg una vez al día | No existe genérico | $60
Valsartán | Diovan^®^ | 160 | mg una vez al día | No existe genérico | $65

1 Las dosis son similares a las utilizadas en estudios de investigación.

2 El costo promedio al por mayor proviene del Drug Topics Redbook, 2007.

## ¿Cómo se comparan los efectos secundarios de las ACEI y las ARB?

Tanto las ACEI como las ARB pueden causar tos, mareo, y dolor de cabeza. La posibilidad de mareo o dolor de cabeza es casi la misma con las ACEI que con las ARB. La principal diferencia es que las ACEI tienden más a causar tos seca. En ocasiones, esta llega a ser tan intensa que se necesita cambiar de medicamento. En estudios de investigación:

- 8 de cada 100 personas que toman alguna ACEI dejan de tomarla por sus efectos secundarios.
- 3 de cada 100 personas que toman alguna ARB dejan de tomarla por sus efectos secundarios.

Hable con su médico o enfermera si le molestan cualquiera de los efectos secundarios. Sin embargo, no sea usted el que decida dejar de tomar su medicamento.

## ¿Existen riesgos graves?

Es poco frecuente, pero algunas personas muestran una reacción al medicamento llamada angioedema. En investigaciones que comparan las ACEI y las ARB, aproximadamente 1 de cada 10,000 personas desarrollan angioedema.

El síntoma más frecuente del angioedema es una hinchazón de la lengua o de los labios. Llame inmediatamente a su médico o enfermera si empieza a tener hinchazón. Puede ser indicio de una reacción adversa al medicamento.

Advertencia:

Si está tomando una ACEI o una ARB y se embaraza, llame a su médico o enfermera para pedir orientación. Las pastillas ACEI y ARB pueden causar defectos de nacimiento graves.

## ¿Dónde puedo obtener más información?

Para obtener una copia electrónica de esta guía y materiales para comparar los tratamientos y medicamentos para otros trastornos de salud, visite esta página Web: www.effectivehealthcare.ahrq.gov/spanishinfo.cfm (http://effectivehealthcare.ahrq.gov/index.cfm/guides-for-patients-and-consumers/informacion-en-espanol/)

Para obtener una copia gratuita, llame a: AHRQ Publications Clearinghouse, (800) 358–9295

Pida la publicación de AHRQ número: 08(09)-EHC003-B

Para más información sobre la presión arterial alta, visite esta página Web de MedlinePlus: http://www.nlm.nih.gov/medlineplus/spanish/highbloodpressure.html

## ¿Cuál es la fuente de esta guía?

La información de esta guía proviene de una revisión detallada de 61 informes de investigación. La revisión se titula Comparative Effectiveness of Angiotensin-Converting Enzyme Inhibitors (ACEIs) and Angiotensin II Receptor Antagonists (ARBs) for Treating Essential Hypertension – 2007 (Comparación de la efectividad de las encimas convertidoras angiotensin (ACEIs, en inglés) y las receptoras antagonistas II (ARBs, en inglés) para curar la hipertensión esencial – 2007), y fue escrita por el Duke Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia de Duke).

## Related Content

Research Review

Clinician Guide

Consumer Guide