# Tratamiento del dolor pélvico crónico

Revisión de las investigaciones para mujeres

## ¿Es esta información apropiada para mí?

### Es apropiado si

- Un médico^*^ le ha dicho que tiene dolor pélvico crónico (dolor en la zona situada entre las caderas y debajo del ombligo, que ha durado más de 3 meses).

### No es apropiado si

- A veces tiene dolor en la pelvis, pero un médico no le ha dicho que sea dolor pélvico crónico.
- El dolor que siente en la pelvis se produce solamente durante su período menstrual, durante las relaciones sexuales o al momento de orinar o defecar.
- Tiene menos de 18 años o es hombre. Esta información proviene de estudios de investigación realizados en mujeres adultas.

### ¿Qué cubrirá este resumen?

En este resumen se describe el dolor pélvico crónico y se explican las investigaciones sobre los tratamientos para las mujeres con esta condición. Puede ayudarle a hablar con su médico acerca del tratamiento o el control del dolor pélvico crónico.

Investigadores financiados por la Agency for Healthcare Research and Quality (Agencia para la Investigación y Calidad de la Atención Médica; AHRQ por su sigla en inglés), una agencia del gobierno federal, revisaron 36 estudios sobre los tratamientos para el dolor pélvico crónico publicados entre enero de 1990 y mayo de 2011. El informe se puede leer en www.effectivehealthcare.ahrq.gov/pelvicpain.cfm (disponible solo en inglés).

## Conozca su condición

### ¿Qué es el dolor pélvico crónico?

El dolor pélvico crónico (CPP por su sigla en inglés) es un dolor constante en la región pélvica (entre las caderas y debajo del ombligo) que ha durado 3 meses o más.

- El dolor puede ser constante pero leve o agudo y similar a un calambre.
- Puede ser continuo, o puede aparecer y desaparecer.
- Es posible que el dolor no se sienta en un punto específico, sino en toda la región pélvica.
- También es posible que sienta presión en la región pélvica.
- El CPP puede dificutarle hacer actividades diarias o ejercicio.

### ¿Qué causa el dolor pélvico crónico?

El CPP es una condición compleja que puede tener muchas causas y estar vinculado a otras condiciones. Algunas de estas condiciones son:

- Síndrome de intestino irritable: condición que afecta al intestino grueso y puede causar inflamación abdominal, cólicos, estreñimiento o diarrea.
- Endometriosis: el endometrio, que es el revestimiento interno del útero, crece por fuera de este órgano.
- Músculos del piso pélvico tensos: los músculos de la parte baja de la región pélvica se ponen tensos o acalambran.
- Síndrome de vejiga dolorosa: la vejiga se vuelve sensible y se irrita fácilmente.
- Tejido cicatricial en la región pélvica: usted puede tener una cicatriz por una infección una operación u otro tratamiento, que ahora causa dolor.

### Encuentre la causa de su dolor pélvico

Hay tratamientos para las causas específicas del CPP. Por ello, es muy importante que acuda al médico para hacerse una evaluación completa con el fin de identificar la causa de su CPP.

- Su médico de cabecera le hará preguntas sobre su dolor y su historial médico y también le hará un examen físico minucioso.
- Su médico de cabecera puede referirla para que vea a varios tipos de médicos: un ginecólogo (especialista en el sistema reproductor femenino), un gastroenterólogo (especialista en enfermedades del sistema digestivo) o un urólogo (especialista en enfermedades de las vías urinarias).
  - Estos especialistas determinarán si la causa del dolor puede ser endometriosis, síndrome de intestino irritable o síndrome de vejiga dolorosa. Éstas son las tres causas comunes del CPP.
- Su médico puede sugerir una laparoscopia diagnóstica.

### ¿Qué es una laparoscopia diagnóstica?

En la laparoscopia diagnóstica, el médico introduce, por un pequeño corte en el abdomen, un tubo fino con una cámara minúscula, para examinar la región pélvica y buscar las posibles causas del dolor.

La laparoscopia puede también utilizarse en cirugías para tratar su CPP o la condición que está causando el dolor. En la página 6, se ofrece más información sobre las cirugías con laparoscopio para tratar el CPP.

El CPP es una condición compleja. En muchas mujeres, los médicos no logran descubrir la causa del dolor pélvico. No conocer la causa puede ser frustrante y puede afectar su bienestar emocional y relaciones con los demás. Puede, incluso, causar depresión. Sin embargo, es posible que los médicos puedan ayudarle a controlar su dolor, aun cuando no hayan encontrado la causa.

## Conozca sus opciones

### Tratamientos para el CPP

Se sabe muy poco sobre maneras eficaces de tratar el CPP. Es posible que el médico pruebe una o más formas para ayudarle a aliviar o lidiar con el dolor, pero existen muy pocas investigaciones que le indiquen al médico cuáles tratamientos funcionan.

Cuando no se encuentra la causa, los médicos pueden recomendar un medicamento, un tratamiento hormonal o una operación, para tratar de aliviar sus síntomas de CPP. Su médico puede sugerir un analgésico narcótico o no narcótico, como la aspirina, Tylenol^®^, Advil^®^, Demerol^®^ u OxyContin^®^ para ayudar a controlar su dolor. Además, le puede sugerir psicoterapia o consejería, fisioterapia, cambios en la alimentación o ejercicio, para ayudarla con su CPP.

La tabla de la página siguiente muestra lo que los investigadores han encontrado acerca de la eficacia de los medicamentos, tratamientos hormonales y cirugías para aliviar los síntomas del CPP. El hecho de que no se hayan realizado suficientes estudios sobre muchos de los tratamientos mencionados, no significa que estos tratamientos no funcionan en algunas personas.

Resultados de las investigaciones sobre los tratamientos del CPP

Tipo de tratamiento | Lo que dicen las investigaciones
Medicamentos
- Gabapentina (nombres comerciales: Fanatrex^®^, Gabarone^®^, Gralise^®^, Horizant^®^ y Neurontin^®^).; - Amitriptilina (nombres comerciales: Elavil^®^, Endep^®^ y Vanatrip^®^).; - Toxina botulínica A, llamada comúnmente Botox^®^, que se administra en forma de inyección. | - No existe suficiente investigación para saber si alguno de estos medicamentos ayudan a aliviar los síntomas del CPP.
Tratamientos hormonales
- Anticonceptivos hormonales (control de la natalidad), inyecciones de hormonas y medicamentos que actúan como hormonas. | - No existe suficiente investigación para saber si algunos otros tratamientos hormonales ayudan a aliviar los síntomas del CPP.; - En un estudio, las mujeres con endometriosis que tomaron un medicamento de tipo hormonal llamado raloxifeno (Evista^®^) después de someterse a laparoscopia diagnóstica, volvieron a sentir dolor con más rápidez que las mujeres que no tomaron ningún medicamento.; - En un estudio, las mujeres que tomaron un medicamento de tipo hormonal llamado leuprolida de absorción lenta (Lupron Depot^®^) sintieron menos dolor que las mujeres que no tomaron ningún medicamento. La mayoría de las mujeres del estudio tenían endometriosis.
Cirugías
- Adhesiólisis laparoscópica: se remueve el tejido cicatricial que se encuentra dentro y alrededor del intestino.; - Ablación laparoscópica del nervio uterosacro (LUNA por su sigla en inglés): se destruyen algunos nervios del útero o zonas circundantes; - Resección del ligamento uterosacro: se eliminan algunos nervios y tejidos que se encuentran alrededor del útero.; - Histerectomía: un cirujano extirpa todo o parte del útero y los ovarios. | - Algunos estudios mostraron que la eliminación del tejido cicatricial mediante un laparoscopio (llamada “adhesiólisis laparoscópica”) no tuvo efecto en cuanto a aliviar el dolor pélvico o mejorar la calidad de vida de la mujer.; - Algunos estudios mostraron que el método LUNA no alivió el dolor pélvico más que el hacerse una laparoscopia diagnóstica; - No se tiene suficiente evidencia para saber qué tanto ayudan a aliviar los síntomas del CPP la resección del ligamento uterosacro o la histerectomía.

### ¿Qué más debo saber sobre los tratamientos del CPP?

- No hay una solución rápida para el CPP. Es posible que usted y su médico tengan que probar muchos tratamientos distintos antes de que empiecen a mejorar sus síntomas.
- Algunas opciones de tratamiento pueden requerir largo tiempo para que usted empiece a sentirse mejor. Es importante no darse por vencida sólo porque no se obtengan resultados inmediatos.
- También es importante que trate de mantener una actitud positiva y colaborar con su médico para controlar el CPP. Hable con su médico, amigos y familiares cuando se sienta desanimada.

## Tome una decisión respecto al tratamiento del CPP

### ¿En qué cosas debo pensar?

- Cuando no haya mucha evidencia para orientar la decisión que deben tomar usted y su médico, sus propios deseos y valores tendrán un papel importante. Usted y su médico deben hablar acerca de lo siguiente:
  - Los posibles efectos secundarios de los medicamentos y qué efectos secundarios estaría dispuesta a tolerar si un medicamento le ayudara a aliviar su dolor.
  - Si desea probar otros tratamientos antes de la cirugía, ya que no hay mucha evidencia de que ésta ayude a aliviar el dolor.
  - Qué piensa sobre una posible histerectomía, si su médico la sugiere. Debe pensar qué tan importante es para usted embarazarse o entrar en la menopausia (si le quitan los ovarios).
  - Otras maneras de evitar que el CPP afecte su trabajo, sus relaciones y su vida diaria.
- Todos los tratamientos para el CPP pueden estar cubiertos de forma diferente por su seguro médico y posiblemente hayan gastos que usted tenga que pagar de su bolsillo.
- Es importante obtener apoyo adicional de amigos, familiares, consejeros y otras personas, mientras usted y su médico tratan de encontrar el tratamiento correcto.

### Pregunte a su médico

Hable con su médico sobre cuánto dolor siente y qué tratamiento responde mejor a sus necesidades, deseos y valores específicos. Pregunte a su médico:

- ¿Cómo decidiremos qué tratamientos probar?
- ¿Cuáles son los efectos secundarios o los riesgos de cada tratamiento?
- ¿En cuánto tiempo empezaré a sentirme mejor?
- ¿Cómo sabré si realmente es necesaria la cirugía?
- ¿Con qué recursos cuento para obtener apoyo mientras tratamos de encontrar el tratamiento correcto?

Otras preguntas:

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

Anote aquí las respuestas:

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

______________________________________________________________________

## Fuente

La información de este resumen proviene del informe Noncyclic Chronic Pelvic Pain Therapies for Women: Comparative Effectiveness (Tratamientos para el dolor pélvico crónico no cíclico para mujeres: comparación de la efectividad), publicado en enero de 2012.

El informe fue producido por el Vanderbilt Evidence-based Practice Center (Centro de Práctica Basada en la Evidencia de Vanderbilt), con financiamiento de la Agency for Healthcare Research and Quality (Agencia para la Investigación y Calidad de la Atención Médica; AHRQ por su sigla en inglés).

Para obtener una copia del informe o más información sobre la AHRQ y el Effective Health Care Program (Programa sobre la Efectividad de la Atención Médica), visite www.effectivehealthcare.ahrq.gov/pelvicpain.cfm (disponible sólo en inglés). Se obtuvo información adicional de la página web MedlinePlus^®^, un servicio de la National Library of Medicine (Biblioteca Nacional de Medicina) y de los National Institutes of Health (Institutos Nacionales de la Salud) de Estados Unidos. Esta página está disponible en www.nlm.nih.gov/medlineplus/spanish.

Este resumen fue preparado por el John M. Eisenberg Center for Clinical Decisions and Communications Science at Baylor College of Medicine (Centro John M. Eisenberg para la Ciencia de las Comunicaciones y Decisiones Clínicas, en la Facultad de Medicina de Baylor) en Houston, Texas. Este resumen fue revisado por mujeres con dolor pélvico crónico.

Traducido de la publicación en inglés titulada Treating Chronic Pelvic Pain: A Review of the Research for Women

* En este resumen, el término “médico” se refiere a los profesionales de la atención médica que puedan atenderlo, incluidos su médico, ginecólogo, gastroenterólogo, urólogo, enfermera o asistente médico.