# Other Effects

## Introduction

This chapter addresses evidence on smoking and health effects over a range of specific diseases and non-specific but adverse consequences. The associations reviewed appear to reflect both specific and non-specific pathways of injury by tobacco smoke. The evidence indicates that smoking should be considered not only a cause of specific diseases and conditions, but a contributing factor to nonspecific morbidity and a diminished quality of life.

## Diminished Health Status

This section focuses on the question of whether cigarette smokers have poorer health in comparison with nonsmokers, beyond the already well-characterized burden of morbidity and mortality from the specific diseases caused by smoking. The hypothesis that smoking might impair health in general draws plausibility from the toxicologic richness of tobacco smoke, the well-documented systemic distribution of tobacco smoke components and metabolites, and the effects on host defenses, including the immune system. Additionally, impairment of organ function short of the level at which clinical disease is diagnosed may leave the smoker vulnerable to otherwise well-tolerated threats to health. For example, the reduction of lung function found in many smokers who do not have overt chronic obstructive pulmonary disease (COPD) may increase the risk for developing a more severe illness with a respiratory infection, or having a respiratory complication following surgery.

This section reviews studies that have addressed a number of health status indicators (Figure 6.1) including direct reports of health status or responses to an instrument that provides a health status index, and indirect indicators such as medical services utilization data. When interpreting the findings of these studies, consideration needs to be given to the potential causal pathways linking smoking to a poor health status, the assessment and measurement of health status, and the potential for biases, such as from confounding, to affect associations of smoking with these outcome measures.

Figure 6.1 A conceptual model for the relationship between cigarette smoking and diminished health status

For the diseases caused by smoking, direct causal pathways are implicit. For example, substantial evidence supports the hypothesis that smoking causes lung cancer through the direct deposition of tobacco smoke carcinogens in the respiratory tract. For some of the outcome measures considered in this section, pathways are far less certain and may be both direct and indirect. Increased absenteeism might reflect, for example, the tendency of smokers to have more severe respiratory illnesses than nonsmokers, possibly attributable to the effects of smoking on respiratory defenses or because smokers tend to have a lower level of lung function.

The outcomes considered in this section have multiple determinants. Health status itself is an integrative measure reflecting the net consequences of the many varied factors that determine health and well-being. To the extent that smokers differ from non-smokers in these factors, there is a potential for confounding to distort associations of smoking with the outcome measures. Studies show, for example, that smokers and nonsmokers differ in aspects of lifestyle and in their approaches to health care (e.g., the use of preventive services such as multiphasic testing [Oakes et al. 1974] and screening [Beaulieu et al. 1996; Edwards and Boulet 1997]). Additionally, the suite of relevant confounding factors may differ from outcome to outcome, and for some outcomes there is uncertainty as to the relevant confounding factors. Some of the individual characteristics that affect the decision to start smoking and to continue to smoke also may be determinants of risk for the outcomes considered here.

### Conclusions of Previous Surgeon General’s Reports

Extensive research over time has identified cigarette smoking as a cause of specific diseases, and many reports from the Surgeon General have focused on smoking and these diseases. These reports have also addressed more general and nonspecific adverse consequences of smoking, such as increased rates of absenteeism from work or the utilization of medical services among smokers in comparison with nonsmokers. Conclusions from the reports that relate to these outcomes are listed in Table 6.1, including findings on general respiratory morbidity. Reports of increased morbidity from common and frequent viral and bacterial respiratory infections among smokers have been reviewed (U.S. Department of Health and Human Services [USDHHS] 1990) and are among the topics covered in Chapter 4 of this report. However, the overall health status of smokers compared with nonsmokers has not been comprehensively addressed in prior Surgeon General’s reports.

Table 6.1 Conclusions from previous Surgeon General’s reports concerning smoking as a cause of diminished health status and respiratory morbidity

Statement | Surgeon General’s report
“Cough, sputum production, or the two combined are consistently more frequent among cigarette smokers than among non-smokers.” (p. 302) | 1964
“Even relatively young cigarette smokers show increased respiratory symptoms and decreased ventilatory function.” (p. 31) | 1967
“Cigarette smokers have higher rates of disability than nonsmokers, whether measured by days lost from work among the employed population, by days spent ill in bed, or by the most general measure — days of ‘restricted activity’ due to illness or injury.” (p. 24) | 1967
“Cigarette smokers show an increased prevalence of respiratory symptoms, including cough, sputum production, and breathlessness, when compared with nonsmokers.” (pp. 9–10) | 1971
“Respiratory infections are more prevalent and severe among cigarette smokers, particularly heavy smokers, than among nonsmokers.” (p. 10) | 1971
“Investigations of high school students have demonstrated that abnormal pulmonary function and pulmonary symptoms are more common in smokers than nonsmokers.” (p. 48) | 1972
“Cigarette smokers have also been shown to have a significantly longer duration of respiratory symptoms following mild viral illness than nonsmokers.” (p. 78) | 1975
“In addition to an increased risk of COPD, cigarette smokers are more frequently subject to and require longer convalescence from other respiratory infections than nonsmokers. Also, if they require surgery, they are more likely to develop postoperative respiratory complications.” (p. 61) | 1975
“The age-adjusted incidence of acute conditions (e.g., influenza) for males who had ever smoked was 14 percent higher, and for females 21 percent higher, than for those who had never smoked cigarettes.” (p. 1–12) | 1979
“A wide variety of alterations in the immune system have been observed due to cigarette smoking.” (p. 1–18) | 1979
“Cessation of smoking definitely improves pulmonary function and decreases the prevalence of respiratory symptoms.” (p. 1–18) | 1979
“Cigarette smokers have an increased frequency of respiratory symptoms, and at least two of them, cough and sputum production, are dose-related.” (p. 1–18) | 1979
“The relationship between smoking and an increased prevalence of respiratory symptoms in the adult has been well established in studies of hospital and clinic patients, working groups, total communities, and representative samples of the community.” (p. 6–20) | 1979
“In summary, many recent studies demonstrate a higher frequency of respiratory symptoms in women who smoke as compared to women who do not smoke. This is true in surveys including children, adolescents, young adults, working age, and elderly women. The effect of cigarette smoking is related in terms of both the number of cigarettes and years smoked.” (p. 156) | 1980
“Relationships between smoking and cough or phlegm are strong and consistent; they have been amply documented and are judged to be causal.” (p. 47) | 1984
“Consideration of evidence from many different studies has led to the conclusion that cigarette smoking is the overwhelmingly most important cause of cough, sputum, chronic bronchitis, and mucus hypersecretion.” (p. 48) | 1984
“Smoking cessation reduces rates of respiratory symptoms such as cough, sputum production, and wheezing, and respiratory infections such as bronchitis and pneumonia, compared with continued smoking.” (p. 349) | 1990
“Former smokers have better health status than current smokers as measured in a variety of ways, including days of illness, number of health complaints, and self-reported health status.” (p. 92) | 1990

Sources: U.S. Department of Health, Education, and Welfare 1964, 1967, 1971, 1972, 1975, 1979; U.S. Department of Health and Human Services 1980, 1984, 1990.

### Biologic Basis

Cigarette smoke, inhaled through the mouth into the lungs, reaches lung airways and alveoli, where the tobacco smoke components pass into the systemic circulation (Murray 1986). The airways and alveoli themselves are exposed to the gaseous and particulate components of tobacco smoke as many of these components readily pass through the alveolar-capillary membrane into the alveolar capillaries and then circulate throughout the body. Nicotine, for example, which is among these components, reaches the brain within 10 seconds after smoke is inhaled (USDHHS 1988). It is distributed throughout the body and has been found in breast milk (Schwartz-Bickenbach et al. 1987; Schulte-Hobein et al. 1992; Golding 1997) and in cervical mucus (Prokopczyk et al. 1997). Carbon monoxide, a diffusible gas, moves from the alveoli into the capillaries where it binds tightly to the hemoglobin of the red blood cells. Benzo[a]pyrene, a well-characterized carcinogen in tobacco smoke, can be found bound to the blood cells in the epithelial cells of the airways of smokers and in their major organs. The effects of smoking on host defenses and aspects of immune function have been covered in prior reports (USDHHS 1990, 1994) and again in this report. These effects may have the consequence of increasing risks for infections, whether of the respiratory tract or other organs. However, there has been less research to date on infections beyond those of the respiratory tract. This systemic distribution of tobacco smoke components underlies the associations between smoking and disease that are well documented for many organs including cardiovascular disease, stroke, and cancers of the kidney and urinary bladder. The widespread distribution may also lead to more general effects on health.

This same systemic distribution may have non-specific effects as well, contributing to a reduction in health status. Exposure to tobacco smoke components causes smoke-specific diseases such as bladder cancer (carcinogens in urine come in contact with the bladder) and atherosclerosis, probably reflecting multiple underlying mechanisms with inflammation having a central role (Cross et al. 1999). Underlying mechanisms might include heightened oxidative stress and reduced antioxidant defenses, increased inflammatory activity, reduced host defenses against infection, and lowered reparative capacities of tissues. The evidence on these mechanisms is at varying levels of development. This section focuses on oxidative stress as an example, selected because the available literature is extensive.

#### Oxidative Stress

Oxidative stress refers to an increased exposure to oxidants and/or a decreased antioxidant capacity, caused by oxygen radicals that mutate DNA, promote atherosclerosis, and lead to chronic lung injury. Oxidative stress is now hypothesized to be a general mechanism underlying aging and many of the chronic diseases associated with aging, contributing to the development of cancer, cardiovascular disease, and COPD (Ames et al. 1995). Mounting evidence points to chronic oxidative stress as one mechanism whereby smoking affects health. Smoking is associated with evidence of chronic systemic inflammation, perhaps a consequence of the chronic oxidative stress experienced by the smoker (Cross et al. 1999; Hecht 1999). The oxidant load posed by cigarette smoke is substantial; the tar component is estimated to contain 10^18^ oxygen radicals per gram of tar and the gas component to have as many as 10^15^ other organic radicals per puff (Repine et al. 1997).

A number of comparisons between smokers and nonsmokers have been made with respect to measures of biomolecular oxidative damage, including oxidative injury to DNA, proteins, and lipids. A widely used assay for quantifying oxidative damage to DNA is 8-hydroxydeoxyguanosine (8-OH-dG). The assay measures hydroxyl radical-induced DNA damage at C8 of guanine (Lagorio et al. 1994), which has been linked experimentally to cigarette smoke condensate (Leanderson and Tagesson 1990). Cultured human lung cells exposed to cigarette smoke had 70 percent higher 8-OH-dG levels than unexposed cells (Leanderson and Tagesson 1992). DNA from the lung tissue of smokers had 42 percent higher 8-OH-dG levels than the DNA from nonsmokers, and 8-OH-dG concentrations increased according to the number of cigarettes smoked per day (Asami et al. 1997).

Studies comparing 8-OH-dG levels in DNA from smokers and nonsmokers are summarized in Table 6.2. In general, regardless of the biologic material, smokers tend to have greater damage. A strong dose-response association with the number of cigarettes smoked was observed in one study (Lodovici et al. 2000), but an inverse dose-response trend was observed in another (van Zeeland et al. 1999). When levels of 8-OH-dG in circulating lymphocytes were compared before and after cigarettes were smoked, Kiyosawa and colleagues (1990) observed that 8-OH-dG levels increased 54 percent after smoking. A similar but less frequently used approach to determine biomolecular oxidative damage is to assay 8-hydroxyguanine, which has been found in leukocyte DNA (Asami et al. 1997) and in urine (Suzuki et al. 1995) of smokers at concentrations at least 90 percent higher than in nonsmokers.

Table 6.2 Studies on the association between smoking and oxidative injury

Study | Population | Group | Results | | | Comments
Study | Population | Group | Precessation | Postcessation | Percentage difference | Comments
8-OH-dG^*^ in DNA from peripheral leukocytes
Kiyosawa et al. 1990 | 10 healthy male volunteers, aged 20–22 years, blood drawn before and 10 minutes after smoking 2 cigarettes in 10 minutes | Total | 3.3 (before smoking) | 5.1 (after smoking) | 54.5 | 8-OH-dG/10^6^ dG
Takeuchi et al. 1994 | 79 healthy male factory workers, aged 25–59 years | Current and never | 1.10 (never) | 1.075 (current) | −2.3 | 8-OH-dG/10^5^ dG; numbers were abstracted from figure
Takeuchi et al. 1994 | 79 healthy male factory workers, aged 25–59 years | Former and never | 1.10 (never) | 1.00 (former) | −9.1 | 8-OH-dG/10^5^ dG; numbers were abstracted from figure
Degan et al. 1995 | 180 smokers and 73 nonsmokers | Total | 5.94 | 7.14 | 20.2 | 8-OH-dG mol/10^5^ mol dG
Lee et al. 1998 | 20 healthy volunteers, 15 smokers, aged 19–31 years | Total | 2.21 | 3.61 | 63.3 | 8-OH-dG/10^5^ dG
van Zeeland et al. 1999 | 102 healthy adults, aged 25–45 years | Current and never | 34.0 (never) | 29.3 (current) | −13.8 | 8-OH-dG/10^6^ dG
van Zeeland et al. 1999 | 102 healthy adults, aged 25–45 years | Former and never | 34.0 (never) | 35.2 (former) | 3.5 | 8-OH-dG/10^6^ dG
Lodovici et al. 2000 | 56 healthy male and female volunteers, aged 18–64 years | Current and never | 15.3 (never) | 33.1 (current) | 116.3 | 8-OH-dG/10^6^ dG
Lodovici et al. 2000 | 56 healthy male and female volunteers, aged 18–64 years | Former and never | 15.3 (never) | 17.8 (former) | 16.3 | 8-OH-dG/10^6^ dG
8-OH-dG in DNA from urine
Loft et al. 1992 | 83 randomly selected persons, aged 40–64 years | Total | 2.13 | 3.20 | 50.2 | 8-OH-dG pmol/24 hours
Tagesson et al. 1993 | 129 persons (30 asbestos-exposed workers, 28 rubber workers, 30 azo dye factory workers, 41 controls) | Total | 1.367 | 1.478 | 8.1 | Weighted average; 8-OH-dG μmol/mol creatinine
Tagesson et al. 1993 | 129 persons (30 asbestos-exposed workers, 28 rubber workers, 30 azo dye factory workers, 41 controls) | Controls | 1.01 | 1.13 | 11.9 | Weighted average; 8-OH-dG μmol/mol creatinine
Tagesson et al. 1993 | 129 persons (30 asbestos-exposed workers, 28 rubber workers, 30 azo dye factory workers, 41 controls) | Asbestos-exposed | 1.38 | 1.41 | 2.2 | Weighted average; 8-OH-dG μmol/mol creatinine
Tagesson et al. 1993 | 129 persons (30 asbestos-exposed workers, 28 rubber workers, 30 azo dye factory workers, 41 controls) | Rubber | 1.60 | 1.34 | −16.3 | Weighted average; 8-OH-dG μmol/mol creatinine
Tagesson et al. 1993 | 129 persons (30 asbestos-exposed workers, 28 rubber workers, 30 azo dye factory workers, 41 controls) | Azo dye | 2.10 | 1.88 | −10.5 | Weighted average; 8-OH-dG μmol/mol creatinine
Lagorio et al. 1994 | 65 randomly sampled gas station attendants, Italy | Current and never | 1.32 (never) | 1.41 (current) | 6.8 | 8-OH-dG μmol/mol creatinine
Lagorio et al. 1994 | 65 randomly sampled gas station attendants, Italy | Former and never | 1.32 (never) | 1.29 (former) | −2.3 | 8-OH-dG μmol/mol creatinine
Tagesson et al. 1996 | 343 workers from the Swedish art glass industry | Total | 11.5 | 13.4 | 16.5 | Weighted average; 8-OH-dG nmol/L
Tagesson et al. 1996 | 343 workers from the Swedish art glass industry | Men | 12.6 | 14.1 | 11.9 | Weighted average; 8-OH-dG nmol/L
Tagesson et al. 1996 | 343 workers from the Swedish art glass industry | Women | 9.3 | 12.1 | 30.1 | Weighted average; 8-OH-dG nmol/L
Protein carbonyls in plasma
Lee et al. 1998 | 20 healthy volunteers, 15 smokers, aged 19–31 years | Total | 1.59 | 2.56 | 61.0 | Protein carbonyl/nmol/mg of protein
Isoprostanes in plasma
Morrow et al. 1995 | Pilot: 16 smokers, 8 nonsmokers Main study: 10 smokers, 10 age- and gender-matched nonsmokers | Pilot: free | 90 | 166 | 84.4
Morrow et al. 1995 | Pilot: 16 smokers, 8 nonsmokers Main study: 10 smokers, 10 age- and gender-matched nonsmokers | Pilot: esterified | 290 | 496 | 71.0
Morrow et al. 1995 | Pilot: 16 smokers, 8 nonsmokers Main study: 10 smokers, 10 age- and gender-matched nonsmokers | Main: free | 103 | 242 | 135.0
Morrow et al. 1995 | Pilot: 16 smokers, 8 nonsmokers Main study: 10 smokers, 10 age- and gender-matched nonsmokers | Main: esterified | 345 | 574 | 66.4
Morrow et al. 1995 | Pilot: 16 smokers, 8 nonsmokers Main study: 10 smokers, 10 age- and gender-matched nonsmokers | Main: cessation/free | 250 | 156 | 60.3 | 2 weeks after cessation
Morrow et al. 1995 | Pilot: 16 smokers, 8 nonsmokers Main study: 10 smokers, 10 age- and gender-matched nonsmokers | Main: cessation/esterified | 624 | 469 | 33.0
Pilz et al. 2000 | 47 smokers ready to quit smoking, aged 30–66 years | Total: cessation | 490 | 300 | 63.3 | pmol/L (serum in plasma) 3 weeks after cessation
Isoprostanes in urine
Morrow et al. 1995 | 10 smokers, 10 age- and gender-matched nonsmokers | Total | 415 | 870 | 109.6 | pmol/nmol creatinine
Reilly et al. 1996 | 24 chronic smokers, 24 age- and gender-matched controls, aged 20–47 years | Total | 63.7 | 122.5 | 92.3 | pmol/mmol creatinine
Reilly et al. 1996 | 24 chronic smokers, 24 age- and gender-matched controls, aged 20–47 years | Moderate | 54.1 | 92.7 | 71.3 | pmol/mmol creatinine
Reilly et al. 1996 | 24 chronic smokers, 24 age- and gender-matched controls, aged 20–47 years | Heavy | 54.1 | 176.5 | 226.2 | dose-response relationship
Reilly et al. 1996 | 24 chronic smokers, 24 age- and gender-matched controls, aged 20–47 years | Cessation | 145.5 | 114.6 | 27.0 | dose-response relationship
Practicò et al. 1998 | 6 smokers, 6 nonsmokers, aged 31–45 years | Total IPF_2a_ pg/ng creatinine | 1,525 | 740 | 106.1 | Cox-dependent and independent excretion in human urine
Practicò et al. 1998 | 6 smokers, 6 nonsmokers, aged 31–45 years | Total 8-iso PGF_2a_ pg creatinine | 270 | 95 | 184.2 | Cox-dependent and independent excretion in human urine
Pilz et al. 2000 | 47 smokers ready to quit smoking, aged 30–66 years | Total: cessation | 580 | 330 | 75.8 | 3 weeks after cessation; pg 8-epi-PGF _2a_/mg creatine
Thiobarbituric acid reactive substances (TBARS) in malondialdehyde (MDA)
Harats et al. 1989 | 16 smokers, 12 age-matched nonsmokers, aged 23–56 years | Total (stored) | 0.287 | 0.198 | 44.9 | Smokers had not smoked for
Harats et al. 1989 | 16 smokers, 12 age-matched nonsmokers, aged 23–56 years | Total (fresh) | 0.180 | 0.154 | 16.9 | 24–40 hours Plasma: nmol/mL LDL^†^: nmol/mg protein
Harats et al. 1990 | 17 smokers before and 2 weeks after vitamin C supplementation; 10 smokers before and 90 minutes after smoking | Study I | Before smoking | After smoking | | Plasma: nmol/mL LDL: nmol/mg protein
Harats et al. 1990 | 17 smokers before and 2 weeks after vitamin C supplementation; 10 smokers before and 90 minutes after smoking | No treatment | 0.106 | 0.187 | 76.4 | Plasma: nmol/mL LDL: nmol/mg protein
Harats et al. 1990 | 17 smokers before and 2 weeks after vitamin C supplementation; 10 smokers before and 90 minutes after smoking | Vitamin C treatment | 0.138 | 0.145 | 5.1 | Plasma: nmol/mL LDL: nmol/mg protein
Harats et al. 1990 | 17 smokers before and 2 weeks after vitamin C supplementation; 10 smokers before and 90 minutes after smoking | Study II: TBARS in LDL | | | | Plasma: nmol/mL LDL: nmol/mg protein
Harats et al. 1990 | 17 smokers before and 2 weeks after vitamin C supplementation; 10 smokers before and 90 minutes after smoking | No treatment | 0.584 | 1.275 | 118.3 | Plasma: nmol/mL LDL: nmol/mg protein
Harats et al. 1990 | 17 smokers before and 2 weeks after vitamin C supplementation; 10 smokers before and 90 minutes after smoking | Vitamin C treatment | 0.683 | 1.333 | 95.2 | Plasma: nmol/mL LDL: nmol/mg protein
Harats et al. 1990 | 17 smokers before and 2 weeks after vitamin C supplementation; 10 smokers before and 90 minutes after smoking | Vitamin E treatment | 0.627 | 0.663 | 5.7 | Plasma: nmol/mL LDL: nmol/mg protein
Harats et al. 1990 | 17 smokers before and 2 weeks after vitamin C supplementation; 10 smokers before and 90 minutes after smoking | Study II: Plasma TBARS | | | | Plasma: nmol/mL LDL: nmol/mg protein
Harats et al. 1990 | 17 smokers before and 2 weeks after vitamin C supplementation; 10 smokers before and 90 minutes after smoking | No treatment | 0.106 | 0.197 | 85.4 | Plasma: nmol/mL LDL: nmol/mg protein
Harats et al. 1990 | 17 smokers before and 2 weeks after vitamin C supplementation; 10 smokers before and 90 minutes after smoking | Vitamin C treatment | 0.107 | 0.118 | 10.3 | Plasma: nmol/mL LDL: nmol/mg protein
Harats et al. 1990 | 17 smokers before and 2 weeks after vitamin C supplementation; 10 smokers before and 90 minutes after smoking | Vitamin E treatment | 0.119 | 0.123 | 3.4 | Plasma: nmol/mL LDL: nmol/mg protein
Scheffler et al. 1990 | 17 male smokers, 21 male nonsmokers, mean age 30–32 years | Time course of TBARS in LDL during incubation | | | | LDL: nmol/mL
Scheffler et al. 1990 | 17 male smokers, 21 male nonsmokers, mean age 30–32 years | 0 hours | 1 | 1 | 0 | LDL: nmol/mL
Scheffler et al. 1990 | 17 male smokers, 21 male nonsmokers, mean age 30–32 years | 1 hour | 1 | 1 | 0 | LDL: nmol/mL
Scheffler et al. 1990 | 17 male smokers, 21 male nonsmokers, mean age 30–32 years | 2 hours | 9 | 4 | 125 | LDL: nmol/mL
Scheffler et al. 1990 | 17 male smokers, 21 male nonsmokers, mean age 30–32 years | 3 hours | 14 | 7 | 100 | LDL: nmol/mL
Scheffler et al. 1990 | 17 male smokers, 21 male nonsmokers, mean age 30–32 years | 4 hours | 14 | 7 | 100 | LDL: nmol/mL
Scheffler et al. 1990 | 17 male smokers, 21 male nonsmokers, mean age 30–32 years | 5 hours | 14 | 7 | 100 | LDL: nmol/mL
Scheffler et al. 1990 | 17 male smokers, 21 male nonsmokers, mean age 30–32 years | 6 hours | 14 | 7 | 100 | LDL: nmol/mL
Scheffler et al. 1992 | 17 smokers, 21 nonsmokers | Incubation for 3 hours | 14.2 | 7.3 | 94.5
Scheffler et al. 1992 | 17 smokers, 21 nonsmokers | 1 week storage | 12.0 | 9.8 | 22.4
Duthie et al. 1993 | 242 adults, aged 45–69 years | Total | 1.87 | 1.76 | 6.3 | nmol/mL
Miller et al. 1997 | 107 nonsmokers, 14 smokers, mean age 48–49 years | Total | 24 | 21 | 14.3 | μmol/mL
Mosca et al. 1997 | 90 adults, aged 39–80 years | Total: former vs. never | 0.05 (former) | 0.07 (never) | −28.6 | LDL: μmol/nmol
Motoyama et al. 1997 | 40 healthy males, 20 smokers, 20 nonsmokers, aged 26–35 years | Total | 1.8 | 1.3 | 38.5 | nmol/mL
Motoyama et al. 1997 | 40 healthy males, 20 smokers, 20 nonsmokers, aged 26–35 years | Smokers: pre/postsmoking | 2.7 (after smoking) | 1.7 (before smoking) | 35.3 | After: 10 minutes Before: at least 8 hours of abstaining from smoking
Berr 1998 | 74 men and 815 women, aged 59–71 years | Men | 2.97 | 2.90 | 2.41 | μmol/L in plasma
Berr 1998 | 74 men and 815 women, aged 59–71 years | Women | 3.06 | 2.96 | 3.4 | μmol/L in plasma
Durak et al. 1999 | 61 adults, aged 25–81 years | Total | 0.55 | 0.31 | 77.4 | nmol/g tissue

* 8-OH-dG = 8-hydroxydeoxyguanosine.

† LDL = Low-density lipoprotein.

Oxidative damage to proteins can occur in both amino acid residues and the peptide backbone in protein, and can be assessed by assaying protein carbonyls (Reznick et al. 1992; Eiserich et al. 1995). Studies document that exposing human plasma (Reznick et al. 1992; Eiserich et al. 1995; Panda et al. 1999) or saliva (Nagler et al. 2000) to cigarette smoke increased protein carbonyl concentrations by more than 300 percent. Compared with unexposed guinea pigs, guinea pigs exposed to cigarette smoke had plasma protein carbonyl concentrations more than 30 times greater (Panda et al. 2000). In humans, protein carbonyl concentrations in 15 smokers were 61 percent higher than in 5 comparison nonsmokers (Lee et al. 1998).

Isoprostanes constitute a specific measure of lipid peroxidation and serve as good general markers of oxidative injury (Morrow and Roberts 1996). Free radicals catalyze the peroxidation of arachidonic acid to F2-isoprostanes (Morrow and Roberts 1996). Circulating (Morrow et al. 1995) and urinary (Morrow et al. 1995; Reilly et al. 1996) isoprostane levels have been shown to be markedly higher in smokers than in non-smokers (Table 6.2). Circulating (Morrow et al. 1995; Pilz et al. 2000) and urinary (Reilly et al. 1996; Pilz et al. 2000) isoprostane concentrations decreased at least 20 percent within two weeks of smoking cessation. Babies of smoking mothers had concentrations of isoprostane levels in their umbilical arteries and veins more than 110 percent higher than babies of nonsmoking mothers (Obwegeser et al. 1999).

Another widely used measure of free radical catalyzed lipid peroxidation is thiobarbituric acid reactive substances (TBARS) (Bonithon-Kopp et al. 1997). Comparisons of TBARS between smokers and nonsmokers have shown that (1) current smokers have higher TBARS levels—sometimes strikingly higher, (2) levels of TBARS rise after smoking, and (3) the influence of smoking on increased lipid peroxidation can be offset somewhat by administering the antioxidant micronutrients vitamins C and E (Table 6.2).

#### Antioxidant Depletion

Even as smokers are exposed to the oxidative stress of regularly inhaling cigarette smoke, substantial evidence shows that blood levels of individual antioxidant micronutrients are lower in current smokers than in nonsmokers. This association has been clearly demonstrated for vitamin C (McClean et al. 1976; Bolton-Smith et al. 1991; Ross et al. 1995; Lykkesfeldt et al. 1997) and for total and selected carotenoids including α-carotene, β-carotene, and cryptoxanthin (Aoki et al. 1987; Stryker et al. 1988; Bolton-Smith et al. 1991; Pamuk et al. 1994; Ross et al. 1995; Brady et al. 1996; Alberg et al. 2000). For vitamin C (Brook and Grimshaw 1968; Buiatti et al. 1996; Marangon et al. 1998) and several of the specific carotenoids (Comstock et al. 1988; Nierenberg et al. 1989; Buiatti et al. 1996; Marangon et al. 1998), circulating concentrations tend to decline with increasing number of cigarettes smoked.

Whether the differences in antioxidant levels across smoking categories reflect direct depletion or differing dietary intake has been controversial. If smoking directly depletes antioxidant micronutrients, the effect would presumably be acute. In fact, levels of vitamin C and selected carotenoids increased when measured in persons after 84 hours without smoking a cigarette (Brown 1996), and an experimental exposure of plasma equivalent to six puffs of cigarette smoke completely depleted the ascorbic acid present in the serum (Handelman et al. 1991; Eiserich et al. 1995). When measurements were taken at baseline and 20 minutes after smoking a cigarette, decreases in circulating micronutrient concentrations were observed (Yeung 1976).

#### Smoking and the Leukocyte Count

Studies show that smokers when compared with nonsmokers have generally heightened inflammation, increased white blood cell counts that remain elevated after cessation, and increased levels of other markers of inflammation such as C-reactive protein (Allen et al. 1985; Das 1985; de Maat et al. 1996; Tracy et al. 1997; Danesh et al. 1999).

The association between smoking and the leukocyte count has been extensively investigated, with numerous studies showing that current smokers have higher leukocyte counts than nonsmokers (Table 6.3). In most studies, the increase was 20 percent or more in smokers compared with nonsmokers and was present across strata of age, gender, and race. The leukocyte count increases with the number of cigarettes smoked per day and with the depth of inhalation. Similar dose-response trends were evident in other studies that did not lend themselves to inclusion in the summary tables (Petitti and Kipp 1986; Schwartz and Weiss 1991). Dose-response trends tend to be weaker when examined in relation to either pack-years^1^ or duration of smoking, suggesting that smoking has an immediate effect on the leukocyte count.

1 Pack-years = The number of years of smoking multiplied by the number of packs of cigarettes smoked per day.

Table 6.3 Studies on the association between current smoking and white blood cell counts

Study | Population | Group | Results (white blood cell counts) | | | Comments
Study | Population | Group | Smokers | Nonsmokers | Percentage difference | Comments
Howell 1970 | 2,483 men, aged 40–54 years | Total | 7,257 | 5,818 | 24.7 | Per mm^3^ of blood
Corre et al. 1971 | 4,264 men, aged 46–52 years | Total | 6,549 | 5,705 | 14.8 | Per mm^3^ of blood
Friedman et al. 1973 | 86,488 Kaiser Permanente enrollees | Men | 8.2 | 7.1 | 15.5 | 10^−3^ per mm^3^ of blood; weighted averages
Friedman et al. 1973 | 86,488 Kaiser Permanente enrollees | Women | 8.3 | 7.3 | 13.7 | 10^−3^ per mm^3^ of blood; weighted averages
Okuno 1973 | 106 men, aged 20–39 years | Total | 6,719 | 5,440 | 23.5 | Per mm^3^ of blood; weighted average for smokers
Parulkar et al. 1973 | 130 Indian men, aged 16–60 years | Total | 8,868 | 6,369 | 39.2 | Per mm^3^ of blood
Billimoria et al. 1975 | 121 men and women | Men | 8.0 | 5.5 | 45.5 | 10^−3^ per mm^3^ of blood
Billimoria et al. 1975 | 121 men and women | Women | 7.0 | 5.8 | 20.7 | 10^−3^ per mm^3^ of blood
Fisch and Freedman 1975 | 14,961 women, aged 18–60 years | Total | 7.59 | 6.26 | 21.2 | 10^−3^ per mm^3^ of blood; weighted averages
Helman and Rubenstein 1975 | 800 healthy patients, aged 20–69 years | Men | 8.7 | 7.1 | 22.5 | 10^−3^ per mm^3^ of blood; weighted average
Helman and Rubenstein 1975 | 800 healthy patients, aged 20–69 years | Women | 8.8 | 7.1 | 23.9 | 10^−3^ per mm^3^ of blood; weighted average
Noble and Penny 1975 | 40 male medical students, aged 20–30 years | Total | 7,625 | 5,934 | 28.5 | Per mm^3^ of blood
Parulkar et al. 1975 | 379 Indian men, aged 20–60 years | Total | 9,782 | 7,299 | 34.0 | Per mm^3^ of blood
Silverman et al. 1975 | 263 persons, aged 20–78 years | Total | 6,803 | 6,023 | 13.0 | Per mm^3^ of blood
Tibblin et al. 1979 | 1,462 women, aged 38–60 years | Total | 6.1 | 4.9 | 24.5 | 10^−3^ per mm^3^ of blood; weighted average for smokers
Dodsworth et al. 1981 | 737 men and women, aged 18–64 years | Men | 7.2 | 6.1 | 14.8 | 10^−3^ per mm^3^ of blood
Dodsworth et al. 1981 | 737 men and women, aged 18–64 years | Women | 7.2 | 6.5 | 10.8 | 10^−3^ per mm^3^ of blood
Zalokar et al. 1981 | 7,206 men, aged 43–53 years, France | Total | 5,740 | 7,280 | 26.8 | 10^−3^ per mm^3^ of blood
Heinemann et al. 1982 | 30 male students | Total | 7.85 | 6.95 | 12.9 | 10^−3^ per mm^3^ of blood
Mellstrom et al. 1982 | 449 men, aged 70 years, Goteberg, Sweden | Total | 6.3 | 5.3 | 18.9 | 10^−3^ per mm^3^ of blood
Nancy et al. 1982 | 100 male smokers, 100 male nonsmokers | Total | 9,156 | 7,310 | 25.3 | Per mm^3^ of blood
Chan-Yeung et al. 1984 | 2 cohorts of men (652 cedar mill workers, 440 office workers), British Columbia | Powell River | 8.4 | 6.7 | 25.4 | 10^−3^ per mm^3^ of blood; weighted averages
Chan-Yeung et al. 1984 | 2 cohorts of men (652 cedar mill workers, 440 office workers), British Columbia | Kitimat | 7.6 | 6.2 | 22.6 | 10^−3^ per mm^3^ of blood; weighted averages
Sparrow et al. 1984 | 1,510 men, aged 23–80 years | Total | 8,400 | 6,830 | 23.0 | Per mm^3^ of blood; weighted average for smokers
Vanuxem et al. 1984 | 43 persons, France | Total | 8.0 | 5.8 | 37.9 | 10^−3^ per mm^3^ of blood
Carel and Eviatar 1985 | 35,000 Israelis, aged 20–80 years | Men | 8.2 | 7.2 | 13.9 | 10^−3^ per mm^3^ of blood
Carel and Eviatar 1985 | 35,000 Israelis, aged 20–80 years | Women | 7.9 | 7.1 | 11.3
Nielsen 1985 | 82 healthy persons, aged 21–74 years | Total | 7.6 | 5.9 | 28.8 | 10^−3^ per mm^3^ of blood
Husgafvel-Pursiainen 1987 | 70 persons, mean age 38 years | Total | 9.3 | 6.8 | 36.8 | 10^−3^ per mm^3^ of blood; weighted average for smokers
Yarnell et al. 1987 | 4,445 men, aged 45–59 years, from 2 communities in the United Kingdom | Caerphilly | 8.0 | 5.9 | 35.6 | 10^−3^ per mm^3^ of blood; weighted average for smokers
Yarnell et al. 1987 | 4,445 men, aged 45–59 years, from 2 communities in the United Kingdom | Speedwell | 8.2 | 6.0 | 36.7 | 10^−3^ per mm^3^ of blood; weighted average for smokers
Chan-Yeung et al. 1988 | 750 male aluminum smelter workers | Total | 7,560 | 6,113 | 2.37 | Per mm^3^ of blood; weighted average for smokers
Hansen et al. 1990b | 12,866 men, aged 35–37 years | Total | 7,553 | 6,094 | 28.9 | Per mm^3^ of blood
Olsen et al. 1991 | 1,900 Dow Chemical Company employees | Men | 8,290 | 6,340 | 30.8 | Per mm^3^ of blood
Olsen et al. 1991 | 1,900 Dow Chemical Company employees | Women | 7,790 | 6,460 | 20.6 | Per mm^3^ of blood
Casasnovas et al. 1992 | 572 military academy cadets, mean age 19 years | Total | 8,194 | 7,332 | 11.8 | Per mm^3^ of blood
Mühlhauser et al. 1993 | 288 patients with diabetes | Men | 8.1 | 6.4 | 26.6 | 10^−3^ per mm^3^ of blood
Mühlhauser et al. 1993 | 288 patients with diabetes | Women | 7.6 | 6.8 | 11.8 | 10^−3^ per mm^3^ of blood
Mercelina-Roumans et al. 1994 | 712 pregnant women | Total | 10.7 | 9.1 | 17.6 | 10^−3^ per mm^3^ of blood
Hogarty et al. 1995 | 6,837 men and women, mean age 58 years | Men | 7.0 | 6.2 | 11.4 | 10^−3^ per mm^3^ of blood; smokers included all ever smokers
Hogarty et al. 1995 | 6,837 men and women, mean age 58 years | Women | 6.8 | 6.4 | 6.3 | 10^−3^ per mm^3^ of blood; smokers included all ever smokers
Bovill et al. 1996 | 5,201 persons, aged >64 years | Men | 7.6 | 6.3 | 20.6 | 10^9^ per liter of blood
Bovill et al. 1996 | 5,201 persons, aged >64 years | Women | 7.3 | 6.1 | 19.7 | 10^9^ per liter of blood
Calori et al. 1996 | 27 monozygotic twin pairs discordant for smoking | Total | 6.2 | 5.2 | 8.4 | 10^3^ per μL of blood
Jensen et al. 1998 | 434 persons | Total | 7.6 | 5.8 | 31.0 | 10^−3^ per mm^3^ of blood

The findings from former smokers are consistent with both an immediate and a persistent effect of smoking. In comparisons with lifetime nonsmokers (Table 6.4), former smokers consistently have higher white blood cell counts, but the difference is smaller than that between current smokers and lifetime nonsmokers. In most of the studies, the leukocyte counts for former smokers were only about 5 percent greater than those for lifetime nonsmokers. The excess is persistent (Petitti and Kipp 1986; Schwartz and Weiss 1991; Sunyer et al. 1996), although it decreases with increasing duration of cessation, becoming closer to the average counts found in lifetime nonsmokers (Yarnell et al. 1987; Hansen et al. 1990b). A short-term (overnight) abstention from cigarettes did not strongly influence the counts (Noble and Penny 1975).

Table 6.4 Studies on the association between former smoking and white blood cell counts

Study | Population | Group | Results (white blood cell counts) | | | Comments
Study | Population | Group | Former smokers | Never smokers | Percentage difference | Comments
Friedman et al. 1973 | 86,488 Kaiser Permanente enrollees | Men: 38,279 | 7.3 | 7.1 | 2.8 | 10^−3^ per mm^3^ of blood; weighted averages
Friedman et al. 1973 | 86,488 Kaiser Permanente enrollees | Women: 48,207 | 7.7 | 7.3 | 5.5 | 10^−3^ per mm^3^ of blood; weighted averages
Tibblin et al. 1979 | 1,462 women, aged 38–60 years | Total | 5.1 | 4.9 | 4.1 | 10^−3^ per mm^3^ of blood
Zalokar et al. 1981 | 7,206 men, aged 43–53 years, France | Total | 5,840 | 7,280 | 1.7 | Per mm^3^ of blood
Mellstrom et al. 1982 | 449 men, aged 70 years, Goteberg, Sweden | Total | 5.8 | 5.3 | 9.3 | 10^−3^ per mm^3^ of blood
Chan-Yeung et al. 1984 | 2 male cohorts, British Columbia | 652 cedar mill workers | 6.8 | 6.7 | 1.5 | 10^−3^ per mm^3^ of blood; weighted averages
Chan-Yeung et al. 1984 | 2 male cohorts, British Columbia | 440 office workers | 6.3 | 6.2 | 1.6 | 10^−3^ per mm^3^ of blood; weighted averages
Sparrow et al. 1984 | 1,510 men, aged 23–80 years | Total | 6,900 | 6,830 | 1.0 | Per mm^3^ of blood
Knoke et al. 1987 | 2,225 white men with high cholesterol | Total | 5,558 | 5,355 | 3.8 | Per mm^3^ of blood
Yarnell et al. 1987 | 4,445 men, aged 45–59 years, in 2 communities | Quit <1 year | 6.96 | 5.95 | 17.0 | 10^−3^ per mm^3^ of blood; weighted averages
Yarnell et al. 1987 | 4,445 men, aged 45–59 years, in 2 communities | Quit 1–4 years | 6.64 | 5.95 | 11.6 | 10^−3^ per mm^3^ of blood; weighted averages
Yarnell et al. 1987 | 4,445 men, aged 45–59 years, in 2 communities | Quit 5–9 years | 6.38 | 5.95 | 7.2 | 10^−3^ per mm^3^ of blood; weighted averages
Yarnell et al. 1987 | 4,445 men, aged 45–59 years, in 2 communities | Quit ≥10 years | 6.15 | 5.95 | 3.4 | 10^−3^ per mm^3^ of blood; weighted averages
Chan-Yeung et al. 1988 | 750 male aluminum smelter employees | Total | 6,302 | 6,113 | 3.1 | Per mm^3^ of blood
Hansen et al. 1990b | 12,866 men, aged 35–37 years | Quit 1–2 years | 6,371 | 6,094 | 4.5 | Per mm^3^ of blood
Hansen et al. 1990b | 12,866 men, aged 35–37 years | Quit 2–3 years | 6,343 | 6,094 | 4.1 | Per mm^3^ of blood
Hansen et al. 1990b | 12,866 men, aged 35–37 years | Quit 3–5 years | 6,297 | 6,094 | 3.3 | Per mm^3^ of blood
Hansen et al. 1990b | 12,866 men, aged 35–37 years | Quit 5–10 years | 6,285 | 6,094 | 3.1 | Per mm^3^ of blood
Hansen et al. 1990b | 12,866 men, aged 35–37 years | Quit ≥10 years | 6,212 | 6,094 | 1.9 | Per mm^3^ of blood
Olsen et al. 1991 | 1,900 Dow Chemical Company employees | Men | 6,650 | 6,340 | 4.9 | Per mm^3^ of blood
Olsen et al. 1991 | 1,900 Dow Chemical Company employees | Women | 7,110 | 6,460 | 10.1 | Per mm^3^ of blood
Sunyer et al. 1996 | 2,435 patients, aged >18 years | Total | 6,501 | 6,265 | 3.8 | Per mm^3^ of blood

Prospective cohort studies have tracked changes in leukocyte counts in relation to changes in smoking. In a study of Kaiser Permanente enrollees in the San Francisco Bay area, the leukocyte counts increased 12 percent among those who started smoking during the follow-up, but it decreased 7 percent among smokers who had quit during the follow-up (Friedman et al. 1973). In a subsequent study that compared leukocyte counts of 9,392 persistent smokers with those of 3,825 smokers who had quit, the quitters experienced significantly higher declines (Friedman and Siegelaub 1980). In a cohort of homosexual men seronegative for human immunodeficiency virus (HIV), Sunyer and colleagues (1996) observed that decreases in smoking were followed by decreased white blood cell counts, and increases in smoking were followed by increased white blood cell counts. Furthermore, changes in white blood cell counts were proportional to changes in smoking patterns (Table 6.5).

Table 6.5 Studies on the percentage difference in white blood cell counts stratified by smoking patterns

Study | Population | Measure of dose | Group | Percentage difference | | | | | | | Comments
Study | Population | Measure of dose | Group | Nonsmokers (referent) | Smokers, by category of dose (1 = low) | | | | | | Comments
Study | Population | Measure of dose | Group | Nonsmokers (referent) | 1 | 2 | 3 | 4 | 5 | 6 | Comments
Howell 1970 | 2,483 men, aged 40–54 years | Number of cigarettes/day | Total | 0 | 22.0 | 30.1 | NR^*^ | NR | NR | NR | None
Corre et al. 1971 | 4,264 men, aged 46–52 years | Inhalation^†^ | Total | 0 | 6.3 | 23.5 | NR | NR | NR | NR | None
Corre et al. 1971 | 4,264 men, aged 46–52 years | Number of cigarettes/day | Noninhalers^‡^ | 0 | 1.7 | 7.4 | 9.8 | 10.0 | NR | NR | None
Corre et al. 1971 | 4,264 men, aged 46–52 years | Number of cigarettes/day | Inhalers | 0 | 10.8 | 21.5 | 27.7 | 29.7 | NR | NR | None
Okuno 1973 | 106 men, aged 20–39 years | Number of cigarettes/day | Total | 0 | 18.9 | 37.9 | NR | NR | NR | NR
Fisch and Freedman 1975 | 14,961 women, aged 18–60 years | Number of cigarettes/day | Total | 0 | 10.9 | 28.1 | NR | NR | NR | NR | Weighted averages
Parulkar et al. 1975 | 379 Indian men, aged 20–60 years | Inhalation | Total | 0 | 31.5 | 36.8 | NR | NR | NR | NR | None
Parulkar et al. 1975 | 379 Indian men, aged 20–60 years | Duration of smoking | Total | 0 | 31.5 | 34.9 | 35.5 | 38.4 | NR | NR | None
Parulkar et al. 1975 | 379 Indian men, aged 20–60 years | Number of cigarettes/day | Total | 0 | 28.1 | 28.1 | 40.1 | 38.9 | NR | NR | None
Silverman et al. 1975 | 268 persons, aged 20–78 years | Pack-years^§^ | Total | 0 | 6.5 | 12.9 | 16.9 | 14.2 | 11.2 | 27.2 | None
Tibblin et al. 1979 | 1,462 women, aged 38–60 years | Number of cigarettes/day | Total | 0 | 8.2 | 24.5 | 24.5 | 34.7 | 38.8 | NR | None
Dodsworth et al. 1981 | 737 men and women, aged 18–64 years | Number of cigarettes/day | Men | 0 | 12.9 | 1.6 | 17.7 | 14.5 | 29.0 | NR | None
Dodsworth et al. 1981 | 737 men and women, aged 18–64 years | Number of cigarettes/day | Women | 0 | 4.9 | 3.3 | 13.1 | 16.4 | 31.1 | NR | None
Zalokar et al. 1981 | 7,206 French men, aged 43–53 years | Inhalation | Total | 0 | 6.5 | 26.8 | NR | NR | NR | NR | None
Zalokar et al. 1981 | 7,206 French men, aged 43–53 years | Number of cigarettes/day | Total | NR | 12.5 | 24.6 | 29.3 | 33.6 | NR | NR | None
Sparrow et al. 1984 | 1,510 men, aged 23–80 years | Number of cigarettes/day | Total | 0 | 19.4 | 29.2 | NR | NR | NR | NR | None
Tell et al. 1985 | 439 Norwegians, aged 14–16 years | Number of cigarettes/day | Males | 0 | 5.8 | 13.5 | NR | NR | NR | NR | None
Tell et al. 1985 | 439 Norwegians, aged 14–16 years | Number of cigarettes/day | Females | 0 | −3.8 | 16.4 | NR | NR | NR | NR | None
Petitti and Kipp 1986 | 63,041 enrollees in Kaiser Permanente | Number of cigarettes/day | White men | 0 | 10.4 | 17.9 | 25.4 | 23.9 | 31.3 | NR | None
Petitti and Kipp 1986 | 63,041 enrollees in Kaiser Permanente | Number of cigarettes/day | White women | 0 | 8.5 | 15.5 | 21.1 | 22.5 | 19.7 | NR | None
Petitti and Kipp 1986 | 63,041 enrollees in Kaiser Permanente | Number of cigarettes/day | Black men | 0 | 10.0 | 13.3 | 21.7 | 18.3 | 18.3 | NR | None
Petitti and Kipp 1986 | 63,041 enrollees in Kaiser Permanente | Number of cigarettes/day | Black women | 0 | 4.5 | 10.4 | 13.4 | 16.4 | 10.4 | NR | None
Husgafvel-Pursiainen 1987 | 70 persons, mean age 38 years | Number of cigarettes/day | Total | 0 | 47.1 | 33.8 | NR | NR | NR | NR | None
Knoke et al. 1987 | 2,225 white men with high cholesterol | Number of cigarettes/day | Total | 0 | 21.9 | 36.8 | 46.6 | 49.0 | 54.9 | NR | None
Yarnell et al. 1987 | 4,445 men, aged 45–59 years, in 2 communities | Number of cigarettes/day | Caerphilly | 0 | 30.4 | 37.2 | 40.1 | NR | NR | NR | None
Yarnell et al. 1987 | 4,445 men, aged 45–59 years, in 2 communities | Number of cigarettes/day | Speedwell | 0 | 33.4 | 36.4 | 41.8 | NR | NR | NR | None
Chang-Yeung et al. 1988 | 750 male aluminum smelter workers | Number of cigarettes/day | Total | 0 | 17.7 | 24.7 | 28.7 | NR | NR | NR | None
Hansen et al. 1990b | 12,866 men, aged 35–37 years | Number of cigarettes/day Inhalation^†^ | Total | 0 | 11.2 | 22.1 | 25.5 | 28.2 | 30.7 | NR | None
Hansen et al. 1990b | 12,866 men, aged 35–37 years | Number of cigarettes/day Inhalation^†^ | Total | 0 | 12.5 | 18.6 | 19.7 | 23.9 | 27.0 | NR | None
Olsen et al. 1991 | 1,900 Dow Chemical Company employees | Number of cigarettes/day | Men | 0 | 11.8 | 32.0 | 45.6 | NR | NR | NR | None
Olsen et al. 1991 | 1,900 Dow Chemical Company employees | Number of cigarettes/day | Women | 0 | 2.2 | 23.8 | 34.4 | NR | NR | NR | None
Olsen et al. 1991 | 1,900 Dow Chemical Company employees | Pack-years^§^ | Men | 0 | 13.9 | 26.3 | 32.3 | 42.4 | NR | NR | None
Olsen et al. 1991 | 1,900 Dow Chemical Company employees | Pack-years^§^ | Women | 0 | 3.1 | 29.4 | 24.1 | 34.5 | NR | NR | None
Sunyer et al. 1996 | 2,435 patients, aged >18 years | Number of cigarettes/day | Total | 0 | 2.4 | 13.5 | 26.4 | 32.1 | NR | NR | None
Jensen et al. 1998 | 434 (298 smokers, 136 nonsmokers) | Number of cigarettes/day | Total | 0 | 31.0 | 46.6 | NR | NR | NR | NR | None

* NR = Data were not reported.

† Inhalation = Inhaling cigarette smoke.

‡ Noninhalers = Not inhaling cigarette smoke.

§ Pack-years = The number of years of smoking multiplied by the number of packs of cigarettes smoked per day.

These observations of inflammatory markers, particularly the leukocyte counts, are consistent with the induction of systemic chronic inflammation in smokers, perhaps reflecting the substantial oxidant load from habitual cigarette smoking. Studies of former smokers suggest that this state of inflammation does not simply reflect an acute effect. These observations support one of the mechanisms, oxidative stress, proposed as contributing to the general effects of smoking on health.

### Epidemiologic Evidence

#### Absenteeism

Absenteeism from work is frequent and costly (Steers and Rhodes 1978); its multiple causes include individual and organizational factors (Steers and Rhodes 1978). Researchers investigating the effect of smoking on absenteeism face the challenges of controlling for potential confounding by individual-level factors such as alcoholism, and specifying how smoking could act in combination with other factors at both individual and group levels. While the literature is extensive (Table 6.6), the studies vary in the success with which these challenges have been met, partially reflecting the extent and quality of available data.

Table 6.6 Studies on the association between current smoking and absenteeism

Study | Population | Group | Results | | | Comments
Study | Population | Group | Smokers | Nonsmokers | Percentage difference | Comments
Lowe 1960 | 3,341 male General Electric Company employees, England | | Number of days absent during the year | | | None
Lowe 1960 | 3,341 male General Electric Company employees, England | Total | 11.19 | 9.81 | 4.1 | None
Lowe 1960 | 3,341 male General Electric Company employees, England | Medical reasons | 6.59 | 5.49 | 20.0 | None
Lowe 1960 | 3,341 male General Electric Company employees, England | Other reasons | 4.61 | 4.32 | 6.7 | None
Holcomb and Meigs 1972 | 226 male factory employees | Total | Total days lost per person-year | | | Short-term: <7 days (unverified medical absences) Long-term: ≥10 days (verified medical absences) during 1956–1964
Holcomb and Meigs 1972 | 226 male factory employees | Total | 6.37 | 4.42 | 44.1 | Short-term: <7 days (unverified medical absences) Long-term: ≥10 days (verified medical absences) during 1956–1964
Holcomb and Meigs 1972 | 226 male factory employees | Total | Absence rate: short-term | | | Short-term: <7 days (unverified medical absences) Long-term: ≥10 days (verified medical absences) during 1956–1964
Holcomb and Meigs 1972 | 226 male factory employees | Total | 0.96 | 0.38 | 152.6 | Short-term: <7 days (unverified medical absences) Long-term: ≥10 days (verified medical absences) during 1956–1964
Holcomb and Meigs 1972 | 226 male factory employees | Total | Days lost: short-term | | | Short-term: <7 days (unverified medical absences) Long-term: ≥10 days (verified medical absences) during 1956–1964
Holcomb and Meigs 1972 | 226 male factory employees | Total | 1.89 | 0.95 | 98.9 | Short-term: <7 days (unverified medical absences) Long-term: ≥10 days (verified medical absences) during 1956–1964
Holcomb and Meigs 1972 | 226 male factory employees | Total | Absence rate: long-term | | | Short-term: <7 days (unverified medical absences) Long-term: ≥10 days (verified medical absences) during 1956–1964
Holcomb and Meigs 1972 | 226 male factory employees | Total | 0.10 | 0.07 | 42.9 | Short-term: <7 days (unverified medical absences) Long-term: ≥10 days (verified medical absences) during 1956–1964
Holcomb and Meigs 1972 | 226 male factory employees | Total | Days lost: long-term | | | Short-term: <7 days (unverified medical absences) Long-term: ≥10 days (verified medical absences) during 1956–1964
Holcomb and Meigs 1972 | 226 male factory employees | Total | 4.48 | 3.47 | 29.1 | Short-term: <7 days (unverified medical absences) Long-term: ≥10 days (verified medical absences) during 1956–1964
Wilson 1973 | 1970 National Health Interview Survey, persons aged ≥17 years | | Mean workdays lost per year | | | None
Wilson 1973 | 1970 National Health Interview Survey, persons aged ≥17 years | Total | 6.3 | 4.4 | 43.2 | None
Wilson 1973 | 1970 National Health Interview Survey, persons aged ≥17 years | Men | 5.8 | 3.7 | 56.8 | None
Wilson 1973 | 1970 National Health Interview Survey, persons aged ≥17 years | Women | 7.4 | 5.1 | 45.1 | None
Wilson 1973 | 1970 National Health Interview Survey, persons aged ≥17 years | 17–44 years | 5.8 | 3.8 | 52.6 | None
Wilson 1973 | 1970 National Health Interview Survey, persons aged ≥17 years | 45–64 years | 7.2 | 5.7 | 26.3 | None
Wilson 1973 | 1970 National Health Interview Survey, persons aged ≥17 years | ≥65 years | 7.7 | 4.3 | 79.1 | None
Athanasou 1979 | 424 persons, aged 15–67 years | | Duration of sickness absence (days) | | | Nonsmokers included never smokers plus former smokers
Athanasou 1979 | 424 persons, aged 15–67 years | Men | 1.15 | 0.68 | 69.1 | Nonsmokers included never smokers plus former smokers
Athanasou 1979 | 424 persons, aged 15–67 years | Women | 1.05 | 1.03 | 1.9 | Nonsmokers included never smokers plus former smokers
U.S. Department of Health and Human Services 1980 | Representative sample of U.S. population aged ≥17 years | | Workdays lost per year due to illness and injury per currently employed persons | | | None
U.S. Department of Health and Human Services 1980 | Representative sample of U.S. population aged ≥17 years | 1965 | | | | None
U.S. Department of Health and Human Services 1980 | Representative sample of U.S. population aged ≥17 years | Men | 5.9 | 4.6 | 28.3 | None
U.S. Department of Health and Human Services 1980 | Representative sample of U.S. population aged ≥17 years | Women | 6.6 | 4.8 | 37.5 | None
U.S. Department of Health and Human Services 1980 | Representative sample of U.S. population aged ≥17 years | 1977 | | | | None
U.S. Department of Health and Human Services 1980 | Representative sample of U.S. population aged ≥17 years | Men | 5.9 | 4.2 | 40.5 | None
U.S. Department of Health and Human Services 1980 | Representative sample of U.S. population aged ≥17 years | Women | 6.6 | 5.7 | 15.8 | None
Janzon et al. 1981 | 1,037 Swedish men, aged 47–48 years | | Percent who used sick leave >3 times during the past year | | | None
Janzon et al. 1981 | 1,037 Swedish men, aged 47–48 years | Total | 13 | 4 | 225.0 | None
Smith et al. 1981 | 826 staff members from 12 Australian organizations | | Mean number of days off work | | | Ratio of days off work for smokers compared with nonsmokers
Smith et al. 1981 | 826 staff members from 12 Australian organizations | Men | 1.59 | 1.0 | 59.0 | Ratio of days off work for smokers compared with nonsmokers
Smith et al. 1981 | 826 staff members from 12 Australian organizations | Women | 1.36 | 1.0 | 36.0 | Ratio of days off work for smokers compared with nonsmokers
Leigh 1983 | 1,200 participants in the 1973 Quality of Employment survey, based on a nation-wide probability sample | | Mean number of absences during the past 2 weeks | | | OR^*^
Leigh 1983 | 1,200 participants in the 1973 Quality of Employment survey, based on a nation-wide probability sample | Men | 1.07 | 1.0 | 7.0 | OR^*^
Leigh 1983 | 1,200 participants in the 1973 Quality of Employment survey, based on a nation-wide probability sample | White collar | 0.72 | 1.0 | −28.0 | OR^*^
Leigh 1983 | 1,200 participants in the 1973 Quality of Employment survey, based on a nation-wide probability sample | Blue collar | 1.50 | 1.0 | 50.0 | OR^*^
Leigh 1983 | 1,200 participants in the 1973 Quality of Employment survey, based on a nation-wide probability sample | Women | 1.89 | 1.0 | 89.0 | OR^*^
Leigh 1983 | 1,200 participants in the 1973 Quality of Employment survey, based on a nation-wide probability sample | White collar | 1.23 | 1.0 | 23.0 | OR^*^
Leigh 1983 | 1,200 participants in the 1973 Quality of Employment survey, based on a nation-wide probability sample | Blue collar | 2.19 | 1.0 | 119.0 | OR^*^
Parkes 1983 | 221 nursing students, aged 18–25 years | | Mean number of absences during 6 months | | | None
Parkes 1983 | 221 nursing students, aged 18–25 years | Total | 3.46 | 1.95 | 77.4 | None
Andersson and Malmgren 1986 | 1,313 Saab employees, aged 50–59 years, Sweden | | Mean number of days absent | | | Nonsmokers included never smokers plus former smokers
Andersson and Malmgren 1986 | 1,313 Saab employees, aged 50–59 years, Sweden | Wage earners | 26 | 24 | 8.3 | Nonsmokers included never smokers plus former smokers
Andersson and Malmgren 1986 | 1,313 Saab employees, aged 50–59 years, Sweden | Salaried | 20 | 16 | 25.0 | Nonsmokers included never smokers plus former smokers
Van Tuinen and Land 1986 | 406 Missouri Department of Health employees | | Mean hours of sick leave per month | | | None
Van Tuinen and Land 1986 | 406 Missouri Department of Health employees | Total | 5.0 | 4.3 | 16.3 | None
Van Tuinen and Land 1986 | 406 Missouri Department of Health employees | Men | 4.5 | 3.7 | 21.6 | None
Van Tuinen and Land 1986 | 406 Missouri Department of Health employees | Women | 5.4 | 4.7 | 14.9 | None
Hendrix and Taylor 1987 | 463 U.S. Department of Defense employees | | Average number of sick days in the past 6 months | | | None
Hendrix and Taylor 1987 | 463 U.S. Department of Defense employees | Total | 3.2 | 2.9 | 10.3 | None
Blake et al. 1988 | 1,230 army recruits in basic training | | Mean time spent in the clinic for visits related to upper respiratory infections (hours) | | | Not absenteeism per se; military conditions controlled confounding
Blake et al. 1988 | 1,230 army recruits in basic training | Total | 30.6 | 17.3 | 76.9 | Not absenteeism per se; military conditions controlled confounding
Hawker 1988 | 252 female student nurses | | Percent absent >7 days (yes/no) | | | Nonsmokers included never smokers plus former smokers
Hawker 1988 | 252 female student nurses | Total | 37.5 | 15.0 | 150.0 | Nonsmokers included never smokers plus former smokers
Dimberg et al. 1989 | 2,814 Volvo employees, Sweden | | Average days lost in 1 year | | | None
Dimberg et al. 1989 | 2,814 Volvo employees, Sweden | Total | 21 | 14 | 50.0 | None
Gallop 1989 | 169 pulp and paper industrial company employees | | Mean illness absences last year | | | Payroll records were used to verify self-reported records
Gallop 1989 | 169 pulp and paper industrial company employees | Self-reported records (n = 82) | 5.1 | 4.1 | 24.4 | Payroll records were used to verify self-reported records
Gallop 1989 | 169 pulp and paper industrial company employees | Payroll records | 10.3 | 7.9 | 30.4 | Payroll records were used to verify self-reported records
Manning et al. 1989 | 324 employees of 2 companies, aged 20–75 years | Baseline | Mean hours absent per month | | | Short-term: ≤2 days Long-term: >2 days
Manning et al. 1989 | 324 employees of 2 companies, aged 20–75 years | Short-term | 2.15 | 1.69 | 27.2 | Short-term: ≤2 days Long-term: >2 days
Manning et al. 1989 | 324 employees of 2 companies, aged 20–75 years | Long-term | 1.44 | 0.78 | 84.6 | Short-term: ≤2 days Long-term: >2 days
Manning et al. 1989 | 324 employees of 2 companies, aged 20–75 years | 1-year follow-up | | | | Short-term: ≤2 days Long-term: >2 days
Manning et al. 1989 | 324 employees of 2 companies, aged 20–75 years | Short-term | 1.73 | 1.17 | 47.9 | Short-term: ≤2 days Long-term: >2 days
Manning et al. 1989 | 324 employees of 2 companies, aged 20–75 years | Long-term | 1.85 | 1.67 | 10.8 | Short-term: ≤2 days Long-term: >2 days
Batenburg and Reinken 1990 | 907 employees from 4 worksites, employed at least 12 months | Men by age | Sickness absence hours | | | Authors noted that male nonsmokers aged ≥50 years had medical conditions predisposing them to absenteeism
Batenburg and Reinken 1990 | 907 employees from 4 worksites, employed at least 12 months | Total | 3.9 | 3.5 | 11.4 | Authors noted that male nonsmokers aged ≥50 years had medical conditions predisposing them to absenteeism
Batenburg and Reinken 1990 | 907 employees from 4 worksites, employed at least 12 months | <20 years | 3.7 | 3.4 | 8.8 | Authors noted that male nonsmokers aged ≥50 years had medical conditions predisposing them to absenteeism
Batenburg and Reinken 1990 | 907 employees from 4 worksites, employed at least 12 months | 20–29 years | 4.0 | 3.6 | 11.1 | Authors noted that male nonsmokers aged ≥50 years had medical conditions predisposing them to absenteeism
Batenburg and Reinken 1990 | 907 employees from 4 worksites, employed at least 12 months | 30–39 years | 4.0 | 3.3 | 21.2 | Authors noted that male nonsmokers aged ≥50 years had medical conditions predisposing them to absenteeism
Batenburg and Reinken 1990 | 907 employees from 4 worksites, employed at least 12 months | 40–49 years | 3.6 | 2.9 | 24.1 | Authors noted that male nonsmokers aged ≥50 years had medical conditions predisposing them to absenteeism
Batenburg and Reinken 1990 | 907 employees from 4 worksites, employed at least 12 months | ≥50 years | 3.9 | 4.5 | −13.3 | Authors noted that male nonsmokers aged ≥50 years had medical conditions predisposing them to absenteeism
Batenburg and Reinken 1990 | 907 employees from 4 worksites, employed at least 12 months | Women by age | | | | Authors noted that male nonsmokers aged ≥50 years had medical conditions predisposing them to absenteeism
Batenburg and Reinken 1990 | 907 employees from 4 worksites, employed at least 12 months | Total | 3.6 | 3.1 | 16.1 | Authors noted that male nonsmokers aged ≥50 years had medical conditions predisposing them to absenteeism
Batenburg and Reinken 1990 | 907 employees from 4 worksites, employed at least 12 months | <30 years | 3.0 | 3.1 | −3.2 | Authors noted that male nonsmokers aged ≥50 years had medical conditions predisposing them to absenteeism
Batenburg and Reinken 1990 | 907 employees from 4 worksites, employed at least 12 months | 30–39 years | 3.8 | 2.7 | 40.7 | Authors noted that male nonsmokers aged ≥50 years had medical conditions predisposing them to absenteeism
Batenburg and Reinken 1990 | 907 employees from 4 worksites, employed at least 12 months | ≥40 years | 4.1 | 3.6 | 13.9 | Authors noted that male nonsmokers aged ≥50 years had medical conditions predisposing them to absenteeism
Jones et al. 1990 | 1,893 Johnson & Johnson Company employees, aged 17–45 years | | Mean sick hours per year | | | None
Jones et al. 1990 | 1,893 Johnson & Johnson Company employees, aged 17–45 years | 1979 | 49.5 | 31.4 | 45.2 | None
Jones et al. 1990 | 1,893 Johnson & Johnson Company employees, aged 17–45 years | 1980 | 52.8 | 37.7 | 40.1 | None
Jones et al. 1990 | 1,893 Johnson & Johnson Company employees, aged 17–45 years | 1981 | 54.2 | 38.5 | 40.8 | None
Ault et al. 1991 | 2,406 (subset of 5,000) randomly sampled U.S. families; data were collected in 1967 | | Days absent from work | | | The association disappeared when the effects of other job characteristics were properly assessed
Ault et al. 1991 | 2,406 (subset of 5,000) randomly sampled U.S. families; data were collected in 1967 | Total | 8.37 | 6.49 | 29.0 | The association disappeared when the effects of other job characteristics were properly assessed
Bertera 1991 | 45,976 DuPont employees | | Mean annual illness days | | | Nonsmokers included never smokers plus former smokers
Bertera 1991 | 45,976 DuPont employees | Total | 3.69 | 2.79 | 32.3 | Nonsmokers included never smokers plus former smokers
Bertera 1991 | 45,976 DuPont employees | | Mean annual illness costs | | | Nonsmokers included never smokers plus former smokers
Bertera 1991 | 45,976 DuPont employees | Total | $3,971.27 | $3,011.23 | 31.9 | Nonsmokers included never smokers plus former smokers
Low and Mitchell 1991 | 30 steel foundry workers, mean age 33.5 years | | Mean number of absence episodes during the year | | | It is unclear how the total percentage difference could occur, given the results for the number and duration of absence episodes
Low and Mitchell 1991 | 30 steel foundry workers, mean age 33.5 years | Total | 6.0 | 5.0 | 20.0 | It is unclear how the total percentage difference could occur, given the results for the number and duration of absence episodes
Low and Mitchell 1991 | 30 steel foundry workers, mean age 33.5 years | | Mean duration of episodes in days | | | It is unclear how the total percentage difference could occur, given the results for the number and duration of absence episodes
Low and Mitchell 1991 | 30 steel foundry workers, mean age 33.5 years | Total | 2.0 | 1.0 | 100.0 | It is unclear how the total percentage difference could occur, given the results for the number and duration of absence episodes
Low and Mitchell 1991 | 30 steel foundry workers, mean age 33.5 years | | Total days absent during the year | | | It is unclear how the total percentage difference could occur, given the results for the number and duration of absence episodes
Low and Mitchell 1991 | 30 steel foundry workers, mean age 33.5 years | Total | 6.0 | 9.0 | −33.3 | It is unclear how the total percentage difference could occur, given the results for the number and duration of absence episodes
Green et al. 1992 | 5,826 employees of 21 Israeli factories, aged 20–64 years | | Mean days lost over 2 years | | | The percentages noted in italics were adjusted for age and occupation (and also present cause-specific data)
Green et al. 1992 | 5,826 employees of 21 Israeli factories, aged 20–64 years | Men | 9.99 | 7.40 | 35.0 | The percentages noted in italics were adjusted for age and occupation (and also present cause-specific data)
Green et al. 1992 | 5,826 employees of 21 Israeli factories, aged 20–64 years | 20–44 years | 8.57 | 6.44 | 33.1 | The percentages noted in italics were adjusted for age and occupation (and also present cause-specific data)
Green et al. 1992 | 5,826 employees of 21 Israeli factories, aged 20–64 years | 45–64 years | 14.45 | 11.15 | 29.6 | The percentages noted in italics were adjusted for age and occupation (and also present cause-specific data)
Green et al. 1992 | 5,826 employees of 21 Israeli factories, aged 20–64 years | Women | 15.19 | 16.13 | −5.8 | The percentages noted in italics were adjusted for age and occupation (and also present cause-specific data)
Green et al. 1992 | 5,826 employees of 21 Israeli factories, aged 20–64 years | 20–44 years | 13.91 | 13.69 | 1.6 | The percentages noted in italics were adjusted for age and occupation (and also present cause-specific data)
Green et al. 1992 | 5,826 employees of 21 Israeli factories, aged 20–64 years | 45–64 years | 17.49 | 24.93 | −29.8 | The percentages noted in italics were adjusted for age and occupation (and also present cause-specific data)
Green et al. 1992 | 5,826 employees of 21 Israeli factories, aged 20–64 years | Men | Mean days per absence episodes | | | The percentages noted in italics were adjusted for age and occupation (and also present cause-specific data)
Green et al. 1992 | 5,826 employees of 21 Israeli factories, aged 20–64 years | 20–44 years | 5.17 | 4.65 | 11.2 | The percentages noted in italics were adjusted for age and occupation (and also present cause-specific data)
Green et al. 1992 | 5,826 employees of 21 Israeli factories, aged 20–64 years | 45–64 years | 9.09 | 7.51 | 21.0 | The percentages noted in italics were adjusted for age and occupation (and also present cause-specific data)
Green et al. 1992 | 5,826 employees of 21 Israeli factories, aged 20–64 years | Women | | | | The percentages noted in italics were adjusted for age and occupation (and also present cause-specific data)
Green et al. 1992 | 5,826 employees of 21 Israeli factories, aged 20–64 years | 20–44 years | 3.86 | 4.04 | −4.5 | The percentages noted in italics were adjusted for age and occupation (and also present cause-specific data)
Green et al. 1992 | 5,826 employees of 21 Israeli factories, aged 20–64 years | 45–64 years | 7.07 | 7.66 | −7.7 | The percentages noted in italics were adjusted for age and occupation (and also present cause-specific data)
Ryan et al. 1992, 1996 | 2,537 U.S. Postal Service employees | Total | Mean absence rate | | | None
Ryan et al. 1992, 1996 | 2,537 U.S. Postal Service employees | 1-year follow-up | 5.4 | 4.1 | 31.7 | None
Ryan et al. 1992, 1996 | 2,537 U.S. Postal Service employees | 2-year follow-up | 7.9 | 5.8 | 36.2 | None
North et al. 1993 | 10,314 London civil servants, aged 35–55 years, prospective cohort | | Periods of absence: short | | | Adjusted rate ratios; short-term: unverified medical absences; long-term: verified medical absences
North et al. 1993 | 10,314 London civil servants, aged 35–55 years, prospective cohort | Men | 1.46 | 1.0 | 46.0 | Adjusted rate ratios; short-term: unverified medical absences; long-term: verified medical absences
North et al. 1993 | 10,314 London civil servants, aged 35–55 years, prospective cohort | Women | 1.09 | 1.0 | 9.0 | Adjusted rate ratios; short-term: unverified medical absences; long-term: verified medical absences
North et al. 1993 | 10,314 London civil servants, aged 35–55 years, prospective cohort | | Periods of absence: long | | | Adjusted rate ratios; short-term: unverified medical absences; long-term: verified medical absences
North et al. 1993 | 10,314 London civil servants, aged 35–55 years, prospective cohort | Men | 1.81 | 1.0 | 81.0 | Adjusted rate ratios; short-term: unverified medical absences; long-term: verified medical absences
North et al. 1993 | 10,314 London civil servants, aged 35–55 years, prospective cohort | Women | 1.37 | 1.0 | 37.0 | Adjusted rate ratios; short-term: unverified medical absences; long-term: verified medical absences
Halpern and Warner 1994 | 1990 U.S. National Health Interview Survey (nationally representative sample) | | Work-loss days past 2 weeks
Halpern and Warner 1994 | 1990 U.S. National Health Interview Survey (nationally representative sample) | Total | 1.48 | 1.0 | 48.0 | OR
Halpern and Warner 1994 | 1990 U.S. National Health Interview Survey (nationally representative sample) | | Limitations of ability to work
Halpern and Warner 1994 | 1990 U.S. National Health Interview Survey (nationally representative sample) | | 1.27 | 1.0 | 27.0 | OR
Post et al. 1994 | 405 workers at an animal feed mill, mean ages 38 years (clerks) and 42 years (blue collar), Netherlands | | Absence prevalence rate
Post et al. 1994 | 405 workers at an animal feed mill, mean ages 38 years (clerks) and 42 years (blue collar), Netherlands | Clerks | 2.36 | 1.0 | 136.0 | OR
Post et al. 1994 | 405 workers at an animal feed mill, mean ages 38 years (clerks) and 42 years (blue collar), Netherlands | Blue collar | 1.64 | 1.0 | 64.0 | OR
Bush and Wooden 1995 | 1989 Australian National Health Survey; n = 21,984 employed persons from randomly selected households | | Any absence 2 weeks before the interview | | | Adjusted OR; also adjusted for health status and health indicators
Bush and Wooden 1995 | 1989 Australian National Health Survey; n = 21,984 employed persons from randomly selected households | Men | 1.43 | 1.0 | 43.0 | Adjusted OR; also adjusted for health status and health indicators
Bush and Wooden 1995 | 1989 Australian National Health Survey; n = 21,984 employed persons from randomly selected households | Women | 1.32 | 1.0 | 32.0 | Adjusted OR; also adjusted for health status and health indicators
Tsai et al. 1997 | 2,287 Shell Oil Company employees, mean age 36 years | | Average duration of absence (days) | | | None
Tsai et al. 1997 | 2,287 Shell Oil Company employees, mean age 36 years | Men | 6.1 | 3.5 | 74.3 | None
Tsai et al. 1997 | 2,287 Shell Oil Company employees, mean age 36 years | Women | 6.8 | 3.6 | 88.9 | None
Tsai et al. 1997 | 2,287 Shell Oil Company employees, mean age 36 years | | Morbidity frequency rate | | | None
Tsai et al. 1997 | 2,287 Shell Oil Company employees, mean age 36 years | Men | 28.5 | 13.3 | 114.3 | None
Tsai et al. 1997 | 2,287 Shell Oil Company employees, mean age 36 years | Women | 20.4 | 13.2 | 54.5 | None
Niedhammer et al. 1998 | 12,555 men (aged 40–50 years) and women (aged 35–50 years), prospective cohort | | Periods of absence | | | Adjusted rate ratios
Niedhammer et al. 1998 | 12,555 men (aged 40–50 years) and women (aged 35–50 years), prospective cohort | Men | 1.24 | 1.0 | 24.0 | Adjusted rate ratios
Niedhammer et al. 1998 | 12,555 men (aged 40–50 years) and women (aged 35–50 years), prospective cohort | Women | 1.26 | 1.0 | 26.0 | Adjusted rate ratios
Niedhammer et al. 1998 | 12,555 men (aged 40–50 years) and women (aged 35–50 years), prospective cohort | | Absence days | | | Adjusted rate ratios
Niedhammer et al. 1998 | 12,555 men (aged 40–50 years) and women (aged 35–50 years), prospective cohort | Men | 1.45 | 1.0 | 45.0 | Adjusted rate ratios
Niedhammer et al. 1998 | 12,555 men (aged 40–50 years) and women (aged 35–50 years), prospective cohort | Women | 1.26 | 1.0 | 26.0 | Adjusted rate ratios

* OR = Odds ratio.

##### Current Smokers

In studies with varying designs conducted in diverse locations, cigarette smokers consistently have had higher rates of absenteeism than nonsmokers (Table 6.6). The evidence also indicates that the duration of sickness absences tends to be longer for smokers and smokers miss more cumulative worktime than nonsmokers. The association between smoking and absenteeism has been observed in both men and women of all ages. Sickness absences have been measured in a variety of ways, including lost worktime per unit of time, episodes of absenteeism, and the duration of absences. The finding that smoking is associated with absenteeism, regardless of the index used, documents consistency of the observed association. Although most studies were cross-sectional or retrospective in design, two were prospective cohort studies (North et al. 1993; Niedhammer et al. 1998) and another studied smoking histories in relation to work-place attendance records during the preceding nine years (Holcomb and Meigs 1972). The findings of these prospective studies confirm that smoking preceded the absenteeism. In a few studies, the association with smoking was observed primarily in men but not in women (Green et al. 1992; North et al. 1993), but in general the findings have been consistent across all of the subgroups studied. Of the 30 studies that were the sources for the data abstracted into Table 6.6, 17 studies found that absenteeism among smokers was at least 20 percent greater than among nonsmokers in all subgroups.

Two additional reports not included in the table also provide evidence of an association between smoking and absence frequency (Ferguson 1973; Donaldson et al. 1999). In a study of 516 men employed in four occupational groups in Australia, Ferguson noted that “. . .the employee with repeated absence also tended (p <0.10), more often than the resister” (employee without repeated absences) “. . .to smoke more than 15 cigarettes daily” (Ferguson 1973, p. 336). In a study of 146 lumber company employees, a tobacco use scale was not correlated (r = 0.01) with absenteeism (Donaldson et al. 1999).

In several studies summarized in Table 6.6 that assessed the relationship between current smoking and absenteeism (Athanasou 1979; Andersson and Malmgren 1986; Hawker and Holtby 1988; Bertera 1991), current smokers were compared with all nonsmokers, including former smokers. As discussed in the following section, absenteeism rates among former smokers are persistently elevated compared with those of lifetime nonsmokers. Thus, using an “unexposed” comparison category that includes former smokers along with lifetime nonsmokers will dilute associations that would be estimated when using a “pure” unexposed category consisting solely of persons who have never smoked.

In the two studies that assessed the dose-response relationship with the number of cigarettes smoked, the likelihood of being absent increased strongly with the number of cigarettes smoked per day (Lowe 1960; Holcomb and Meigs 1972). In a retrospective cohort study of 226 male factory employees in Connecticut that included eight years of follow-up, the rate of long-term absences increased 43 percent, 57 percent, and 100 percent compared with nonsmokers for those who smoked less than one pack, one pack, and more than one pack of cigarettes per day, respectively (Holcomb and Meigs 1972). In a study of more than 3,300 male General Electric employees in England, the number of days absent for medical reasons increased 11 percent, 13 percent, 26 percent, and 57 percent compared with nonsmokers for those who smoked 1 to 9, 10 to 19, 20 to 29, and 30 or more cigarettes per day, respectively (Lowe 1960).

This body of evidence shows increased absenteeism among smokers, while providing only limited information on the reasons for the absences. A significant proportion of sickness absences in smokers would be expected to be due to smoking-associated illnesses. Athanasou and colleagues (1981) hypothesized that smoking acts as a susceptibility factor, increasing the risks for other harmful occupational exposures. In one study, smoking was associated with a significantly increased likelihood of absences resulting from problems as diverse as back symptoms, digestive tract symptoms, and neck and upper limb symptoms (Dimberg et al. 1989). A recent review summarizing 38 studies showed an increased risk for back pain in smokers compared with nonsmokers in the majority of studies (Goldberg et al. 2000). In another study, absences were elevated not only for “medical reasons” but also for “other” reasons (Lowe 1960). Substantial evidence also documents that smokers are more likely than non-smokers to have on-the-job injuries (Lowe 1960; Naus et al. 1966; Reynolds et al. 1994; Forrester et al. 1996). Because smoking increases absences for a broad set of health problems, and not just specific smoking-associated illnesses, the underlying causal pathways are likely to be multiple and general, reflecting the systemic nature of the effects of smoking.

##### Former Smokers

The evidence is consistent that former smokers are less likely to be absent from work compared with persistent smokers. Former smokers tend to have somewhat higher absenteeism rates than persons who have never smoked (Table 6.7), but the increases are much smaller than those for current smokers. The analyses performed by Wooden and Bush (1995) with former smokers (n = 4,812) in the 1989–1990 Australian National Health Survey illustrate the seemingly paradoxic relationship between quitting smoking and absenteeism. In a multiple regression model that included both the duration of active smoking and time since quitting, the number of years that a former smoker had smoked remained a strong predictor of absenteeism, and the likelihood of absences declined gradually over time since cessation (Wooden and Bush 1995). Similarly, Manning and colleagues (1989) found differences between recent and sustained quitters, and observed considerably higher absenteeism rates for recent quitters compared with long-term quitters. These results indicate that both prior smoking history and time since quitting are factors strongly associated with absenteeism, but in opposite directions. This pattern may arise because some smokers may quit when diagnosed with an illness caused by smoking, and the recent quitters may thus already have a smoking-induced illness that predisposes them to lost worktime.

Table 6.7 Studies on the association between former smoking and absenteeism

Study | Population | Group | Results | | | Comments
Study | Population | Group | Former smokers | Nonsmokers | Percentage difference | Comments
Holcomb and Meigs 1972 | 226 male factory employees | Total | Total days lost per person per year | | | Short-term: <7 days unverified medical absences Long-term: ≥10 days verified medical absences
Holcomb and Meigs 1972 | 226 male factory employees | Total | 6.37 | 4.42 | 44.1 | Short-term: <7 days unverified medical absences Long-term: ≥10 days verified medical absences
Holcomb and Meigs 1972 | 226 male factory employees | Total | Absence rate: short-term | | | Short-term: <7 days unverified medical absences Long-term: ≥10 days verified medical absences
Holcomb and Meigs 1972 | 226 male factory employees | Total | 0.75 | 0.38 | 97.4 | Short-term: <7 days unverified medical absences Long-term: ≥10 days verified medical absences
Holcomb and Meigs 1972 | 226 male factory employees | Total | Absence rate: long-term | | | Short-term: <7 days unverified medical absences Long-term: ≥10 days verified medical absences
Holcomb and Meigs 1972 | 226 male factory employees | Total | 0.10 | 0.07 | 42.9 | Short-term: <7 days unverified medical absences Long-term: ≥10 days verified medical absences
Wilson 1973 | 1970 National Health Interview Survey, persons aged ≥17 years | | Mean workdays lost per year | | | None
Wilson 1973 | 1970 National Health Interview Survey, persons aged ≥17 years | Total | 5.2 | 4.4 | 18.2 | None
Wilson 1973 | 1970 National Health Interview Survey, persons aged ≥17 years | Men | 5.1 | 3.7 | 37.8 | None
Wilson 1973 | 1970 National Health Interview Survey, persons aged ≥17 years | Women | 5.3 | 5.1 | 3.9 | None
Wilson 1973 | 1970 National Health Interview Survey, persons aged ≥17 years | 17–44 years | 4.3 | 3.8 | 13.2 | None
Wilson 1973 | 1970 National Health Interview Survey, persons aged ≥17 years | 45–64 years | 5.7 | 5.7 | 0 | None
Wilson 1973 | 1970 National Health Interview Survey, persons aged ≥17 years | ≥65 years | 8.6 | 4.3 | 100.0 | None
U.S. Department of Health and Human Services 1980 | Nationally representative population sample, aged ≥17 years, United States | | Workdays lost per year due to illness and injury per currently employed persons | | | None
U.S. Department of Health and Human Services 1980 | Nationally representative population sample, aged ≥17 years, United States | 1965 | | | | None
U.S. Department of Health and Human Services 1980 | Nationally representative population sample, aged ≥17 years, United States | Men | 6.8 | 4.6 | 47.8 | None
U.S. Department of Health and Human Services 1980 | Nationally representative population sample, aged ≥17 years, United States | Women | 6.7 | 4.8 | 39.6 | None
U.S. Department of Health and Human Services 1980 | Nationally representative population sample, aged ≥17 years, United States | 1977 | | | | None
U.S. Department of Health and Human Services 1980 | Nationally representative population sample, aged ≥17 years, United States | Men | 6.1 | 4.2 | 45.2 | None
U.S. Department of Health and Human Services 1980 | Nationally representative population sample, aged ≥17 years, United States | Women | 5.4 | 5.7 | −5.3 | None
Janzon et al. 1981 | 1,037 Swedish men, aged 47–48 years | Total | Percent using sick leave >3 times during the past year | | | None
Janzon et al. 1981 | 1,037 Swedish men, aged 47–48 years | Total | 7 | 4 | 75.0
Gallop 1989 | 169 pulp and paper industrial company employees | | Mean illness absences last year | | | Payroll records were used to verify self-reported records
Gallop 1989 | 169 pulp and paper industrial company employees | Total self-reported records (n = 82) | 4.7 | 4.1 | 14.6 | Payroll records were used to verify self-reported records
Gallop 1989 | 169 pulp and paper industrial company employees | Payroll records | 9.1 | 7.9 | 15.2 | Payroll records were used to verify self-reported records
Jackson et al. 1989 | 70 persons (started with 100—50 matched former and persistent smokers), North Carolina pharmaceutical company | | Annual mean ranked sick days | | | Ranked using absent days minus days due to personal leave, death in family, jury duty
Jackson et al. 1989 | 70 persons (started with 100—50 matched former and persistent smokers), North Carolina pharmaceutical company | Persistent smokers | Persistent | Former | | Ranked using absent days minus days due to personal leave, death in family, jury duty
Jackson et al. 1989 | 70 persons (started with 100—50 matched former and persistent smokers), North Carolina pharmaceutical company | 3 years precessation | 32.9 | 38.1 | −13.6 | Ranked using absent days minus days due to personal leave, death in family, jury duty
Jackson et al. 1989 | 70 persons (started with 100—50 matched former and persistent smokers), North Carolina pharmaceutical company | 2 years precessation | 30.7 | 40.3 | −23.8 | Ranked using absent days minus days due to personal leave, death in family, jury duty
Jackson et al. 1989 | 70 persons (started with 100—50 matched former and persistent smokers), North Carolina pharmaceutical company | 1 year precessation | 36.5 | 34.5 | 5.8 | Ranked using absent days minus days due to personal leave, death in family, jury duty
Jackson et al. 1989 | 70 persons (started with 100—50 matched former and persistent smokers), North Carolina pharmaceutical company | Former smokers | 38.3 | 32.7 | 17.1 | Ranked using absent days minus days due to personal leave, death in family, jury duty
Jackson et al. 1989 | 70 persons (started with 100—50 matched former and persistent smokers), North Carolina pharmaceutical company | 1 year postcessation | 41.0 | 30.0 | 36.7 | Ranked using absent days minus days due to personal leave, death in family, jury duty
Jackson et al. 1989 | 70 persons (started with 100—50 matched former and persistent smokers), North Carolina pharmaceutical company | 2 years postcessation | 42.1 | 28.9 | 45.7 | Ranked using absent days minus days due to personal leave, death in family, jury duty
Jackson et al. 1989 | 70 persons (started with 100—50 matched former and persistent smokers), North Carolina pharmaceutical company | 3 years postcessation | 44.7 | 26.3 | 70.0 | Ranked using absent days minus days due to personal leave, death in family, jury duty
Manning et al. 1989 | 324 employees of 2 companies, aged 20–75 years | Baseline | Mean hours absent per month | | | Short-term: ≤2 days Long-term: >2 days Sustained: >1 year Recent: ≤1 year
Manning et al. 1989 | 324 employees of 2 companies, aged 20–75 years | Short-term absences | | | | Short-term: ≤2 days Long-term: >2 days Sustained: >1 year Recent: ≤1 year
Manning et al. 1989 | 324 employees of 2 companies, aged 20–75 years | Recent quitters | 2.21 | 1.69 | 30.8 | Short-term: ≤2 days Long-term: >2 days Sustained: >1 year Recent: ≤1 year
Manning et al. 1989 | 324 employees of 2 companies, aged 20–75 years | Sustained quitters | 1.47 | 1.69 | −13.0 | Short-term: ≤2 days Long-term: >2 days Sustained: >1 year Recent: ≤1 year
Manning et al. 1989 | 324 employees of 2 companies, aged 20–75 years | Long-term absences | | | | Short-term: ≤2 days Long-term: >2 days Sustained: >1 year Recent: ≤1 year
Manning et al. 1989 | 324 employees of 2 companies, aged 20–75 years | Recent quitters | 1.38 | 0.78 | 76.9 | Short-term: ≤2 days Long-term: >2 days Sustained: >1 year Recent: ≤1 year
Manning et al. 1989 | 324 employees of 2 companies, aged 20–75 years | Sustained quitters | 0.68 | 0.78 | −12.8 | Short-term: ≤2 days Long-term: >2 days Sustained: >1 year Recent: ≤1 year
Manning et al. 1989 | 324 employees of 2 companies, aged 20–75 years | 1-year follow-up | | | | Short-term: ≤2 days Long-term: >2 days Sustained: >1 year Recent: ≤1 year
Manning et al. 1989 | 324 employees of 2 companies, aged 20–75 years | Short-term absences | | | | Short-term: ≤2 days Long-term: >2 days Sustained: >1 year Recent: ≤1 year
Manning et al. 1989 | 324 employees of 2 companies, aged 20–75 years | Recent quitters | 2.21 | 1.17 | 88.9 | Short-term: ≤2 days Long-term: >2 days Sustained: >1 year Recent: ≤1 year
Manning et al. 1989 | 324 employees of 2 companies, aged 20–75 years | Sustained quitters | 1.15 | 1.17 | −1.7 | Short-term: ≤2 days Long-term: >2 days Sustained: >1 year Recent: ≤1 year
Manning et al. 1989 | 324 employees of 2 companies, aged 20–75 years | Long-term absences | | | | Short-term: ≤2 days Long-term: >2 days Sustained: >1 year Recent: ≤1 year
Manning et al. 1989 | 324 employees of 2 companies, aged 20–75 years | Recent quitters | 1.90 | 1.67 | 13.8 | Short-term: ≤2 days Long-term: >2 days Sustained: >1 year Recent: ≤1 year
Manning et al. 1989 | 324 employees of 2 companies, aged 20–75 years | Sustained quitters | 1.95 | 1.67 | 16.8 | Short-term: ≤2 days Long-term: >2 days Sustained: >1 year Recent: ≤1 year
Low and Mitchell 1991 | 30 steel foundry workers, mean age 33.5 years | | Mean number of absence episodes during the year | | | None
Low and Mitchell 1991 | 30 steel foundry workers, mean age 33.5 years | | 4.5 | 5.0 | −10.0 | None
Low and Mitchell 1991 | 30 steel foundry workers, mean age 33.5 years | Total | Mean duration of episodes | | | None
Low and Mitchell 1991 | 30 steel foundry workers, mean age 33.5 years | | 1.0 | 1.0 | 0 | None
Low and Mitchell 1991 | 30 steel foundry workers, mean age 33.5 years | | Total days absent | | | None
Low and Mitchell 1991 | 30 steel foundry workers, mean age 33.5 years | | 6.0 | 9.0 | −33.3 | None
Halpern and Warner 1994 | 1990 U.S. National Health Interview Survey (nationally representative sample) | Time since cessation | Work-loss days during the past 2 weeks | | | OR^*^
Halpern and Warner 1994 | 1990 U.S. National Health Interview Survey (nationally representative sample) | 0–2 months | 2.69 | 1.0 | 169.0 | OR^*^
Halpern and Warner 1994 | 1990 U.S. National Health Interview Survey (nationally representative sample) | 3 months–1 year | 1.47 | 1.0 | 47.0 | OR^*^
Halpern and Warner 1994 | 1990 U.S. National Health Interview Survey (nationally representative sample) | 2–4 years | 1.45 | 1.0 | 45.0 | OR^*^
Halpern and Warner 1994 | 1990 U.S. National Health Interview Survey (nationally representative sample) | 5–10 years | 1.31 | 1.0 | 31.0 | OR^*^
Halpern and Warner 1994 | 1990 U.S. National Health Interview Survey (nationally representative sample) | 11–19 years | 1.41 | 1.0 | 41.0 | OR^*^
Halpern and Warner 1994 | 1990 U.S. National Health Interview Survey (nationally representative sample) | ≥20 years | 1.26 | 1.0 | 26.0 | OR^*^
Post et al. 1994 | 405 workers at an animal feed mill, mean ages 38 years (clerks) and 42 years (blue collar), Netherlands | | Absence prevalence
Post et al. 1994 | 405 workers at an animal feed mill, mean ages 38 years (clerks) and 42 years (blue collar), Netherlands | Clerks | 0.74 | 1.0 | −26.0 | OR
Post et al. 1994 | 405 workers at an animal feed mill, mean ages 38 years (clerks) and 42 years (blue collar), Netherlands | Blue collar | 1.22 | 1.0 | 22.0 | OR
Bush and Wooden 1995 | 1989 Australian National Health Survey, n = 21,984 employed persons from randomly selected households | | Any absence 2 weeks before the interview | | | OR was adjusted for demographics (age, gender, ethnicity, marital status, education, location of residence); job characteristics (employment status, hours worked, income, occupation, industry); and health risk factors (alcohol use, physical exercise, body weight); additional factors measured overall health and happiness (more specific information was not provided)
Bush and Wooden 1995 | 1989 Australian National Health Survey, n = 21,984 employed persons from randomly selected households | Men: 12,839 | 1.33 | 1.0 | 33.0
Bush and Wooden 1995 | 1989 Australian National Health Survey, n = 21,984 employed persons from randomly selected households | Women: 9,145 | 1.19 | 1.0 | 19.0
Wooden and Bush 1995 | 4,812 randomly sampled former smokers, Australian National Health Survey | | ORs for incidence of absence during past 2 weeks (modeled) | | | Adjusted for several potential confounders
Wooden and Bush 1995 | 4,812 randomly sampled former smokers, Australian National Health Survey | Total | 1.04 | 1.0 | 4.0 | Adjusted for several potential confounders
Wooden and Bush 1995 | 4,812 randomly sampled former smokers, Australian National Health Survey | Time since cessation | | | | Adjusted for several potential confounders
Wooden and Bush 1995 | 4,812 randomly sampled former smokers, Australian National Health Survey | 1–4 years | 0.53 | | | Adjusted for several potential confounders
Wooden and Bush 1995 | 4,812 randomly sampled former smokers, Australian National Health Survey | 5–9 years | 0.50 | | | Adjusted for several potential confounders
Wooden and Bush 1995 | 4,812 randomly sampled former smokers, Australian National Health Survey | 10–19 years | 0.32 | | | Adjusted for several potential confounders
Wooden and Bush 1995 | 4,812 randomly sampled former smokers, Australian National Health Survey | ≥20 years | 0.22 | | | Adjusted for several potential confounders
Niedhammer et al. 1998 | 9,065 men (aged 40–50 years) and 3,490 women (aged 35–50 years), prospective cohort | | Periods of absence | | | Adjusted rate ratios
Niedhammer et al. 1998 | 9,065 men (aged 40–50 years) and 3,490 women (aged 35–50 years), prospective cohort | Men | 1.10 | 1.0 | 10.0 | Adjusted rate ratios
Niedhammer et al. 1998 | 9,065 men (aged 40–50 years) and 3,490 women (aged 35–50 years), prospective cohort | Women | 1.03 | 1.0 | 3.0 | Adjusted rate ratios
Niedhammer et al. 1998 | 9,065 men (aged 40–50 years) and 3,490 women (aged 35–50 years), prospective cohort | | Days absent | | | Adjusted rate ratios
Niedhammer et al. 1998 | 9,065 men (aged 40–50 years) and 3,490 women (aged 35–50 years), prospective cohort | Men | 1.06 | 1.0 | 6.0 | Adjusted rate ratios
Niedhammer et al. 1998 | 9,065 men (aged 40–50 years) and 3,490 women (aged 35–50 years), prospective cohort | Women | 1.05 | 1.0 | 5.0 | Adjusted rate ratios

* OR = Odds ratio.

In interpreting evidence linking smoking to a diminished health status, including absenteeism, untangling the direct effects of smoking from the indirect effects is challenging, as smokers and nonsmokers may differ in potential confounding factors. Nonetheless, given the scope of the evidence available and the diversity of the populations studied, the literature does provide insights into the role of smoking as a cause of absenteeism.

With regard to confounding, alcohol use is a major factor of concern. Alcohol use has been linked to absenteeism in some studies, and smokers drink more than nonsmokers (Smith 1970; Turner 1988; Ault et al. 1991; Marmot et al. 1993; Vasse et al. 1998). Smokers are also more likely to be heavy alcohol drinkers and to use illicit substances (Merrill et al. 1999; Best et al. 2000; Brain et al. 2000; Dawson 2000), and heavy alcohol and illicit substance use, rather than cigarette smoking, could increase the likelihood of workplace absences. Studies that adjusted for alcohol consumption have generally (Hendrix and Taylor 1987; Bush and Wooden 1995; Wooden and Bush 1995), but not universally (Ault et al. 1991), found smoking to be associated with frequent absences, implying that the association of smoking with alcoholism is not due to confounding. Studies were not found that accounted for illicit substance use in assessing the association between smoking and workplace absences. Less likely is the possibility that the association between smoking and absences reflects confounding by characteristics that are linked both to smoking (see the section on “Health Status” later in this section) and to an increased risk for frequent absences. For example, women are consistently absent from work more often than men (Leigh 1983; Pines et al. 1985; Steinhardt et al. 1991). But women assume a disproportionate share of family responsibilities such as staying home with sick children, and the relative importance of smoking may therefore be less. Observations of persons with “psychosocial problems” (Leijon and Mikaelsson 1984) and anxiety/neuroses (Taylor 1968; Ferguson 1973) document increased risks for absenteeism, and if such persons are more likely to smoke, confounding is possible. Given the range of populations studied, confounding by psychosocial factors seems unlikely.

Of the relevant pathway factors leading to health-related absences, age is the primary demographic characteristic that is a potential modifying or confounding factor. Socioeconomic status, another potential confounding or modifying factor, is inherently restricted in studies within occupational groups. Age is associated with both absenteeism (Pines et al. 1985) and health status. The association between smoking and absenteeism has been observed consistently across a broad spectrum of age strata in the summarized results, implying that the association does not reflect confounding by age.

Only a few studies provide prospective data concerning absenteeism following smoking cessation; the findings suggest that smoking cessation is associated with better attendance at work. A particularly informative study conducted with employees of a North Carolina pharmaceutical company compared the attendance patterns of former smokers before and after quitting with attendance patterns of a matched group of persistent smokers (Jackson et al. 1989). In the time preceding smoking cessation by the cessation group, the persistent smokers tended to have fewer absences than the smokers who went on to stop smoking. However, during the three years following cessation, the mean number of annual sick days declined among those who quit. Absences continued to increase for persistent smokers, leading to a widening gap in absences between the two groups. The study was small, with only 70 persons participating. In a randomized trial of nine worksite smoking cessation programs, employees who were smokers at baseline had a significant reduction (p = 0.002) in self-reported sick days after stopping smoking (Jeffrey et al. 1993). In another study evaluating a workplace health promotion program that reduced smoking prevalence, the authors reported significant reductions in absenteeism for program participants but not for nonparticipants (Wood et al. 1989).

The evidence that reduced absenteeism follows cessation complements findings based on comparisons of current smokers with nonsmokers. The reduced rate after cessation supports a causal interpretation, rather than attributing the association to an indirect pathway or to confounding factors.

In summary, there is consistent evidence demonstrating that employees who are current smokers have a greater likelihood of absences from work compared with employees who have never smoked. Additional evidence is needed on dose-response trends and, more importantly, on changes in absence rates before and after smoking cessation. Other reviewers have concluded that reduced absenteeism could lead to potential savings that can be accrued from smoking cessation programs in the workplace (Kristein 1983; Warner et al. 1996).

#### Medical Services Utilization

Medical services utilization provides another measure of the global effects of smoking on health. The most important utilization indicators in studies on smoking can be grouped into three general categories: (1) costs, (2) outpatient visit rates, and (3) hospitalization rates. Interpreting these findings requires consideration of the many factors influencing medical services utilization. Smokers, for example, are less likely than nonsmokers to use preventive services such as screening (Beaulieu et al. 1996; Edwards and Boulet 1997). However, the high incidence of smoking-induced diseases among smokers will tend to drive their medical care needs. The socioeconomic and educational differences between smokers and nonsmokers also complicate data interpretation because of potential confounding. Comparisons of smokers within well-defined groups, such as particular workforces or health care plans, should provide unbiased comparisons.

##### Costs

In evaluating the relationship between smoking and medical care costs, only those studies directly addressing expenditures were considered (Table 6.8). The literature on comparative lifetime costs of medical care for smokers and nonsmokers based on assumed models and projections was not considered relevant to this chapter. Of the seven studies reviewed, six showed the medical costs of smokers to be greater by at least 15 percent in at least one subgroup. In one study of enrollees in a health maintenance organization, smokers had costs 25 percent higher than nonsmokers among those younger than 65 years of age, but few differences were observed in those age 65 years or older (Terry et al. 1998). Only the study by Vogt and Schweitzer (1985) on enrollees in Kaiser Permanente found no differences between smokers and nonsmokers.

Table 6.8 Studies on the association between current smoking and medical service costs

Study | Population | Group | Results | | | Comments
Study | Population | Group | Smokers | Nonsmokers | Percentage difference | Comments
Costs
Vogt and Schweitzer 1985 | 2,582 adult HMO^*^ enrollees | Laboratory | $18,515 | $19,772 | −6.4 | None
Vogt and Schweitzer 1985 | 2,582 adult HMO^*^ enrollees | X-ray | 12,412 | 11,958 | 3.8 | None
Vogt and Schweitzer 1985 | 2,582 adult HMO^*^ enrollees | Surgery | 6,819 | 6,923 | −1.5 | None
Vogt and Schweitzer 1985 | 2,582 adult HMO^*^ enrollees | Total | 93,234 | 93,326 | −0.1 | None
Freeborn et al. 1990 | 515 HMO enrollees, aged >17 years | Group I (1970–1974) | $ 238 | $ 206 | 15.5 | Average ambulatory care costs
Freeborn et al. 1990 | 515 HMO enrollees, aged >17 years | Group II (1970–1979) | 231 | 225 | 2.7 | Average ambulatory care costs
Penner and Penner 1990 | 20,831 employees enrolled in a fee-for-service plan | Total | | | | None
Penner and Penner 1990 | 20,831 employees enrolled in a fee-for-service plan | Average cost per admission | $ 3,716.28 | $ 3,188.19 | 16.6 | None
Penner and Penner 1990 | 20,831 employees enrolled in a fee-for-service plan | Average inpatient cost per day | 459.56 | 241.74 | 90.1 | None
Hodgson 1992 | U.S. National Health Interview Survey, persons aged >17 years | Men | $35,914 | $27,276 | 31.7 | None
Hodgson 1992 | U.S. National Health Interview Survey, persons aged >17 years | Women | 52,902 | 42,783 | 23.7 | None
Callahan et al. 1998 | 12,581 patients who had at least 2 ambulatory visits plus 1 hospitalization, 1993–1996, aged >60 years | Total | $17,362 | $ 8,560 | 102.8 | Average costs over 4 years
Terry et al. 1998 | 5,780 HMO enrollees, aged >18 years | Aged <65 years | $ 119 | $ 95 | 25.3 | Charges per month
Terry et al. 1998 | 5,780 HMO enrollees, aged >18 years | Aged ≥65 years | 255 | 258 | −1.2 | Charges per month
Pronk et al. 1999 | 6,589 adult HMO enrollees, Minnesota | Total | NR^†^ | NR | 18.0 | Absolute values were not reported; adjusted for age, gender, race, body mass index, physical activity, and comorbidity conditions
Outpatient services
Peters and Ferris 1967 | Harvard/Radcliffe students | Total | 9.25 | 7.52 | 23.0 | Clinic visits, Harvard 1964–1965
Palmore 1970 | 268 community volunteers, aged 60–94 years at baseline | Total | 33.0 | 26.0 | 26.9 | Percentage with ≥3 doctor visits per year; nonsmokers/slight present use of tobacco vs. moderate present use/heavy present use of tobacco; nonsmokers had never used tobacco; slight present use of tobacco was defined as 1–4 cigarettes per day, 1–2 cigars and/or pipes per day, occasional use of snuff, or occasional tobacco chewing; moderate present use was defined as 5–10 cigarettes per day, 3–4 cigars and/or pipes per day, frequent use of snuff, or frequent tobacco chewing; heavy present use was defined as ≥11 cigarettes per day, ≥5 cigars and/or pipes per day, constant use of snuff, or constant use of chewing tobacco
Ashford 1973 | 32,319 residents of Exeter, United Kingdom, aged ≥15 years | Home visits | | | | Number of visits during the survey year
Ashford 1973 | 32,319 residents of Exeter, United Kingdom, aged ≥15 years | Men: 15–29 years | 0.21 | 0.17 | 23.5 | Number of visits during the survey year
Ashford 1973 | 32,319 residents of Exeter, United Kingdom, aged ≥15 years | 30–44 years | 0.28 | 0.18 | 55.6 | Number of visits during the survey year
Ashford 1973 | 32,319 residents of Exeter, United Kingdom, aged ≥15 years | 45–59 years | 0.43 | 0.33 | 30.3 | Number of visits during the survey year
Ashford 1973 | 32,319 residents of Exeter, United Kingdom, aged ≥15 years | ≥60 years | 1.4 | 2.3 | −39.1 | Number of visits during the survey year
Ashford 1973 | 32,319 residents of Exeter, United Kingdom, aged ≥15 years | Women: 15–29 years | 1.3 | 1.1 | 18.2 | Number of visits during the survey year
Ashford 1973 | 32,319 residents of Exeter, United Kingdom, aged ≥15 years | 30–44 years | 0.67 | 0.64 | 4.7 | Number of visits during the survey year
Ashford 1973 | 32,319 residents of Exeter, United Kingdom, aged ≥15 years | 45–59 years | 0.44 | 0.49 | −10.2 | Number of visits during the survey year
Ashford 1973 | 32,319 residents of Exeter, United Kingdom, aged ≥15 years | ≥60 years | 2.1 | 2.2 | −4.5 | Number of visits during the survey year
Ashford 1973 | 32,319 residents of Exeter, United Kingdom, aged ≥15 years | Hospital outpatient | | | | Number of visits during the survey year
Ashford 1973 | 32,319 residents of Exeter, United Kingdom, aged ≥15 years | Men: 15–29 years | 0.62 | 0.45 | 37.8 | Number of visits during the survey year
Ashford 1973 | 32,319 residents of Exeter, United Kingdom, aged ≥15 years | 30–44 years | 0.47 | 0.38 | 23.7 | Number of visits during the survey year
Ashford 1973 | 32,319 residents of Exeter, United Kingdom, aged ≥15 years | 45–59 years | 0.52 | 0.46 | 13.0 | Number of visits during the survey year
Ashford 1973 | 32,319 residents of Exeter, United Kingdom, aged ≥15 years | ≥60 years | 0.46 | 0.57 | −19.3 | Number of visits during the survey year
Ashford 1973 | 32,319 residents of Exeter, United Kingdom, aged ≥15 years | Women: 15–29 years | 0.56 | 0.46 | 21.7 | Number of visits during the survey year
Ashford 1973 | 32,319 residents of Exeter, United Kingdom, aged ≥15 years | 30–44 years | 0.51 | 0.45 | 13.3 | Number of visits during the survey year
Ashford 1973 | 32,319 residents of Exeter, United Kingdom, aged ≥15 years | 45–59 years | 0.48 | 0.52 | −7.7 | Number of visits during the survey year
Ashford 1973 | 32,319 residents of Exeter, United Kingdom, aged ≥15 years | ≥60 years | 0.47 | 0.59 | 20.3 | Number of visits during the survey year
Oakes et al. 1974 | 2,557 HMO enrollees, aged ≥20 years | Men: Total | 3.4 | 2.8 | 21.4 | Mean number of office visits during the past year
Oakes et al. 1974 | 2,557 HMO enrollees, aged ≥20 years | 20–39 years | 3.1 | 2.4 | 29.2 | Mean number of office visits during the past year
Oakes et al. 1974 | 2,557 HMO enrollees, aged ≥20 years | 40–59 years | 3.2 | 2.4 | 33.3 | Mean number of office visits during the past year
Oakes et al. 1974 | 2,557 HMO enrollees, aged ≥20 years | ≥60 years | 5.4 | 3.9 | 38.5 | Mean number of office visits during the past year
Oakes et al. 1974 | 2,557 HMO enrollees, aged ≥20 years | Women: Total | 4.2 | 4.8 | −12.5 | Mean number of office visits during the past year
Oakes et al. 1974 | 2,557 HMO enrollees, aged ≥20 years | 20–39 years | 5.0 | 5.4 | −7.4 | Mean number of office visits during the past year
Oakes et al. 1974 | 2,557 HMO enrollees, aged ≥20 years | 40–59 years | 3.5 | 4.0 | −12.5 | Mean number of office visits during the past year
Oakes et al. 1974 | 2,557 HMO enrollees, aged ≥20 years | ≥60 years | 3.3 | 5.0 | −34.0 | Mean number of office visits during the past year
Vogt and Schweitzer 1985 | 2,582 adult HMO enrollees | Total | 3,690 | 3,667 | 0.6 | Total office visits
Chetwynd and Rayner 1986 | 978 women, aged 18–60 years | Illness episodes | 3.31 | 2.56 | 29.3 | Smokers = ever smokers
Chetwynd and Rayner 1986 | 978 women, aged 18–60 years | General practitioner visits | 5.71 | 4.90 | 16.5 | Smokers = ever smokers
Chetwynd and Rayner 1986 | 978 women, aged 18–60 years | Specialist visits | 0.83 | 0.45 | 84.4 | Smokers = ever smokers
Chetwynd and Rayner 1986 | 978 women, aged 18–60 years | Outpatient visits | 0.81 | 0.64 | 26.6 | Smokers = ever smokers
Chetwynd and Rayner 1986 | 978 women, aged 18–60 years | Chiropractor visits | 0.16 | 0.12 | 33.3 | Smokers = ever smokers
Rice et al. 1986 | 1979 National Health Interview Survey participants | Total | 5.2 | 4.9 | 6.1 | Physician visits per person per year
Rice et al. 1986 | 1979 National Health Interview Survey participants | Aged 17–44 years | 4.7 | 4.4 | 6.8 | Physician visits per person per year
Rice et al. 1986 | 1979 National Health Interview Survey participants | Aged 45–64 years | 5.3 | 4.9 | 8.2 | Physician visits per person per year
Rice et al. 1986 | 1979 National Health Interview Survey participants | Aged ≥65 years | 7.0 | 6.6 | 6.1 | Physician visits per person per year
Freeborn et al. 1990 | 515 HMO enrollees, aged >65 years | Group I (1970–1974) | 6.12 | 5.33 | 19.8 | Office visits per year
Freeborn et al. 1990 | 515 HMO enrollees, aged >65 years | Group II (1970–1979) | 6.18 | 5.30 | 16.6 | Office visits per year
Halpern and Warner 1994 | 1990 U.S. National Health Interview Survey | Total | 1.01 | 1.00 | 1.0 | Physician visits in the past year; OR^‡^
Miller et al. 1999 | 1987 National Medical Expenditure Survey, n = 38,446 | Total | 0.7417 | 0.7379 | 0.5 | Probability of ambulatory expense
Hospitalizations/inpatient services
Palmore 1970 | 268 community volunteers, aged 60–94 years at baseline | Total | 38.0 | 33.0 | 15.2 | Percentage with ≥1 operation; nonsmokers/slight present use of tobacco vs. moderate present use/heavy present use of tobacco; nonsmokers had never used tobacco; slight present use of tobacco was defined as 1–4 cigarettes per day, 1–2 cigars and/or pipes per day, occasional use of snuff, or occasional tobacco chewing; moderate present use was defined as 5–10 cigarettes per day, 3–4 cigars and/or pipes per day, frequent use of snuff, or frequent tobacco chewing; heavy present use was defined as ≥11 cigarettes per day, ≥5 cigars and/or pipes per day, constant use of snuff, or constant use of chewing tobacco
Ashford 1973 | 32,219 residents of Exeter, United Kingdom, aged ≥15 years | Men: 15–29 years | 1.0 | 0.4 | 150.0 | Average number of days hospitalized during the survey year
Ashford 1973 | 32,219 residents of Exeter, United Kingdom, aged ≥15 years | 30–44 years | 0.9 | 0.8 | 12.5 | Average number of days hospitalized during the survey year
Ashford 1973 | 32,219 residents of Exeter, United Kingdom, aged ≥15 years | 45–59 years | 0.8 | 0.6 | 25.0 | Average number of days hospitalized during the survey year
Ashford 1973 | 32,219 residents of Exeter, United Kingdom, aged ≥15 years | ≥60 years | 1.0 | 0.7 | 42.9 | Average number of days hospitalized during the survey year
Ashford 1973 | 32,219 residents of Exeter, United Kingdom, aged ≥15 years | Women: 15–29 years | 1.8 | 1.2 | 50.0 | Average number of days hospitalized during the survey year
Ashford 1973 | 32,219 residents of Exeter, United Kingdom, aged ≥15 years | 30–44 years | 1.2 | 1.1 | 9.1 | Average number of days hospitalized during the survey year
Ashford 1973 | 32,219 residents of Exeter, United Kingdom, aged ≥15 years | 45–59 years | 0.9 | 0.8 | 12.5 | Average number of days hospitalized during the survey year
Ashford 1973 | 32,219 residents of Exeter, United Kingdom, aged ≥15 years | ≥60 years | 1.2 | 1.5 | −20.0 | Average number of days hospitalized during the survey year
Oakes et al. 1974 | 2,557 HMO enrollees, aged >20 years | Men: 20–39 years | 9 | 6 | 50.0 | Percentage hospitalized during the past year
Oakes et al. 1974 | 2,557 HMO enrollees, aged >20 years | 40–59 years | 7 | 8 | −12.5 | Percentage hospitalized during the past year
Oakes et al. 1974 | 2,557 HMO enrollees, aged >20 years | ≥60 years | 26 | 11 | 136.4 | Percentage hospitalized during the past year
Oakes et al. 1974 | 2,557 HMO enrollees, aged >20 years | Women: 20–39 years | 14 | 17 | −17.6 | Percentage hospitalized during the past year
Oakes et al. 1974 | 2,557 HMO enrollees, aged >20 years | 40–59 years | 6 | 10 | −40.0 | Percentage hospitalized during the past year
Oakes et al. 1974 | 2,557 HMO enrollees, aged >20 years | ≥60 years | 13 | 15 | −13.3 | Percentage hospitalized during the past year
Coronary Drug Project Research Group 1976 | 2,789 men with a history of myocardial infarction, aged 30–64 years at baseline | Total | 55.2 | 49.7 | 11.1 | 5-year hospitalization rates
Vogt and Schweitzer 1985 | 2,582 adult HMO enrollees | Total | 801.5 | 668.6 | 19.9 | Nonobstetric hospital days
Chetwynd and Rayner 1986 | 978 women, aged 18–60 years | Hospitalized | 0.22 | 0.15 | 46.7 | Smokers = ever smokers
Chetwynd and Rayner 1986 | 978 women, aged 18–60 years | Emergency admissions | 0.09 | 0.06 | 50.0 | Smokers = ever smokers
Rice et al. 1986 | 1979 National Health Interview Survey participants | Total | 1.3 | 0.8 | 62.5 | Smokers = ever smokers
Van Peenen et al. 1986 | AMOCO Corporation white male employees | Total | 2.7 | 2.4 | 12.5 | Average number of insurance claims during the second quarter of 1984, the number submitted divided by the number eligible (for whom smoking habits were known) multiplied by 100, then adjusted for age; the difference is smaller after adjusting for age
Freeborn et al. 1990 | 515 HMO enrollees, aged >65 years | Group I (1970–1974) | 0.17 | 0.15 | 13.3 | Hospital admissions per year
Freeborn et al. 1990 | 515 HMO enrollees, aged >65 years | Group II (1970–1979) | 0.17 | 0.15 | 13.3 | Hospital admissions per year
Penner and Penner 1990 | 20,831 employees enrolled in a fee-for-service plan | Total | | | | None
Penner and Penner 1990 | 20,831 employees enrolled in a fee-for-service plan | Admissions per 1,000 employees | 126.66 | 75.82 | 63.1 | None
Penner and Penner 1990 | 20,831 employees enrolled in a fee-for-service plan | Days per 1,000 employees | 800.39 | 381.21 | 110.0 | None
Penner and Penner 1990 | 20,831 employees enrolled in a fee-for-service plan | Average length of stay (days) | 6.47 | 5.03 | 38.6 | None
Kaplan et al. 1992 | 630 residents of a southern California community, aged >65 years | Total | 42.3 | 31.9 | 32.6 | Age-adjusted hospitalization rates Prospective study
Halpern and Warner 1994 | 1990 U.S. National Health Interview Survey participants | Total | 1.30 | 1.00 | 30.0 | ORs for hospital admissions
Terry et al. 1998 | 5,780 HMO enrollees (n = 3,825, aged 18–64 years; n = 1,955, aged ≥65 years) | Aged <65 years | 6 | 8 | −25.0 | Percentage with any inpatient service
Terry et al. 1998 | 5,780 HMO enrollees (n = 3,825, aged 18–64 years; n = 1,955, aged ≥65 years) | Aged ≥65 years | 6 | 15 | −60.0 | Percentage with any inpatient service
Terry et al. 1998 | 5,780 HMO enrollees (n = 3,825, aged 18–64 years; n = 1,955, aged ≥65 years) | Aged <65 years | $113 | $ 95 | 18.9 | Charges per month
Terry et al. 1998 | 5,780 HMO enrollees (n = 3,825, aged 18–64 years; n = 1,955, aged ≥65 years) | Aged ≥65 years | 324 | 258 | 25.6 | Charges per month
Miller et al. 1999 | 1987 National Medical Expenditure Survey, n = 38,446 | Total | 0.1236 | 0.1113 | 11.1 | Probability of having a hospital expense

* HMO = Health maintenance organization.

† NR = Data were not reported.

‡ OR = Odds ratio.

Two studies not included in Table 6.8 are also relevant. In a population of retirees followed for one year, smoking was associated with added health care costs of more than $1,900 per year per pack of cigarettes smoked per day, after adjusting for age, gender, education, seat belt use, and alcohol consumption (Leigh and Fries 1992). In a study conducted as part of a worksite health promotion program in Birmingham, Alabama, smokers were found to have incurred more costs than nonsmokers, but the data were not presented (Weaver et al. 1998).

##### Outpatient Services

In several studies (Table 6.8), smokers were at least 15 percent more likely than nonsmokers to use outpatient services (Peters and Ferris 1967; Palmore 1970; Chetwynd and Rayner 1986; Freeborn et al. 1990); one study found an increased likelihood of 6 percent (Rice et al. 1986). In studies that stratified age and gender, strong associations with smoking were observed in particular groups. Male smokers were more frequent users of outpatient services than were male nonsmokers, but this difference was not found among females in one study (Oakes et al. 1974). In another study, this gender difference occurred in young but not old persons (Ashford 1973). Three studies showed only small differences in the use of outpatient services between smokers and nonsmokers (Vogt and Schweitzer 1985; Halpern and Warner 1994; Miller et al. 1999).

The frequency of outpatient visits does not appear to increase with the number of cigarettes smoked (Peters and Ferris 1967; Balarajan et al. 1985; Marsden et al. 1988). However, regardless of the number of cigarettes smoked, some studies documented a large difference in the number of visits by smokers compared with nonsmokers.

##### Hospitalization

In all but one of the studies considered (Terry et al. 1998), smokers had higher hospitalization rates than nonsmokers; the differences were at least 10 percent. In two other studies that stratified age and gender, one study found an association in males but not in females (Oakes et al. 1974), and the other study found an association only among younger females (Ashford 1973).

Additional studies corroborate the results summarized in Table 6.8. In a study of a cohort of retirees followed for one year, the number of packs of cigarettes smoked per day was significantly associated with the number of days hospitalized (Leigh and Fries 1992). In a study of 1,000 veterans accessing the Veterans Administration system in Connecticut, tobacco users were significantly more likely (p <0.01) than nonusers to be hospitalized, and tobacco users were significantly more likely (p<0.01) than nonusers to be hospitalized and to spend more days in the hospital (Benedetto et al. 1998). In a study of Kaiser Permanente enrollees in Oregon, Pope (1982) observed a weak, non-significant correlation between a smoking index and hospitalization rates in the youngest age group for men and women (aged <35 years), but this association was not present in the other age groups studied.

Dose-response data are available from two prospective cohort studies (Table 6.9). In the Coronary Drug Project, the five-year hospitalization rates for smokers compared with nonsmokers plateaued at the lowest smoking category, and were more compatible with a threshold relationship than with a nonthreshold dose-response relationship. However, it was unclear whether these analyses accounted for the higher mortality rates experienced by smokers relative to nonsmokers during the follow-up period (Coronary Drug Project Research Group 1976). In a two-year follow-up of smokers in the American Cancer Society Cancer Prevention Study I (CPS-I) a strong dose-response relationship was present: compared with those who smoked 1 to 9 cigarettes per day, those who smoked 10 to 19, 20 to 39, and 40 or more cigarettes per day had an increased likelihood of hospitalization during the follow-up period of 8.5 percent, 14.6 percent, and 28.0 percent, respectively (Hammond 1965). In a cross-sectional survey of U.S. military personnel that compared smokers with nonsmokers, those who smoked one-half of a pack or less, one pack, and one and one-half packs or more per day had increases in self-reported days hospitalized of 28.1 percent, 6.3 percent, and 54.7 percent, respectively (Marsden et al. 1988).

Table 6.9 Studies on the association between the amount smoked and medical service utilization rates

Study | Population | Group | Percentage difference | | | | Comments
Study | Population | Group | Nonsmokers (referent) | Smokers, by category of dose (1 = low) | | | Comments
Study | Population | Group | Nonsmokers (referent) | 1 | 2 | 3 | Comments
5-year hospitalization rates
Hammond 1965 | 69,069 male smokers, U.S. men aged 50–69 years | Total | Not applicable | Referent | 8.5 | 14.6 | None
Coronary Drug Project Research Group 1976 | 2,789 men with a history of myocardial infarction, aged 30–64 years at baseline | Total | 0 | 13.9 | 8.7 | 11.5 | None
Marsden et al. 1988 | 17,328 active U.S. military personnel, aged >17 years | Total | 0 | 28.1 | 6.3 | 54.7 | Days hospitalized in the past year
Medical encounters during the past 30 days
Peters and Ferris 1967 | Harvard/Radcliffe students | Total | 0 | 33.9 | 21.1 | 30.3 | Years smoked
Balarajan et al. 1985 | United Kingdom General Household Survey, 1980, participants | Outpatient visits Consultations with a physician | 0 | 46.0 | 46.0 | 43.0 | None
Balarajan et al. 1985 | United Kingdom General Household Survey, 1980, participants | Outpatient visits Consultations with a physician | 0 | 12.0 | 8.0 | 9.0 | None
Marsden et al. 1988 | 17,328 active U.S. military personnel, aged >17 years | Total | 0 | −1.7 | 6.2 | 31.1 | Number of cigarettes per day in the past year

##### Former Smokers

Studies comparing the use of medical services by former smokers with lifetime nonsmokers are summarized in Table 6.10. Costs were 26 percent higher for former smokers in one study (Pronk et al. 1999), and higher for some services but not higher overall in another study (Vogt and Schweitzer 1985). In every study, former smokers were more likely than lifetime nonsmokers to use outpatient services. In a study conducted in the United Kingdom that was stratified by age and gender, smokers were more likely than non-smokers to have general practice health care providers visit their homes for an illness (Ashford 1973). The use of outpatient services by smokers remained elevated compared with that of nonsmokers long after smoking cessation (Halpern and Warner 1994). For hospitalizations the findings were mixed, with three studies showing higher rates in former smokers (Van Peenen et al. 1986; Kaplan et al. 1992; Halpern and Warner 1994). In one of these studies, however, the difference was eliminated after adjusting for age, and in two other studies there were only small differences between former smokers and lifetime nonsmokers. In another study that stratified age and gender, former smokers were more likely than lifetime nonsmokers to be hospitalized in some strata, but less likely in others, without a consistent pattern (Ashford 1973).

Table 6.10 Studies on the association between former smoking and medical services utilization costs and rates

Study | Population | Group | Results | | | Comments
Study | Population | Group | Former smokers | Nonsmokers | Percentage difference | Comments
Costs
Vogt and Schweitzer 1985 | 2,582 adult HMO^*^ enrollees | Laboratory | $21,150 | $19,772 | 7.0 | None
Vogt and Schweitzer 1985 | 2,582 adult HMO^*^ enrollees | X-ray | 13,419 | 11,958 | 12.2 | None
Vogt and Schweitzer 1985 | 2,582 adult HMO^*^ enrollees | Surgery | 8,639 | 6,923 | 24.8 | None
Vogt and Schweitzer 1985 | 2,582 adult HMO^*^ enrollees | Total | 94,254 | 93,326 | 1.0 | None
Pronk et al. 1999 | 6,589 adult HMO enrollees, Minnesota | Total | NR^†^ | NR | 25.8 | Absolute values were not reported; adjusted for age, gender, race, body mass index, physical activity, and comorbidity conditions
Outpatient services
Peters and Ferris 1967 | Harvard/Radcliffe college students | Total | 10.09 | 7.52 | 34.2 | Clinic visits, Harvard, 1964–1965
Ashford 1973 | 32,219 residents of Exeter, United Kingdom, aged >15 years | Home visits | | | | Number of visits during the survey year
Ashford 1973 | 32,219 residents of Exeter, United Kingdom, aged >15 years | Men: 15–29 years | 0.28 | 0.17 | 64.7 | Number of visits during the survey year
Ashford 1973 | 32,219 residents of Exeter, United Kingdom, aged >15 years | 30–44 years | 0.28 | 0.18 | 55.6 | Number of visits during the survey year
Ashford 1973 | 32,219 residents of Exeter, United Kingdom, aged >15 years | 45–59 years | 0.46 | 0.33 | 39.4 | Number of visits during the survey year
Ashford 1973 | 32,219 residents of Exeter, United Kingdom, aged >15 years | ≥60 years | 2.1 | 2.3 | −8.7 | Number of visits during the survey year
Ashford 1973 | 32,219 residents of Exeter, United Kingdom, aged >15 years | Women: 15–29 years | 2.7 | 1.1 | 145.5 | Number of visits during the survey year
Ashford 1973 | 32,219 residents of Exeter, United Kingdom, aged >15 years | 30–44 years | 0.78 | 0.64 | 21.9 | Number of visits during the survey year
Ashford 1973 | 32,219 residents of Exeter, United Kingdom, aged >15 years | 45–59 years | 0.58 | 0.49 | 18.4 | Number of visits during the survey year
Ashford 1973 | 32,219 residents of Exeter, United Kingdom, aged >15 years | ≥60 years | 3.3 | 2.2 | 50.0 | Number of visits during the survey year
Ashford 1973 | 32,219 residents of Exeter, United Kingdom, aged >15 years | Hospital outpatient | | | | Number of visits during the survey year
Ashford 1973 | 32,219 residents of Exeter, United Kingdom, aged >15 years | Men: 15–29 years | 0.69 | 0.45 | 53.3 | Number of visits during the survey year
Ashford 1973 | 32,219 residents of Exeter, United Kingdom, aged >15 years | 30–44 years | 0.37 | 0.38 | −2.6 | Number of visits during the survey year
Ashford 1973 | 32,219 residents of Exeter, United Kingdom, aged >15 years | 45–59 years | 0.39 | 0.46 | −15.2 | Number of visits during the survey year
Ashford 1973 | 32,219 residents of Exeter, United Kingdom, aged >15 years | ≥60 years | 0.69 | 0.57 | 21.1 | Number of visits during the survey year
Ashford 1973 | 32,219 residents of Exeter, United Kingdom, aged >15 years | Women: 15–29 years | 0.56 | 0.46 | 21.7 | Number of visits during the survey year
Ashford 1973 | 32,219 residents of Exeter, United Kingdom, aged >15 years | 30–44 years | 0.44 | 0.45 | −2.2 | Number of visits during the survey year
Ashford 1973 | 32,219 residents of Exeter, United Kingdom, aged >15 years | 45–59 years | 0.73 | 0.52 | 40.4 | Number of visits during the survey year
Ashford 1973 | 32,219 residents of Exeter, United Kingdom, aged >15 years | ≥60 years | 0.57 | 0.59 | −3.4 | Number of visits during the survey year
Oakes et al. 1974 | 2,557 HMO enrollees, aged >20 years | Men: Total | 3.3 | 2.8 | 17.9 | Mean number of office visits during the past year
Oakes et al. 1974 | 2,557 HMO enrollees, aged >20 years | 20–39 years | 2.7 | 2.4 | 12.5 | Mean number of office visits during the past year
Oakes et al. 1974 | 2,557 HMO enrollees, aged >20 years | 40–59 years | 2.9 | 2.4 | 20.8 | Mean number of office visits during the past year
Oakes et al. 1974 | 2,557 HMO enrollees, aged >20 years | ≥60 years | 4.3 | 3.9 | 10.3 | Mean number of office visits during the past year
Oakes et al. 1974 | 2,557 HMO enrollees, aged >20 years | Women: Total | 5.9 | 4.8 | 22.9 | Mean number of office visits during the past year
Oakes et al. 1974 | 2,557 HMO enrollees, aged >20 years | 20–39 years | 5.1 | 5.4 | −5.6 | Mean number of office visits during the past year
Oakes et al. 1974 | 2,557 HMO enrollees, aged >20 years | 40–59 years | 7.4 | 4.0 | −85.0 | Mean number of office visits during the past year
Oakes et al. 1974 | 2,557 HMO enrollees, aged >20 years | ≥60 years | 5.0 | 5.0 | 0.0 | Mean number of office visits during the past year
Balarajan et al. 1985 | 1980 General Household Survey, United Kingdom | Outpatient visits | | | | OR^†^ for prevalence of chronic illness after adjustment for age, gender, and socioeconomic group
Balarajan et al. 1985 | 1980 General Household Survey, United Kingdom | Stopped >1 year | 1.40 | 1.0 | 40.0 | OR^†^ for prevalence of chronic illness after adjustment for age, gender, and socioeconomic group
Balarajan et al. 1985 | 1980 General Household Survey, United Kingdom | Stopped <1 year | 1.25 | 1.0 | 25.0 | OR^†^ for prevalence of chronic illness after adjustment for age, gender, and socioeconomic group
Balarajan et al. 1985 | 1980 General Household Survey, United Kingdom | Consultations with a physician | | | | OR^†^ for prevalence of chronic illness after adjustment for age, gender, and socioeconomic group
Balarajan et al. 1985 | 1980 General Household Survey, United Kingdom | Stopped >1 year | 1.19 | 1.0 | 19.0 | OR^†^ for prevalence of chronic illness after adjustment for age, gender, and socioeconomic group
Balarajan et al. 1985 | 1980 General Household Survey, United Kingdom | Stopped <1 year | 1.47 | 1.0 | 47.0 | OR^†^ for prevalence of chronic illness after adjustment for age, gender, and socioeconomic group
Vogt and Schweitzer 1985 | 2,482 adult HMO enrollees | Total | 4,115 | 3,667 | 12.2 | Total office visits
Halpern and Warner 1994 | 1990 U.S. National Health Interview Survey participants | Quit 0–2 months | 1.20 | 1.0 | 20.0 | OR for the number of physician visits during the past year
Halpern and Warner 1994 | 1990 U.S. National Health Interview Survey participants | Quit 3 months–1 year | 1.47 | 1.0 | 47.0 | OR for the number of physician visits during the past year
Halpern and Warner 1994 | 1990 U.S. National Health Interview Survey participants | Quit 2–4 years | 1.32 | 1.0 | 32.0 | OR for the number of physician visits during the past year
Halpern and Warner 1994 | 1990 U.S. National Health Interview Survey participants | Quit 5–10 years | 1.24 | 1.0 | 24.0 | OR for the number of physician visits during the past year
Halpern and Warner 1994 | 1990 U.S. National Health Interview Survey participants | Quit 11–19 years | 1.25 | 1.0 | 25.0 | OR for the number of physician visits during the past year
Halpern and Warner 1994 | 1990 U.S. National Health Interview Survey participants | Quit ≥20 years | 1.18 | 1.0 | 18.0 | OR for the number of physician visits during the past year
Hospitalizations/inpatient services
Ashford 1973 | 32,219 residents of Exeter, United Kingdom, aged >15 years | Men: 15–29 years | 1.0 | 0.4 | 150.0 | Average number of days hospitalized during the year
Ashford 1973 | 32,219 residents of Exeter, United Kingdom, aged >15 years | 30–44 years | 0.2 | 0.8 | −75.0 | Average number of days hospitalized during the year
Ashford 1973 | 32,219 residents of Exeter, United Kingdom, aged >15 years | 45–59 years | 0.4 | 0.6 | −33.3 | Average number of days hospitalized during the year
Ashford 1973 | 32,219 residents of Exeter, United Kingdom, aged >15 years | ≥60 years | 1.4 | 0.7 | 100.0 | Average number of days hospitalized during the year
Ashford 1973 | 32,219 residents of Exeter, United Kingdom, aged >15 years | Women: 15–29 years | 1.7 | 1.2 | 41.7 | Average number of days hospitalized during the year
Ashford 1973 | 32,219 residents of Exeter, United Kingdom, aged >15 years | 30–44 years | 1.0 | 1.1 | −9.1 | Average number of days hospitalized during the year
Ashford 1973 | 32,219 residents of Exeter, United Kingdom, aged >15 years | 45–59 years | 1.9 | 0.8 | 137.5 | Average number of days hospitalized during the year
Ashford 1973 | 32,219 residents of Exeter, United Kingdom, aged >15 years | ≥60 years | 1.55 | 1.5 | 0.0 | Average number of days hospitalized during the year
Vogt and Schweitzer 1985 | 2,582 adult HMO enrollees | Total | 704.3 | 668.6 | 5.3 | Nonobstetric hospital days
Van Peenen et al. 1986 | AMOCO Corporation white male employees | Total | 3.0 | 2.4 | 25.0 | There was no difference after adjusting for age
Kaplan et al. 1992 | 630 residents of a southern California community, aged >65 years | Total | 41.0 | 31.9 | 28.5 | Age-adjusted rates of hospitalization; prospective study
Halpern and Warner 1994 | 1990 U.S. National Health Interview Survey participants | Quit 0–2 months | 1.79 | 1.0 | 79.0 | ORs for hospital admissions
Halpern and Warner 1994 | 1990 U.S. National Health Interview Survey participants | Quit 3 months–1 year | 2.59 | 1.0 | 159.0 | ORs for hospital admissions
Halpern and Warner 1994 | 1990 U.S. National Health Interview Survey participants | Quit 2–4 years | 1.25 | 1.0 | 25.0 | ORs for hospital admissions
Halpern and Warner 1994 | 1990 U.S. National Health Interview Survey participants | Quit 5–10 years | 1.32 | 1.0 | 32.0 | ORs for hospital admissions
Halpern and Warner 1994 | 1990 U.S. National Health Interview Survey participants | Quit 11–19 years | 1.04 | 1.0 | 4.0 | ORs for hospital admissions
Halpern and Warner 1994 | 1990 U.S. National Health Interview Survey participants | Quit ≥20 years | 1.0 | 1.0 | −3.0 | ORs for hospital admissions
Terry et al. 1998 | 5,780 HMO enrollees, aged >18 years | Age <65 years | 7 | 8 | −12.5 | Percentage with any inpatient use
Terry et al. 1998 | 5,780 HMO enrollees, aged >18 years | Age ≥65 years | 16 | 15 | 6.7 | Percentage with any inpatient use

* HMO = Health maintenance organization.

† NR = Data were not reported.

† OR = Odds ratio.

These studies generally have not taken into account prior smoking history and time since quitting, nor have they considered whether development of a disease led to quitting. The extent of smoking before quitting is a determinant of risk, and risks fall for many diseases as the duration of quitting lengthens. The somewhat inconsistent findings may reflect (1) the heterogeneity of former smokers in these studies and (2) analysis strategies that did not fully account for risk determinants in the former smokers. In an analysis of the 1990 National Health Interview Survey data that accounted for time since quitting, former smokers had significantly more hospital admissions until 10 years following cessation, at which point former smokers and lifetime nonsmokers had similar numbers of hospital admissions (Halpern and Warner 1994).

The clinical trials of Wagner and colleagues (1995) provide additional evidence. Two cessation trials followed participants and collected medical care utilization data. After six years of follow-up, quitters experienced reductions in outpatient visits, hospital admissions, and hospital days in both trials compared with persistent smokers. In contrast, medical care utilization continued to increase among persistent smokers: 7 to 15 percent for outpatient visits, 30 to 45 percent for hospital admissions, and 75 to 100 percent for days spent in the hospital. These divergent patterns in the use of medical care services resulted in substantially greater rates of hospitalization, hospital days, and outpatient visits for persistent smokers.

##### Age

Several studies suggest that smoking may have a greater impact on the youngest age groups compared with older age groups. More frequent use of outpatient (Peters and Ferris 1967; Newcomb and Bentler 1987) and inpatient (Newcomb and Bentler 1987) services among smokers than among nonsmokers has been observed even in adolescents and young adults, suggesting that the differences observed in smoking and nonsmoking older adults are not solely a result of smoking-induced diseases. In fact, in a few studies higher levels of service utilization were observed among smokers than among nonsmokers in the younger age groups, but such differences were either not present or were reversed in the oldest age groups. This pattern is evident in the cross-sectional analyses of the 1970 U.S. National Health Interview Survey data, a random sample of U.S. households in which both smoking men and smoking women had a markedly higher number of days hospitalized per year than their nonsmoking counterparts until they reached their mid-40s, at which point the differences between smokers and nonsmokers became more subtle (Weinkam et al. 1987).

In general, compared with nonsmokers, smokers tend to incur more medical costs, to see physicians more often in the outpatient setting, and to be admitted to the hospital more often. Among patients admitted to the hospital, smokers have longer lengths of stay and incur greater expenses per admission than nonsmokers. Less information is available concerning the use of medical services such as prescription drugs and emergency department visits, but increases for smokers compared with nonsmokers have also been observed with respect to these outcomes (Chetwynd and Rayner 1986; Miller et al. 1999). Although smokers use more palliative care services, as demonstrated by this review, smokers have been less likely than non-smokers to use preventive services such as multiphasic testing (Oakes et al. 1974) and screening (Beaulieu et al. 1996; Edwards and Boulet 1997).

#### Postoperative Complications

In comparison with nonsmokers, smokers have been hypothesized to be at a higher risk for postoperative complications because of a greater frequency of chronic diseases, impaired pulmonary reserve, altered immune responses, and impaired wound healing. Higher rates of postoperative complications in smokers could contribute to the greater costs that they incur for health care services.

Substantial clinical and experimental research has been conducted on the relevant effects of smoking on host defenses, immune responses, and wound healing. As reviewed elsewhere in this report and in a previous Surgeon General’s report (USDHHS 1990), smoking produces a range of effects on respiratory defense mechanisms that may increase the risk for postoperative pneumonia. Compromised lung function and the presence of COPD increase the risks for respiratory complications, including respiratory failure. The increased likelihood of coronary heart disease (CHD) in smokers increases the risk for cardiac events during and after surgery. In animal and clinical models, exposure to tobacco smoke and nicotine specifically impaired aspects of wound healing (Brown et al. 1986; Silcox et al. 1995; Haverstock and Mandracchia 1998; Jorgensen et al. 1998; Hollinger et al. 1999).

The literature on postoperative complications is extensive and diverse in the scope of complications associated with smoking. Table 6.11 provides evidence for lower survival rates after surgery for smokers compared with nonsmokers and suggests that this increased mortality may reflect a range of specific and nonspecific consequences of smoking, including a greater risk for postoperative complications related to the surgery. A number of reports address specific surgical complications such as flap failures, wound infections, and poor orthopedic outcomes. A similarly diverse set of reports consistently shows that smoking also increases the risk of respiratory complications.

Table 6.11 Studies on the association between smoking and complications of surgery

Study | Population | Outcome studied | Results
Postoperative and wound-healing complications
Abidi et al. 1998 | Retrospective study, 63 consecutive patients with fractures of the calcaneus who underwent open reduction and internal fixation during a 3-year period | Postoperative and wound complications | A history of active smoking was correlated with an increase in time to heal the wound in the outpatient group; risk factors for wound complications: high body mass index, extended time between injury and surgery, smoking, and single layered closure
Golosow et al. 1999 | Retrospective study, 91 patients with sternal wound-healing complications between January 1990 and December 1996, seen at the Indiana University Medical Center and affiliated hospitals | Operative procedure and outcome | Smoking history, chronic obstructive pulmonary disease, steroid use, previous sternotomy, age, diabetes, operation time, emergency operation, elevated white blood cell count, fever, and positive wound or blood cultures all correlated with one another
Goodman et al. 1999 | Retrospective study, 48 spinal cord-injured patients with pressure ulcers, seen at a tertiary referral Veterans hospital between 1992 and 1997 | Wound healing and postoperative complications | Chronic smokers had longer courses of antibiotic therapy, but smoking did not correlate with other variables, including wound-healing complications
Spelman et al. 2000 | 693 patients undergoing CABG^*^ between December 1, 1996, and November 30, 1997 | Surgical wound infections (SWIs) and post- operative bacteremia | Diabetes, obesity, and previous cardiovascular procedures were independent predictors of SWIs, and obesity was a risk factor for bacteremia
Postoperative complications
Ashraf et al. 1995 | 48 consecutive patients who underwent cardiovascular surgery | Mortality | Smoking was related to later mortality (p = 0.04) in a univariate model
Watterson et al. 1995 | 556 women who had transverse rectus abdominis musculocutaneous (TRAM) flap breast reconstruction | Postoperative complications | Risk of hernia formation was higher among those smoking at the time of surgery (p = 0.0001); risk factors for any complication were associated with smoking (p <0.002)
D’Agostino et al. 1996 | Prospective study, 1,835 consecutive patients undergoing first-time isolated CABG between March 1990 and July 1995 in Massachusetts | Postoperative risk of stroke | Smoking was a significant predictor of carotid stenosis (p <0.0001)
Kroll et al. 1996 | 854 consecutive free flaps | Successful outcome | Smoking, age, and previous irradiation had no significant effects on flap failure rates
Samuels et al. 1996 | All patients aged <40 years who had a CABG at the Allegheny University Hospital in Pennsylvania, between July 1990 and June 1995 | Postoperative cardiac-related events | A history of smoking was a risk factor (83%); most patients resumed smoking, did not return to work, and did not take lipid-lowering drugs after surgery
Utley et al. 1996 | Prospective study, 2,916 patients with a history of 1 CABG | Preoperative and postoperative characteristics | Smoking was not predictive of mortality or morbidity; 7.5% of nonsmokers and 4.7% of smokers needed an intra-aortic pump; a recent myocardial infarction was more common in smokers
Arend et al. 1997 | All renal transplants from the Leiden Renal Transplant Database performed between 1966 and 1994 in the Netherlands | Patient survival | A slightly increased mortality risk in the first year after a transplant for smokers, patients aged >40 years, men, and persons with hypertension or diabetes
Boucher et al. 1997 | 329 consecutive patients aged ≥70 years, who had undergone cardiac surgery between January 1990 and December 1993 in a university-affiliated tertiary care hospital in Montreal, Canada | Long-term survival and functional status | Current smoking on admission was associated with postoperative mortality; RR^†^ = 3.6 (95% CI^‡^, 1.4–10.0)
Brooks-Brunn 1997 | Prospective model-building study, convenience sample of 400 patients who underwent abdominal surgical procedures between January 1993 and August 1995 | Postoperative pulmonary complications | Smoking within the past 8 weeks was an independent risk factor (adjusted OR^§^ = 2.27)
Espehaug et al. 1997 | Register-based matched case-control study with 674 cases who had total hip replacements, and 1,343 controls with primary hip operations only, reported to the Norwegian Arthroplasty Register from 1987–1993 | Poor total hip replacement prognosis | Smoking had no overall effect, but former smokers had a 2.8 increased risk compared with nonsmokers
Gentile et al. 1997 | 93 patients with at least 6 months of postoperative surveillance, identified through a vascular registry | Intrinsic vein graft stenosis (postoperative) in lower extremities | Smoking was associated with the development of a vein graft flow disturbance (p = 0.03)
Lindquist et al. 1997 | Prospective study, 45 edentulous patients (21 smokers and 24 nonsmokers), followed for 10 years after treatment with a fixed implant-supported prosthesis in the mandible | Bone loss around mandibular implants | Mean bone loss around mandible was approximately 1 mm greater in smokers than in nonsmokers and related to the amount of cigarette smoking; smokers with poor oral hygiene were at a greater risk, especially for peri-implant bone loss
Nettleman et al. 1997 | Retrospective study, 266 patients | Mortality from postoperative myocardial infarction | Current smoking was an independent risk factor (RR = 2.3 [95% CI, 1.2–4.7])
Rockman et al. 1997 | 606 patients (183 patients with preoperative strokes compared with 423 who only experienced transient ischemic attacks [TIAs]), who underwent consecutive carotid endarterectomies from 1988–1993 in New York | Perioperative stroke rates after endarterectomy | Patients with preoperative strokes who smoked had a greater risk for a perioperative stroke compared with those with asymptomatic TIAs or who experienced only TIAs (52 vs. 40.6%, p = 0.01)
Sasajima et al. 1997 | Retrospective study, 71 patients (97% smokers) who had autogenous vein bypasses in Japan | Patency rates (blood flow in veins remaining open) | The nonsmoking group had higher rates than the smoking group (66.8 vs. 34.7%, p <0.05)
Bluman et al. 1998 | Prospective cohort study, 410 patients scheduled for noncardiac elective surgery at the Veterans Administration Medical Center in Syracuse, New York | Postoperative pulmonary complications | Complications occurred in 22% of current smokers, 12.8% of former smokers, and 4.9% of nonsmokers; adjusted OR = 5.5 (95% CI, 1.9–16.2) for current smokers vs. nonsmokers, 4.2 (95% CI, 1.2–14.8) for former smokers; OR for current smokers who reduced their smoking 1 month before surgery = 6.7 (95% CI, 2.6–17.1)
Medina et al. 1998 | Retrospective study, 62 patients (40 with Crohn’s disease [CD] and 22 with ulcerative colitis [UC]) with previous surgery for inflammatory bowel disease, compared with 202 patients (69 with CD and 133 with UC) in a control group with inflammatory bowel disease but without previous surgery | Development of inflammatory bowel disease in patients with CD and UC | The number and type of complications after surgery were not related to smoking habits; inflammatory bowel disease recurred earlier in smokers among the CD patients (p >0.05)
Fujisawa et al. 1999 | 369 patients with stage I non-small-cell lung carcinoma | 10-year survival rate | Increased mortality risk with increasing age and >30 pack-yearsΔ of smoking
Kinsella et al. 1999 | Retrospective study, 91 patients (38 current smokers, 12 former smokers, and 41 nonsmokers) with facial skin defects reconstructed with local flaps | Postoperative complications | 23 patients (25%) had complications (smokers = 37%, former smokers = 17%, and nonsmokers = 17%; p <0.03); all full-thickness skin losses and cellulitis occurred in active smokers; former smokers had a complication rate similar to that of nonsmokers
Lavernia et al. 1999 | 202 patients (25 smokers and 177 nonsmokers) undergoing arthroplasty of the hip and knee | Short-term complications, resource consumption, length of hospital stay | Smokers, compared with nonsmokers, were younger and had fewer comorbidities, significantly longer surgical times, higher charges, and required more anesthesia (maybe for a more severe illness); former smokers had better short-term outcomes than did current smokers
Pereira et al. 1999 | 408 patients in a tertiary university hospital, analyzed prospectively for preoperative and postoperative pulmonary complications in Brazil | Pulmonary function and complication rate | Postoperative complication rate = 14%; predictors in univariate analyses: age >50 years, smoking, presence of chronic pulmonary disease, surgery duration >210 minutes, and comorbidity (p <0.04)
Sinclair et al. 1999 | 17,638 consecutive outpatients who had surgery | Postoperative nausea and vomiting | Smoking was an independent risk factor; age, gender, duration and type of anesthesia, previous postoperative nausea and vomiting, and surgery type also were independent risk factors
Sorensen et al. 1999 | 333 unselected consecutive patients between January 1993 and October 1996 in 1 surgical department, who underwent colon or rectal resection with anastomosis in Denmark | Anastomotic leakage | Smokers had increased risks compared with nonsmokers (RR = 3.18 [95% CI, 1.44–7.00])
Warner et al. 1999 | 135 patients undergoing abdominal surgery with a history of smoking or reduced pulmonary function | Pulmonary function and complications | Pack-years of smoking, age, site of incision, and current smoking status were predictors of airway obstruction bronchospasm (OR = 6.9 [95% CI, 1.2–38.4]); pack-years of smoking were not associated with the need for endotracheal intubation (OR = 1.1 [95% CI, 0.4–3.2]) or with prolonged intensive care or readmission
Chan et al. 2000 | 67 consecutive patients (84% smokers) who underwent surgical resection of esophageal carcinoma from January 1989 to December 1996 | 5-year survival rate | Poor outcomes (18% survival rate) mainly because most tumors were in advanced stages when resected
Chimbira and Sweeney 2000 | 327 consecutive patients (85 smokers and 242 nonsmokers) undergoing arthroscopic knee surgery, who had standard anesthetic pre- and postoperative drugs | Postoperative nausea and vomiting | 6% of smokers compared with 15% of nonsmokers were affected (p <0.05)
Kotani et al. 2000 | 30 smoking and 30 nonsmoking patients who had propofol-fentanyl general anesthesia in Japan | Types of alveolar immune cell and macrophage aggregation | Smoking was associated with macrophage aggregation, but with markedly reduced phagocytic and microbicidal activity
Wetterslev et al. 2000 | Healthy cardiopulmonary patients who had combined general and thoracic epidural anesthesia for abdominal surgery | Postoperative hypoxemia and complications | Smoking ≥20 pack-years was associated with a 47% higher incidence compared with smoking <20 pack-years (p <0.006)
Wound-healing complications
Camilleri et al. 1996 | 111 consecutive recipients of Becker breast expanders | Wound infection | Heavy smoking was a risk factor (p <0.05)
Erdmann et al. 1997 | 66 patients with flaps raised from the posteromedial border of the leg | Wound healing | Peripheral vascular disease and heavy smoking were contributory factors to suboptimal healing
Takeishi et al. 1997 | 114 patients who had transverse rectus abdominis musculocutaneous (TRAM) flap breast reconstruction in Japan | Wound healing complications | Smoking was associated with a greater risk (p = 0.03)

* CABG = Coronary artery bypass graft.

† RR = Relative risk.

‡ CI = Confidence interval.

§ OR = Odds ratio.

Δ Pack-years = The number of years of smoking multiplied by the number of packs of cigarettes smoked per day.

#### Health Status

Comparisons of self-rated health statuses in smokers and nonsmokers provide further evidence of the global effects of smoking on health. Although self-ratings are inherently subjective, they provide direct evidence of the relationship of smoking to a diminished health status. Consonant with the complex concept of “health,” health status is itself a multidimensional construct, challenging to measure and approached with varied measurement methods, including direct questions on perceived health status and standardized scales. For example, the Short Form 36 (SF-36) is a standardized, 36-item scale that measures eight dimensions of health (Lyons et al. 1994), three of which have a direct relevance to this review: general health perceptions (five items), physical health (four items), and mental health (five items). Table 6.12 (smokers versus nonsmokers), Table 6.13 (dose-responses), and Table 6.14 (former smokers versus non-smokers) summarize the evidence. Studies were grouped according to the aspect of health status measured: symptoms/illnesses/health complaints, perceived health status (poor/good), physical function, physical status, general health status, life satisfaction/ dissatisfaction, well-being, quality of life, tiredness, and mental health. In some studies “poor” health was measured whereas in others “good” health was measured, so the anticipated directions of the effects of smoking vary with the specified outcome.

Table 6.12 Studies comparing the health status of smokers and nonsmokers

Study | Population | Group | Results | | | Comments
Study | Population | Group | Smokers | Nonsmokers | Percentage difference | Comments
Mean number of illness episodes during the past year
Chetwynd and Rayner 1986 | Survey of 978 women who worked at home, Christchurch, New Zealand, aged 18–60 years | Total | 3.31 | 2.56 | 29.3 | None
Chetwynd and Rayner 1986 | Survey of 978 women who worked at home, Christchurch, New Zealand, aged 18–60 years | Aged 18–29 years | 3.58 | 2.58 | 38.8 | None
Chetwynd and Rayner 1986 | Survey of 978 women who worked at home, Christchurch, New Zealand, aged 18–60 years | Aged 30–44 years | 3.14 | 2.57 | 22.2 | None
Chetwynd and Rayner 1986 | Survey of 978 women who worked at home, Christchurch, New Zealand, aged 18–60 years | Aged 45–60 years | 2.62 | 2.42 | 8.3 | None
Self-reported chronic conditions
Halpern and Warner 1994 | 1990 U.S. National Health Interview Survey, random sample (n = 119,631), aged >17 years | Total | 1.27 | 1.0 | 27.0 | OR^*^
Physical symptoms (% reporting)
Macnee 1991 | 240 men and women, mean age 33 years | Total | 25.2 | 21.5 | 17.2 | None
Physical symptoms (mean number)
York and Hirsch1995 | 425 alcohol drinkers, alcoholics and social drinkers, aged 20–59 years | Alcoholics | | | | Alcoholics were recruited from local alcoholism treatment centers; social drinkers were nominated for participation by alcoholics; teetotalers were excluded
York and Hirsch1995 | 425 alcohol drinkers, alcoholics and social drinkers, aged 20–59 years | Men | 5.11 | 4.75 | 7.6 | Alcoholics were recruited from local alcoholism treatment centers; social drinkers were nominated for participation by alcoholics; teetotalers were excluded
York and Hirsch1995 | 425 alcohol drinkers, alcoholics and social drinkers, aged 20–59 years | Women | 7.11 | 6.14 | 15.8 | Alcoholics were recruited from local alcoholism treatment centers; social drinkers were nominated for participation by alcoholics; teetotalers were excluded
York and Hirsch1995 | 425 alcohol drinkers, alcoholics and social drinkers, aged 20–59 years | Social drinkers | | | | Alcoholics were recruited from local alcoholism treatment centers; social drinkers were nominated for participation by alcoholics; teetotalers were excluded
York and Hirsch1995 | 425 alcohol drinkers, alcoholics and social drinkers, aged 20–59 years | Men | 1.02 | 0.98 | 4.1 | Alcoholics were recruited from local alcoholism treatment centers; social drinkers were nominated for participation by alcoholics; teetotalers were excluded
York and Hirsch1995 | 425 alcohol drinkers, alcoholics and social drinkers, aged 20–59 years | Women | 1.83 | 1.43 | 28.0 | Alcoholics were recruited from local alcoholism treatment centers; social drinkers were nominated for participation by alcoholics; teetotalers were excluded
Self-reported poor health
Palmore 1970 | 268 male volunteers, aged 60–94 years | Total | 28.6 | 22.9 | 24.9 | Percentage that rated their health was worse than the self-perceived average
Wilson and Elinson 1981 | 3,092 adults, aged 20–64 years, National Survey of Personal Health Practices and Consequences | Men | 24.8 | 21.3 | 16.4 | Percentage with a physical health status score of 1–3 (poor)
Wilson and Elinson 1981 | 3,092 adults, aged 20–64 years, National Survey of Personal Health Practices and Consequences | Women | 37.0 | 33.9 | 9.1 | Percentage with a physical health status score of 1–3 (poor)
Seidell et al. 1986 | 455 men and 790 women, aged 26–66 years | Men | 6.8 | 7.3 | −6.8 | Number of health complaints
Seidell et al. 1986 | 455 men and 790 women, aged 26–66 years | Women | 10.2 | 9.0 | 13.8 | Number of health complaints
Pearson et al. 1987 | 864 HMO^†^ enrollees, mean age 52 years | Total | 14.0 | 7.4 | 89.2 | Percentage reporting fair/poor health
Orleans et al. 1989 | 1,163 African American life insurance policyholders, mean age 39 years | Total | 22.5 | 11.3 | 99.1 | Percentage reporting fair/poor health
Halpern and Warner 1994 | 1990 U.S. National Health Interview Survey, random sample (n = 119,631), aged >17 years | Total | 1.62 | 1.0 | 62.0 | OR
Poikolainen et al. 1996 | 6,040 men and women, Finland, aged 25–64 years | Total | 48.8 | 40.7 | 19.9 | Percentage reporting suboptimal health
Bobak et al. 1998 | Sample of 1,599 Russians, aged >18 years | Total | 1.29 | 1.0 | 29.0 | OR was adjusted for age, gender, education, alcohol, and marital status
Pampalon et al. 1999 | 1992–1993 Quebec Health and Social Survey(n = 20,739), mean age 41 years | Total | 1.34 | 1.0 | 34.0 | OR for reporting fair/poor health status
Self-perceived good/excellent health (% reporting)
Colsher et al. 1990 | 4 population-based cohorts, aged >65 years | Men: Iowa | 64.4 | 74.6 | −13.8 | None
Colsher et al. 1990 | 4 population-based cohorts, aged >65 years | East Boston | 58.0 | 69.1 | −16.1 | None
Colsher et al. 1990 | 4 population-based cohorts, aged >65 years | New Haven | 54.8 | 68.8 | −20.9 | None
Colsher et al. 1990 | 4 population-based cohorts, aged >65 years | Piedmont | 42.8 | 60.1 | −28.8 | None
Colsher et al. 1990 | 4 population-based cohorts, aged >65 years | Women: Iowa | 58.3 | 72.6 | −19.7 | None
Colsher et al. 1990 | 4 population-based cohorts, aged >65 years | East Boston | 59.1 | 54.3 | 8.8 | None
Colsher et al. 1990 | 4 population-based cohorts, aged >65 years | New Haven | 55.2 | 60.8 | −9.2 | None
Colsher et al. 1990 | 4 population-based cohorts, aged >65 years | Piedmont | 53.6 | 54.5 | −1.7 | None
York and Hirsch1995 | 425 alcohol drinkers, alcoholics and social drinkers, aged 20–59 years | Alcoholics | | | | Health score
York and Hirsch1995 | 425 alcohol drinkers, alcoholics and social drinkers, aged 20–59 years | Men | 0.43 | 0.65 | −33.8 | Health score
York and Hirsch1995 | 425 alcohol drinkers, alcoholics and social drinkers, aged 20–59 years | Women | 0.76 | 1.29 | −41.1 | Health score
York and Hirsch1995 | 425 alcohol drinkers, alcoholics and social drinkers, aged 20–59 years | Social drinkers | | | | Health score
York and Hirsch1995 | 425 alcohol drinkers, alcoholics and social drinkers, aged 20–59 years | Men | 0.18 | 0.12 | 50.0 | Health score
York and Hirsch1995 | 425 alcohol drinkers, alcoholics and social drinkers, aged 20–59 years | Women | 0.26 | 0.30 | −13.3 | Health score
Self-perceived good physical function (% reporting)
Colsher et al. 1990 | 4 population-based cohorts, aged >65 years | Men: Iowa | 59.1 | 70.5 | −16.2 | None
Colsher et al. 1990 | 4 population-based cohorts, aged >65 years | East Boston | 53.3 | 64.2 | −17.0 | None
Colsher et al. 1990 | 4 population-based cohorts, aged >65 years | New Haven | 64.8 | 71.0 | −8.7 | None
Colsher et al. 1990 | 4 population-based cohorts, aged >65 years | Piedmont | 56.3 | 71.5 | −21.2 | None
Colsher et al. 1990 | 4 population-based cohorts, aged >65 years | Women: Iowa | 42.5 | 61.5 | −30.9 | None
Colsher et al. 1990 | 4 population-based cohorts, aged >65 years | East Boston | 49.4 | 45.8 | 7.9 | None
Colsher et al. 1990 | 4 population-based cohorts, aged >65 years | New Haven | 48.9 | 57.1 | −14.4 | None
Colsher et al. 1990 | 4 population-based cohorts, aged >65 years | Piedmont | 49.4 | 50.9 | −2.9 | None
Physical health status
Belloc and Breslow 1972 | Random sample of Alameda County, California, residents, aged >20 years | Men | 0.51 | 0.47 | 8.5 | Higher scores reflect poorer physical health status measured by ridits (mean rank sums)
Belloc and Breslow 1972 | Random sample of Alameda County, California, residents, aged >20 years | Women | 0.52 | 0.48 | 8.3 | Higher scores reflect poorer physical health status measured by ridits (mean rank sums)
Reed 1983 | 542 HMO enrollees | Total | 0.50 | 0.49 | 2.0 | Higher scores reflect poorer physical health status, measured by ridits (mean rank sums); age and gender adjusted
Pearson et al. 1987 | 864 HMO enrollees, mean age 52 years | Total | 42.4 | 39.9 | 6.6 | Percent reporting low physical health
Wooden and Bush 1995 | 23,813 Australians | Total | 2.090 | 2.316 | −9.8 | Higher scores reflect better physical health status (4-point scale, 4 = best)
General health status (health status questionnaire Short Form 36 [SF-36])
Wakefield et al. 1995 | 3,010 Australians, aged >15 years | Aged 15–29 years | 71.0 | 77.4 | −8.3 | Smokers = ever smokers
Wakefield et al. 1995 | 3,010 Australians, aged >15 years | Aged ≥30 years | 69.1 | 74.6 | −7.4 | Smokers = ever smokers
Sippel et al. 1999 | 619 HMO members with asthma | Total | 53 | 66 | −19.7 | Higher scores reflect better health status(100 = best, 0 = worst)
Life dissatisfaction
Kaprio and Koskenvuo 1988 | 7,094 Finns, twin cohort, men aged 20–54 years, women aged 20–39 years | Men: 20–34 years | 8.8 | 8.4 | 4.8 | Based on a psychological scale; details were not specified
Kaprio and Koskenvuo 1988 | 7,094 Finns, twin cohort, men aged 20–54 years, women aged 20–39 years | 35–54 years | 9.1 | 8.3 | 9.6 | Based on a psychological scale; details were not specified
Kaprio and Koskenvuo 1988 | 7,094 Finns, twin cohort, men aged 20–54 years, women aged 20–39 years | Women: 20–39 years | 8.7 | 8.2 | 6.1 | Based on a psychological scale; details were not specified
General life satisfaction
Blair et al. 1980 | 504 employees, mean age 34 years | Men | 28.4 | 32.9 | −13.7 | Age-adjusted proportion with a high level of general life satisfaction
Blair et al. 1980 | 504 employees, mean age 34 years | Women | 15.4 | 35.4 | −56.5 | Age-adjusted proportion with a high level of general life satisfaction
Overall well-being
Dennerstein et al. 1994 | Random sample of 1,503 women, Melbourne, Australia, aged 45–55 years | Total | 1.43 | 1.57 | −8.9 | Higher scores reflect a greater sense of well- being
Overall quality of life
Sippel et al. 1999 | 619 HMO members with asthma | Total | 2.1 | 1.8 | 16.7 | Higher scores reflect a poorer quality of life(10-point scale, 1 = best, 10 = worst)
Tiredness for no reason (% reporting)
Chetwynd and Rayner 1986 | Survey of 978 women who worked at home, Christchurch, New Zealand, aged 18–60 years | Total | 36 | 21 | 71.4 | None
Getting very tired easily (% reporting)
Rimer et al. 1990 | 3,147 American Association of Retired Persons members, aged 50–102 years | Total | 32 | 20 | 60.0 | Age-adjusted
Mental health (health status questionnaire Short Form 36 [SF-36])
Wakefield et al. 1995 | 3,010 Australians, aged >15 years | Aged 15–29 years | 73.6 | 75.2 | −2.1 | Smokers = ever smokers
Wakefield et al. 1995 | 3,010 Australians, aged >15 years | Aged ≥30 years | 78.6 | 80.6 | −2.5 | Smokers = ever smokers
Sippel et al. 1999 | 619 HMO members with asthma | Total | 69 | 76 | −9.2 | Higher scores reflect better mental health(100 = best, 0 = worst)
Mental well-being
Wooden and Bush 1995 | 23,813 Australians | Total | 2.223 | 2.300 | −3.3 | Higher scores reflect better mental health(4-point scale, 4 = best)
Psychosomatic symptoms
Matarazzo and Saslow 1960 | 294 persons from 3 populations: psychiatric patients, student nurses, and university undergraduates | Psychiatric patients | 13.9 | 12.1 | 14.9 | Mean score on Saslow Psychosomatic Screening Inventory (higher = more symptoms)
Matarazzo and Saslow 1960 | 294 persons from 3 populations: psychiatric patients, student nurses, and university undergraduates | Student nurses | 8.2 | 6.3 | 30.2 | Mean score on Saslow Psychosomatic Screening Inventory (higher = more symptoms)
Matarazzo and Saslow 1960 | 294 persons from 3 populations: psychiatric patients, student nurses, and university undergraduates | Undergraduates | | | | Mean score on Saslow Psychosomatic Screening Inventory (higher = more symptoms)
Matarazzo and Saslow 1960 | 294 persons from 3 populations: psychiatric patients, student nurses, and university undergraduates | Men | 3.9 | 3.3 | 18.2 | Mean score on Saslow Psychosomatic Screening Inventory (higher = more symptoms)
Matarazzo and Saslow 1960 | 294 persons from 3 populations: psychiatric patients, student nurses, and university undergraduates | Women | 6.1 | 3.7 | 64.9 | Mean score on Saslow Psychosomatic Screening Inventory (higher = more symptoms)
Psychological symptoms
Macnee 1991 | 240 men and women, mean age 33 years | Total | 8.8 | 7.9 | 11.4 | Symptom checklist: range from 0–40; higher scores equal more symptoms based on a 10-item measure
Depressed mood (%)
Schoenborn and Horm 1993 | 1991 National Health Interview Survey, random sample, U.S. adults (n = 43,732) | Men | 10.3 | 5.8 | 77.6 | None
Schoenborn and Horm 1993 | 1991 National Health Interview Survey, random sample, U.S. adults (n = 43,732) | Women | 15.8 | 10.0 | 58.0
Health behavior efficacy expectations, health status
Grembowski et al. 1993 | 2,523 Medicare beneficiaries | Total | 2.96 | 9.78 | −69.7 | Scales of 0 to 10 (0 = low and 10 = high); efficacy expectations of health behaviors(exercise, dietary fat, weight control, smoking, and alcohol consumption) and resulting health status expectations
Grembowski et al. 1993 | 2,523 Medicare beneficiaries | Total | 7.66 | 9.69 | −21.0 | Scales of 0 to 10 (0 = low and 10 = high); efficacy expectations of health behaviors(exercise, dietary fat, weight control, smoking, and alcohol consumption) and resulting health status expectations

* OR = Odds ratio.

† HMO = Health maintenance organization.

Table 6.13 Studies evaluating the dose-response relationship between the number of cigarettes smoked per day and health status

Study | Population | Group | Percentage difference | | | | Comments
Study | Population | Group | Nonsmokers (referent) | Smokers, by category of dose (1 = low) | | | Comments
Study | Population | Group | Nonsmokers (referent) | 1 | 2 | 3 | Comments
Mean number of illnesses in the past 30 days
Marsden et al. 1988 | 17,328 active U.S. military personnel | Total | 0 | 0.4 | 12.3 | 36.4 | None
Self-reported poor health status (number of health complaints)
Seidell et al. 1986 | 455 Dutch men and 790 Dutch women, aged26–66 years | Men | 0 | 23.3 | 31.5 | | None
Seidell et al. 1986 | 455 Dutch men and 790 Dutch women, aged26–66 years | Women | 0 | 6.8 | 28.4
Subjective health complaints
Joung et al. 1995 | 16,311 Dutch men and women, aged 25–74 years | Total | 0 | 71.0 | 137.0 | | None
Chronic conditions
Joung et al. 1995 | 16,311 Dutch men and women, aged 25–74 years | Total | 0 | 29.0 | 43.0 | | None
Self-reported chronic conditions
Balarajan et al. 1985 | 23,956 participants in the United Kingdom General Household Survey, aged >16 years | Total | 0 | 7.0 | 31.0 | 76.0 | None
Perceived poor health
Joung et al. 1995 | 16,311 Dutch men and women, aged 25–74 years | Total | 0 | 75.0 | 101.0 | | None
Manderbacka et al. 1999 | 1991 Swedish Level of Living Survey (n = 5,306, aged 18–75 years) | Total | 0 | 33.0 | 37.0 | | Adjusted for age, gender, and risk
Physical health status
Belloc and Breslow1972 | Random sample of Alameda County, California, residents, aged >20 years | Current smokers | | | | | Ridits (higher score = poorer health); whether one inhales cigarette smoke, and the extent of such inhalation, appear highly correlated with physicial health status
Belloc and Breslow1972 | Random sample of Alameda County, California, residents, aged >20 years | Men | 0 | 4.3 | 17.0 | | Ridits (higher score = poorer health); whether one inhales cigarette smoke, and the extent of such inhalation, appear highly correlated with physicial health status
Belloc and Breslow1972 | Random sample of Alameda County, California, residents, aged >20 years | Women | 0 | 6.3 | 16.7 | | Ridits (higher score = poorer health); whether one inhales cigarette smoke, and the extent of such inhalation, appear highly correlated with physicial health status
Belloc and Breslow1972 | Random sample of Alameda County, California, residents, aged >20 years | Former smokers | | | | | Ridits (higher score = poorer health); whether one inhales cigarette smoke, and the extent of such inhalation, appear highly correlated with physicial health status
Belloc and Breslow1972 | Random sample of Alameda County, California, residents, aged >20 years | Men | 0 | 6.4 | 14.9 | | Ridits (higher score = poorer health); whether one inhales cigarette smoke, and the extent of such inhalation, appear highly correlated with physicial health status
Belloc and Breslow1972 | Random sample of Alameda County, California, residents, aged >20 years | Women | 0 | 8.3 | 10.4 | | Ridits (higher score = poorer health); whether one inhales cigarette smoke, and the extent of such inhalation, appear highly correlated with physicial health status
Physical health score
Wiley and Camacho1980 | 3,982 Alameda County residents, aged 20–70 years | Men | 0 | −75.9 | −265.5 | −286.2 | High scores = better physical health
Wiley and Camacho1980 | 3,982 Alameda County residents, aged 20–70 years | Women | 0 | 50.0 | −500.0 | −375.0 | High scores = better physical health
Self-reported health status
Segovia et al. 1989 | Sample of 3,300 residents of St. John’s, Canada, aged >20 years | Total | 0 | −16.3 | 19.1 | −31.9 | Percentage reporting good health; additional smoking categories, by increasing dose: −40.9, −67.4, −48.0, −76.2
Poikolainen et al. 1996, Poikolainen and Vartiainen 1997 | 6,040 men and women, Finland, aged 25–64 years | Total | 0 | 0.2 | 45.7 | NR^*^ | Percentage reporting suboptimal health
Impaired psychological status
Lindenthal et al. 1972 | 938 New Haven adults (aged >18 years), sample | Total | 0 | 35.8 | −23.8 | 50.3 | Based on a percentage with very impaired status; smoking frequency categories
Psychological well-being
Wetzler and Ursano1988 | 6,675 U.S. Air Force personnel | Total | 0 | 1.7 | 3.3 | NR | None

* NR = Data were not reported.

Table 6.14 Studies comparing the health status of former smokers and nonsmokers

Study | Population | Group | Results | | | Comments
Study | Population | Group | Former smokers | Nonsmokers | Percentage difference | Comments
Perceived poor health
Joung et al. 1995 | 16,311 Dutch men and women, aged 25–74 years | Total | 1.35 | 1.0 | 35.0 | OR^*^
Self-reported poor health (number of health complaints)
Seidell et al. 1986 | 455 Dutch men and 790 Dutch women, aged 26–66 years | Men | 6.8 | 7.3 | −6.8 | None
Seidell et al. 1986 | 455 Dutch men and 790 Dutch women, aged 26–66 years | Women | 10.2 | 9.0 | 13.8 | None
Subjective health complaints
Lilienfeld 1959 | 903 residents, Buffalo, New York | Total | 18.9 | 18.3 | 3.3 | Physical or health problem
Joung et al. 1995 | 16,311 Dutch men and women, aged 25–74 years | Total | 1.32 | 1.0 | 32.0 | OR
Self-reported chronic conditions
Balarajan et al. 1985 | 23,956 participants in the United Kingdom | Quit >1 year | 1.43 | 1.0 | 43.0 | OR
Balarajan et al. 1985 | General Household Survey, aged >16 years | Quit ≤1 year | 1.23 | 1.0 | 26.0 | OR
Chronic conditions
Joung et al. 1995 | 16,311 Dutch men and women, aged 25–74 years | Total | 1.49 | 1.0 | 49.0 | ORs
Physical symptoms
Macnee 1991 | 240 men and women, mean age 33 years | Total | 36.6 | 21.5 | 32.8 | Based on a scale from 0–120 (higher = more symptoms)
Concern about physical health (% reporting)
Thomas 1960 | 657 medical students | Total | 4.4 | 3.3 | 33.3 | None
Getting very tired easily (% reporting)
Rimer et al. 1990 | 3,147 American Association of Retired Persons members, aged 50–102 years | Total | 25 | 20 | 25.0 | Age-adjusted
Self-reported poor health
Halpern and Warner 1994 | 1990 U.S. National Health Interview Survey, random sample (n = 119,631), aged >17 years | Time since cessation | | | | OR
Halpern and Warner 1994 | 1990 U.S. National Health Interview Survey, random sample (n = 119,631), aged >17 years | 0–2 months | 3.03 | 1.0 | 203.0 | OR
Halpern and Warner 1994 | 1990 U.S. National Health Interview Survey, random sample (n = 119,631), aged >17 years | 3 months–1 year | 2.83 | 1.0 | 183.0 | OR
Halpern and Warner 1994 | 1990 U.S. National Health Interview Survey, random sample (n = 119,631), aged >17 years | 2–4 years | 2.03 | 1.0 | 103.0 | OR
Halpern and Warner 1994 | 1990 U.S. National Health Interview Survey, random sample (n = 119,631), aged >17 years | 5–10 years | 1.35 | 1.0 | 35.0 | OR
Halpern and Warner 1994 | 1990 U.S. National Health Interview Survey, random sample (n = 119,631), aged >17 years | 11–19 years | 1.42 | 1.0 | 42.0 | OR
Halpern and Warner 1994 | 1990 U.S. National Health Interview Survey, random sample (n = 119,631), aged >17 years | ≥20 years | 1.00 | 1.0 | 0.0 | OR
Manderbacka et al. 1999 | 1991 Swedish Level of Living Survey (n = 5,306), persons aged 18–75 years | Total | 1.45 | 1.0 | 45.0 | OR; adjusted for age, gender, risk factors, health behaviors, and health
Self-reported health status
Orleans et al. 1989 | 1,163 African American life insurance policyholders, mean age 39 years | Total | 22.5 | 11.3 | 99.1 | Percentage fair/poor
Poikolainen and Vartiainen 1997 | 6,040 men and women, Finland, aged 25–64 years | Total | 46.7 | 40.7 | 14.7 | Percentage suboptimal
General health status (health status questionnaire Short Form 36 [SF-36])
Sippel et al. 1999 | 619 HMO^†^ members with asthma | Total | 61 | 66 | −7.6 | Higher scores reflect a better health status (100 = best, 0 = worst)
Self-perceived good/excellent health (% reporting)
Colsher et al. 1990 | 4 population-based cohorts, aged >65 years | Men: Iowa | 63.8 | 74.6 | −14.5 | None
Colsher et al. 1990 | 4 population-based cohorts, aged >65 years | East Boston | 61.7 | 69.1 | −10.7 | None
Colsher et al. 1990 | 4 population-based cohorts, aged >65 years | New Haven | 61.0 | 68.8 | −11.3 | None
Colsher et al. 1990 | 4 population-based cohorts, aged >65 years | Piedmont | 57.0 | 60.1 | −5.2 | None
Colsher et al. 1990 | 4 population-based cohorts, aged >65 years | Women: Iowa | 67.4 | 72.6 | −7.2 | None
Colsher et al. 1990 | 4 population-based cohorts, aged >65 years | East Boston | 57.1 | 54.3 | 5.2 | None
Colsher et al. 1990 | 4 population-based cohorts, aged >65 years | New Haven | 63.6 | 60.8 | 4.6 | None
Colsher et al. 1990 | 4 population-based cohorts, aged >65 years | Piedmont | 57.4 | 54.5 | 5.3 | None
Good physical function (% reporting)
Colsher et al. 1990 | 4 population-based cohorts, aged >65 years | Men: Iowa | 60.4 | 70.5 | −14.3 | None
Colsher et al. 1990 | 4 population-based cohorts, aged >65 years | East Boston | 58.6 | 64.2 | −8.7 | None
Colsher et al. 1990 | 4 population-based cohorts, aged >65 years | New Haven | 65.7 | 71.0 | −7.5 | None
Colsher et al. 1990 | 4 population-based cohorts, aged >65 years | Piedmont | 64.2 | 71.5 | −10.2 | None
Colsher et al. 1990 | 4 population-based cohorts, aged >65 years | Women: Iowa | 49.0 | 61.5 | −20.3 | None
Colsher et al. 1990 | 4 population-based cohorts, aged >65 years | East Boston | 44.9 | 45.8 | −2.0 | None
Colsher et al. 1990 | 4 population-based cohorts, aged >65 years | New Haven | 47.9 | 57.1 | −16.1 | None
Colsher et al. 1990 | 4 population-based cohorts, aged >65 years | Piedmont | 49.8 | 50.9 | −2.2 | None
Physical health status
Belloc and Breslow 1972 | Random sample of Alameda County, California, residents aged >20 years | Men | 0.51 | 0.47 | 8.5 | Higher scores reflect a poorer health status, measured by ridits (mean rank sums)
Belloc and Breslow 1972 | Random sample of Alameda County, California, residents aged >20 years | Women | 0.51 | 0.48 | 6.3 | Higher scores reflect a poorer health status, measured by ridits (mean rank sums)
Reed 1983 | 542 HMO enrollees | Total | 0.52 | 0.49 | 6.1 | Higher scores reflect a poorer health status, measured by ridits (mean rank sums); age and gender adjusted
Wooden and Bush 1995 | 23,813 Australians | Total | 2.231 | 2.316 | −3.7 | Higher scores reflect a better health status (4-point scale, 4 = best)
Overall quality of life
Sippel et al. 1999 | 619 HMO members with asthma | Total | 2.4 | 1.8 | 33.3 | Higher scores reflect a poorer quality of life (10-point scale, 10 = worst)
Mental health (health status questionnaire Short Form 36 [SF-36])
Sippel et al. 1999 | 619 HMO members with asthma | Total | 73 | 76 | −3.9 | Higher scores reflect a better mental health (100 = best, 0 = worst)
Psychological symptoms
Macnee 1991 | 240 men and women, mean age 33 years | Total | 11.8 | 7.9 | 49.4 | None
Impaired psychological status
Lindenthal et al. 1972 | 938 New Haven adults aged >18 years (sample) | Total | 20.3 | 15.1 | 34.4 | Percentage of very impaired
Mental health: prevalence of psychiatric morbidity
Stansfeld et al. 1993 | 9,962 men and women, Whitehall Study, aged 35–55 years | Men | 29.1 | 23.7 | 22.8 | Smoking was also associated with a risk of physical symptoms in both genders
Stansfeld et al. 1993 | 9,962 men and women, Whitehall Study, aged 35–55 years | Women | 30.6 | 30.0 | 0.3 | Smoking was also associated with a risk of physical symptoms in both genders
Feeling discouraged/blue (depression)
Lilienfeld 1959 | 903 residents, Buffalo, New York | Total | 32.9 | 24.8 | 32.7 | Percentage sometimes/very often
Psychological well-being
Wetzler and Ursano 1988 | 6,675 U.S. Air Force personnel | Total | 4.17 | 4.24 | −1.7 | None
Mental well-being
Wooden and Bush 1995 | 23,813 Australians | Total | 2.285 | 2.300 | −0.6 | Higher scores reflect better well-being (4-point scale, 4 = best)
Life dissatisfaction
Kaprio and Koskenvuo 1988 | 7,094 Finns, twin cohort, men aged 20–54 years, women aged 20–39 years | Men: 20–34 years | 8.3 | 8.4 | −1.2 | Based on a psychological scale
Kaprio and Koskenvuo 1988 | 7,094 Finns, twin cohort, men aged 20–54 years, women aged 20–39 years | 35–54 years | 8.5 | 8.3 | 2.4 | Based on a psychological scale
Kaprio and Koskenvuo 1988 | 7,094 Finns, twin cohort, men aged 20–54 years, women aged 20–39 years | Women: 20–39 years | 8.4 | 8.2 | 2.4 | Based on a psychological scale
General life satisfaction
Blair et al. 1980 | 504 employees, mean age 34 years | Men | 27.5 | 32.9 | −16.4 | None
Blair et al. 1980 | 504 employees, mean age 34 years | Women | 20.5 | 35.4 | −42.1 | None

* OR = Odds ratio.

† HMO = Health maintenance organization.

Studies with varying designs, as well as studies measuring physical health status (Table 6.12), have shown uniformly that smokers tend to rate their general health status lower than do nonsmokers. Studies that do not include sufficient data to summarize in the tables obtained similar results. A study of 558 Bank of America retirees in California comparing smokers with nonsmokers showed that smoking was strongly associated with a higher number of sick days confined to home (Leigh and Fries 1992). In an analysis of 1990 National Health Interview Survey data, the perception of health status held by current smokers was significantly lower than that held by nonsmokers (Erickson 1998). In a multiple regression analysis of data collected from approximately 18,000 men and women in Finland, which included variables for sociodemographic characteristics, family life, morbid conditions, pain, psychosocial problems, and relative weight, smoking was associated with a significantly lower perceived health status in men but not in women (Fylkesnes and Førde 1991). In a random sample of 1,200 adults in South Wales, United Kingdom, the mean score on the SF-36 general health perception scale among participants who had ever smoked was 7.8 points lower than for those who had never smoked (Lyons et al. 1994). A study using the same scale with 921 U.S. male military veterans showed that current smoking was significantly inversely correlated with good general health perceptions (Schnurr and Spiro 1999). In a telephone survey of Newfoundland residents, the likelihood of rating one’s health as good declined in proportion to the number of cigarettes smoked per day; those who had never smoked were more than four times more likely than smokers of more than 30 cigarettes per day to rate their health as good (Segovia et al. 1989). In a survey of 1,623 patients from nine medical practices in Scotland who had a history of smoking, persistent smokers rated their general health 8.0 percent lower than former smokers rated theirs on the SF-36 scale (Tillmann and Silcock 1997). Among 2,502 enrollees in an Oregon health maintenance organization, smoking was negatively correlated with general health status for both men and women, an observation that extended to measures of mental and physical health status (Pope 1982).

Smokers in at least one subgroup were at least 10 percent more likely than nonsmokers to rate their health as poor, including studies that compared self-reported chronic conditions (Balarajan et al. 1985; Halpern and Warner 1994), acute conditions (Balarajan et al. 1985), and physical symptoms (Macnee 1991; York and Hirsh 1995). An increasing number of cigarettes smoked per day was consistently associated with increased risks for symptoms or illnesses (Balarajan et al. 1985; Marsden et al. 1988; Joung et al. 1995), and with a greater likelihood of rating one’s health as poor (Joung et al. 1995; Poikolainen et al. 1996; Manderbacka et al. 1999) (Table 6.13), with differences between the highest and lowest exposure categories of about 30 percent or greater in every study that assessed dose-response trends (Table 6.13). For several measures of poor health, the differences between former smokers and lifetime nonsmokers (Table 6.14) tended to be even more striking than for comparisons between current smokers and lifetime nonsmokers, probably because of the increased likelihood of quitting among those experiencing symptoms or diagnosed with illnesses.

A few studies examined reports of fatigue or tiredness. In a survey of New Zealand women who worked at home, smokers were 71 percent more likely than nonsmokers to report frequently feeling tired for no reason (Chetwynd and Rayner 1986). In a study of retired persons in the United States, after adjusting for age, current smokers were 60 percent more likely than lifetime nonsmokers to report becoming very tired easily (Rimer et al. 1990); former smokers were 25 percent more likely than lifetime nonsmokers to report getting very tired easily (Rimer et al. 1990).

Smokers tend to rate their general level of well-being lower than do nonsmokers whether well-being is measured directly (Dennerstein et al. 1994), assessed overall as quality of life (Sippel et al. 1999), or rated by degrees of general satisfaction with life (Blair et al. 1980) (Table 6.12). Similar findings have been observed when former smokers were compared with lifetime nonsmokers (Table 6.14) (Blair et al. 1980; Sippel et al. 1999). Conversely, compared with lifetime nonsmokers, current smokers tend to rate themselves as more dissatisfied with life (Table 6.12) (Kaprio and Koskenvuo 1988), but few differences in the prevalence rates of life dissatisfaction were observed between former smokers and nonsmokers (Table 6.14) (Kaprio and Koskenvuo 1988).

With respect to mental health and well-being, smokers tend to rate themselves slightly lower on measures of mental health or mental well-being (Wakefield et al. 1995; Wooden and Bush 1995; Sippel et al. 1999). In addition, smokers are more likely than nonsmokers to have psychological symptoms such as depressed mood and phobic anxiety (Matarazzo and Saslow 1960; Macnee 1991; Schoenborn and Horm 1993). In the South Wales study, not included in the summary tables, current smokers had a mean SF-36 mental health score that was slightly but not significantly lower than that of people who had never smoked (Lyons et al. 1994). Former smokers also tend to rate themselves less favorably than do nonsmokers (Table 6.14). The differences between former smokers and lifetime nonsmokers were small with respect to mental health and well-being (Wetzler and Ursano 1988; Wooden and Bush 1995; Sippel et al. 1999), but were more marked on measures of symptoms or morbidity (Table 6.14) (Lilienfeld 1959; Lindenthal et al. 1972; Macnee 1991). A strong dose-response trend was observed between smoking frequency and depressed moods in nationally representative U.S. data from the National Health Interview Survey (Schoenborn and Horm 1993). However, dose-response trends generally did not occur for mental health measures (Table 6.13) (Lindenthal et al. 1972; Wetzler and Ursano 1988; Stansfeld et al. 1993).

Studies of physical functioning, or functional status, among elderly populations also provide relevant evidence. Although they are not a focus of this review, such studies have provided prospective evidence that cigarette smoking is associated with accelerated declines in physical function (Pinsky et al. 1987; Guralnik and Kaplan 1989; Berkman et al. 1993; Strawbridge 1993). An analysis of data from the Honolulu Heart Study showed that smoking was inversely associated with freedom from clinical illnesses, physical impairment, and cognitive impairment (Reed et al. 1998).

The evidence provides a clear indication that smokers perceive their health as poorer than nonsmokers perceive theirs. Smokers report more symptoms (including mental health symptoms) and illness episodes, feel more tired, and have lower ratings for physical health status. Compared with nonsmokers, smokers even report lower overall levels of well-being for reasons that may at least partially reflect their diminished health status. The consistent indications of a poorer health status among smokers compared with nonsmokers across numerous health status dimensions provide direct evidence that smoking is associated with a diminished health status.

### Evidence Synthesis

This section reviewed evidence on smoking and a diverse but interrelated set of measures of health status. Although the measures are nonspecific and likely to be affected by factors other than smoking, there is abundant and consistent evidence that smokers generally have a poorer health status than nonsmokers. This section reviewed findings on self-reported health statuses, absenteeism, and medical services utilization rates, as well as complications of surgical care. For each of these outcomes, the weight of the evidence indicates an adverse effect from smoking. There are many studies with differing designs and a variety of populations. The strength of the association with smoking is variable across the outcome measures and across study populations, probably reflecting the nonspecificity of these measures and the differing mixes of potential confounding and modifying factors across studies. In general, there is evidence for an increasing severity of outcome measures with an increasing number of cigarettes smoked, and current smokers tend to have worse outcomes than former smokers. Studies have addressed potential confounding factors to a limited extent, depending on the availability of data on relevant factors. Given the diversity of populations, study designs, and consistency of findings, confounding alone does not seem to be a satisfactory explanation for the overall pattern of findings. A single, unifying biologic basis for the association of smoking with the outcome measures cannot be postulated, but there are many well-supported direct and indirect mechanisms that may link smoking to the adverse effects documented in this section.

### Conclusions

1. The evidence is sufficient to infer a causal relationship between smoking and diminished health status that may manifest as increased absenteeism from work and increased use of medical care services.
2. The evidence is sufficient to infer a causal relationship between smoking and increased risks for adverse surgical outcomes related to wound healing and respiratory complications.

### Implications

Although preventing the specific diseases caused by smoking has been a public health priority for a long time, cigarette smoking also causes a substantial and costly burden of nonspecific morbidity. Smokers have a poorer health status, lose more time from work, and use medical care services at a higher rate than their nonsmoking peers. These adverse effects occur among younger smokers even before the burden of smoking-induced diseases becomes apparent at middle age and older.

## Loss of Bone Mass and the Risk of Fractures

In the United States, of the estimated 850,000 fractures per year in persons 65 years of age and older, nearly 300,000 are hip fractures (Apple and Hayes 1994; Centers for Disease Control and Prevention [CDC] 1996; Ray et al. 1997). Approximately 33 percent of women and 17 percent of men experience a hip fracture if they live to be 90 years old (Mazess 1982; Melton and Riggs 1987). Mortality in persons with a hip fracture is 12 to 20 percent higher than in persons without a hip fracture of similar age, race, and gender (Miller 1978; Jensen and Tondevold 1979; Weiss et al. 1983; Jensen 1984; Kenzora et al. 1984; Kreutzfeldt et al. 1984). The estimated annual costs for medical and nursing services related to hip fractures range from $7 billion to $10 billion (Ray et al. 1997). From July 1991 through June 1992, costs to Medicare for 10 types of fractures were estimated at $4.2 billion (Baron et al. 1996). Moreover, continued growth of the elderly population can be expected to dramatically increase the number of hip fractures, because hip fracture incidence rates increase exponentially with age (Melton and Riggs 1987; Melton et al. 1987). If these demographic and incidence trends continue, the number of hip fractures may well double or triple by the middle of the century (Kelsey and Hoffman 1987). With their frequency, adverse quality of life impacts, and economic costs, hip fractures are an urgent and major public health problem.

Bone mineral density (BMD) is one of the strongest indicators of the risk for a fracture. Several cohort studies have confirmed that even a single low BMD measurement is associated with the risk of a later fracture (Gärdsell et al. 1989; Hui et al. 1989; Cummings et al. 1993). For each standard deviation decrease in BMD, the estimated relative risk (RR) of fractures ranged from 1.5 to 2.6, depending on the site that was measured (Marshall et al. 1996). Therefore, discussions of the possible adverse effects from smoking on bone health should consider both BMD and fractures as outcome measures. An estimated 60 to 80 percent of the bone density variation is explained by genetic factors (Eisman 1999), leaving 20 to 40 percent of the variation attributable to nongenetic factors. Smoking is an important modifiable risk factor in both women and men.

### Conclusions of Previous Surgeon General’s Reports

Harmful effects of smoking on the skeleton have been recognized for several decades but the data were not sufficient to conclude that smoking adversely affects bone mass (USDHHS 1990); however, the most recent Surgeon General’s report on women and smoking (USDHHS 2001) identified smoking as adversely affecting bone health and increasing the risks for fractures. The report concluded that smoking adversely affects bone density and increases the risks for hip fractures in postmenopausal women. Specifically, the conclusions were that (1) postmenopausal women who currently smoke have lower bone density than women who do not smoke; (2) women who currently smoke have an increased risk for hip fracture compared with women who do not smoke; and (3) the relationship among women between smoking and the risk for bone fracture at sites other than the hip is not clear (USDHHS 2001). However, because male osteoporosis also has been recognized as a considerable disease burden, the role of smoking in male bone health also deserves consideration.

### Biologic Basis

Smoking has the potential for direct and indirect effects on skeletal health and the risk of fractures. Direct toxic effects of smoking on bone cells may be related to the physiologic effects of nicotine (Fang et al. 1991; Riebel et al. 1995) or possibly cadmium in tobacco smoke (Bhattacharyya et al. 1988). Indirect effects of smoking on bone cells may result from decreased intestinal calcium absorption (Krall and Dawson-Hughes 1999), reduced intake and lower levels of vitamin D (Brot et al. 1999), or alterations in the metabolism of adrenal cortical and gonadal hormones (Michnovicz et al. 1986; Khaw et al. 1988; Baron et al. 1995). These direct and indirect effects may account for the generally observed decrease in markers of bone formation such as osteocalcin in smokers compared with nonsmokers (Brot et al. 1999; Bjarnason and Christiansen 2000). Smoking might also indirectly influence bone density through reduction in body weight, since body weight tends to be lower for smokers than for nonsmokers. This weight difference may itself lead to lower bone density and an increased risk for a fracture (Kiel et al. 1987; Cummings et al. 1995). Smokers also tend to have an earlier menopause than nonsmokers, thus extending the postmenopausal period of accelerated bone mineral loss (USDHHS 2001). Finally, smokers tend to be less physically active than nonsmokers and activity level is associated with bone density and hence risk for a fracture (Gregg et al. 1998).

In several analyses involving women, the lower weight of smokers compared with nonsmokers explains part of the increased risk for low BMD associated with smoking (Bauer et al. 1993). However, there are differences in BMD and in fracture rates between smokers and nonsmokers even after adjusting for weight differences, suggesting that the weight difference alone does not explain the effects of smoking (Kiel et al. 1992, 1996; Bjarnason and Christiansen 2000). The lower weight in smokers may increase the risk of fractures, such as hip fractures, through several mechanisms: reduced soft tissue mass overlaying the trochanter, resulting in less energy absorption from a fall on the hip; reduced weight loads on the skeleton; or reduced conversion of adrenal steroids into sex steroids in adipose tissue. The antiestrogenic effect of smoking also may contribute to osteoporosis in women (Jensen et al. 1985; Jensen and Christiansen 1988), and may reduce the benefits of hormonal replacement therapy (Komulainen et al. 2000). In a Finnish trial of osteoporosis prevention, smoking was associated with a nonresponse to hormonal therapy, as assessed by changes in BMD (Komulainen et al. 2000). Less consistent evidence for a blunted response to estrogen by smoking was reported from a Danish trial (Bjarnason and Christiansen 2000). Interestingly, although estrogen appears to be a critical hormone for male skeletal health (Slemenda et al. 1997; Khosla et al. 1998), smoking does not appear to modify the association between estradiol levels and bone density in men (Amin et al. 1999). Finally, smoking may increase the risk of fractures through reductions in physical performance capacity, thereby increasing the risk for falls (Nelson et al. 1994).

### Bone Density in Young Men and Women

#### Epidemiologic Evidence

Increasingly refined measures of BMD have become available so that current studies use direct BMD measurements. Before such direct measurements were possible BMD was assessed using radiographs, with measurements typically focused on the widths of the cortical bones in sites such as the metacarpals. Direct quantitative assessments of the amount of mineral in various skeletal sites have now become possible with the advent of single and dual photon absorptiometry, followed by refinements such as single and dual x-ray absorptiometry, quantitative computed tomography, and quantitative ultrasonography. These techniques have all been used to generate the data summarized here.

In adults at any particular age bone mass is dependent on the peak mass achieved up to that age, and subsequent losses from the peak are attributable to aging and other factors. The pace of skeletal growth is rapid during infancy, slower during childhood, accelerated during puberty, and by 20 to 30 years of age the peak skeletal mass is attained (Kroger et al. 1992; Lu et al. 1996). Gains in BMD continue into the third decade after bone growth has ceased (Recker et al. 1992). After menopause, bone loss rates accelerate compared with premenopausal rates, and these rates are sustained or increase even more with aging (Ensrud et al. 1995). Age-related losses also occur in men (Jones et al. 1994). In the context of these age-related patterns, the role of smoking in the attainment of peak bone mass is reviewed along with studies of bone density and menopausal status. A literature search was conducted using the National Library of Medicine’s PubMed system; the key words used were “bone mineral density,” “bone density,” “fracture,” “smoking,” and “cigarettes.” In addition, all references from a key meta-analysis (Law and Hackshaw 1997) were also retrieved. Studies focusing on men mainly involve older age groups. The evidence on smoking and BMD comes primarily from cross-sectional and cohort studies. The cross-sectional studies assess the cumulative consequences of smoking on BMD growth and/or decline. Cohort studies can assess changes in BMD over time. Findings of the different types of studies are presented in Tables 6.15–6.17.

Table 6.15 Cross-sectional studies on the association between smoking status and bone density in women^*^

Study | Mean (range) age (years) | Smoking status | Site of bone density measurement | Findings
Premenopausal
Fehily et al. 1992 | 22 (20–23) | 104 current smokers 78 never/former smokers | Radius | No differences in BMD^†^ between smokers (0.71 g/cm^2^ [SD^‡^ = 0.07]) and nonsmokers (0.71 [0.06])
Välimäki et al. 1994 | 24 (20–29) | 9 current smokers 47 never smokers | Femur | Mean BMD in g/cm^2^ (SD) at hip = 0.914 (0.102) for smokers compared with 0.956 (0.100) for nonsmokers; adjusted for age, weight, and exercise
McCulloch et al. 1990 | 28 (20–35) | 25 current smokers 76 never/former smokers | Calcaneus | Mean BMD in g/cm^2^ = 177.8 (54.1) for smokers compared with 190.6 (52.9) for nonsmokers
Ortego-Centeno et al. 1994 | 28 (SD = 7) | 47 current smokers 54 never/former smokers | Femur | Femoral neck BMD in g/cm^2^ (SD) for smokers = 0.796 (0.118), nonsmokers = 0.838 (0.123), p <0.05; lumbar spine for smokers = 1.025 (0.108), nonsmokers = 1.039 (0.106), p = not significant
Daniel et al. 1992 | 29 (20–35) | 25 current smokers 27 never/former smokers | Femur | Mean BMD in g/cm^2^ (SD) = 1.16 (0.014) for smokers compared with 1.151 (0.014) for nonsmokers; adjusted for weight (p = 0.140)
Mazess and Barden 1991 | 30 (20–39) | 23 current smokers 195 never/former smokers | Femur, lumbar spine, and radius | Spine BMD was significantly lower for smokers compared with nonsmokers (t = 2.26, p <0.05)
Sowers et al. 1992 | 36 (22–54) | 31 current smokers 77 never/former smokers | Radius | Radial BMD loss in g/cm^2^ (SD) = 0.71 (0.01) for smokers compared with 0.74 (0.008) for nonsmokers (p = 0.300)
Law et al. 1997 | 37 (35–39) | 28 current smokers 72 never smokers | Radius | Difference between current and nonsmokers = 0.43 (95% CI^§^, −0.73–1.59)
Law et al. 1997 | 42 (40–44) | 63 current smokers 115 never smokers | Radius | Difference between current and nonsmokers = 0.43 (95% CI^§^, −0.73–1.59)
Law et al. 1997 | 47 (45–49) | 50 current smokers 107 never smokers | Radius | Difference between current and nonsmokers = 0.43 (95% CI^§^, −0.73–1.59)
Law et al. 1997 | 52 (50–54) | 14 current smokers 79 never smokers | Radius | Difference between current and nonsmokers = 0.43 (95% CI^§^, −0.73–1.59)
Hopper and Seeman 1994 | 42 (27–49) | 9 current smokers 9 never smokers | Femur | Study of twin pairs found that BMD was lower for the twin who smoked more heavily
Johnell and Nilsson 1984 | 49 (49) | 186 current smokers 185 never/former smokers | Radius | Distal BMCΔ in mg/cm^2^ = 320 (SD = 73) for smokers compared with 318 (77) for nonsmokers; proximal = 538 (68) for smokers compared with 533 (62) for nonsmokers; results were not significant
Postmenopausal
Law et al. 1997 | 45 (39–49) | 24 current smokers 56 never smokers | Radius | Difference in BMD^†^ between current smokers and nonsmokers = −0.17 g/cm^2^ (95% CI, −1.88–1.54)
Law et al. 1997 | 52 (50–54) | 31 current smokers 83 never smokers | Radius | Difference in BMD^†^ between current smokers and nonsmokers = −0.17 g/cm^2^ (95% CI, −1.88–1.54)
Law et al. 1997 | 57 (55–59) | 32 current smokers 135 never smokers | Radius | Difference in BMD^†^ between current smokers and nonsmokers = −0.17 g/cm^2^ (95% CI, −1.88–1.54)
Law et al. 1997 | 62 (60–64) | 27 current smokers 65 never smokers | Radius | Difference in BMD^†^ between current smokers and nonsmokers = −0.17 g/cm^2^ (95% CI, −1.88–1.54)
Jensen and Christiansen 1988 | 50 (44–53) | 56 current smokers 54 never/former smokers | Radius | No odds ratio was given for smoking
Jensen et al. 1985 | 51 (44–56) | 67 current smokers 69 never/former smokers | Radius | BMCΔ (g/cm) = 38.2 (95% CI, 20.9–48.7) in smokers compared with 38.0 (95% CI, 24.9–58.9) in nonsmokers
Slemenda et al. 1989 | 51 (45–57) | 21 current smokers 63 never/former smokers | Radius and lumbar spine | For current smokers of >20 pack-years^¶^, midradius had a −0.0034 g/cm^2^ (SD^‡^ = 0.169) change in bone mass/year, distal radius = −0.0071 (0.0180), and lumbar spine = −0.0261 (0.0476); for current smokers of <20 pack-years, midradius = −0.0023 (0.0135), distal radius = −0.0113 (0.0366), and lumbar spine = 0.0136 (0.0800); and for nonsmokers, midradius = −0.0072 (0.0111), distal radius = −0.0071 (0.0172), and lumbar spine = −0.0120 (0.0409)
McDermott and Witte 1988 | 53 (SD = 10) | 24 current smokers 24 never smokers | Radius | BMC (g/cm) midradius = 0.89 (0.03) for smokers compared with 0.87 (0.02) for nonsmokers (p = 0.66); distal radius = 0.87 (0.03) for smokers compared with 0.87 (0.03) for nonsmokers (p = 0.98)
Premenopausal
Guthrie et al. 1996 | 54 (48–57) | 7 current smokers 39 never/former smokers | Femur | Smoking was associated with a lower BMD
Cheng et al. 1991 | 54 (50–60) | 25 current smokers 82 never/former smokers | Calcaneus | BMD (g/cm^2^) was lower among smokers (0.170 [SD = 0.025]) than nonsmokers (0.180 [0.029] p >0.05)
Krall and Dawson-Hughes 1991 | 59 (40–70) | 35 current smokers 267 never/former smokers | Femur | Mean BMD (g/cm^2^) of current smokers = 0.611 (SD = 0.012) for radius, 0.787 (0.015) for femoral neck, and 1.084 (0.021) for spine; for current nonsmokers radius = 0.614 (0.005), femoral neck = 0.793 (0.007), and spine = 1.080 (0.009)
Hopper and Seeman 1994 | 62 (50–73) | 7 current smokers 7 nonsmokers | Femur | Study of twins discordant for tobacco use, by menopause status, BMD was lower for the twin who smoked more heavily
Sowers et al. 1985 | 62 (55–80) | 119 current smokers 278 never smokers | Radius | Mean BMD^†^ = 0.633 (SD^‡^ = 0.014) for smokers of 1–9,000 pack-days, and 0.637 (SD = 0.014) for >9,000 pack-days compared with 0.625 (SD = 0.005) for nonsmokers (findings were not significant); adjusted for age to 66 years and median muscle mass
Hansen et al. 1991 | 63 (59–67) | 61 current smokers 60 never/former smokers | Femur | Smokers had a lower BMD (g/cm^2^) 0.69 (SD = 0.11) than nonsmokers 0.65 (0.09)
Egger et al. 1996 | 66 (63–68) | 23 current smokers 99 never smokers | Femur and lumbar spine | Mean (g/cm^2^) change/decade of smoking = −0.015 (95% CI, −0.028 to −0.003) for lumbar spine and −0.004 (−0.012 to −0.003) for femoral neck; adjusted for age, weight, height, alcohol use, calcium intake, and physical activity
Holló et al. 1979 | 68 (61–75) | 41 current smokers 125 never smokers | Radius | Smokers had a lower BMCΔ (0.68 g/cm [SD = 0.10]) than nonsmokers (0.72 [0.10]), p <0.05
Nguyen et al. 1994 | 70 (>60) | 102 current smokers 765 never smokers | Femur and lumbar spine | Lumbar spine BMD = 0.96 g/cm^2^ (SD = 0.22) for current smokers, 1.03 (0.17) for former smokers, and 1.02 (0.19) for never smokers; femoral neck BMD = 0.73 (0.10) for current smokers, 0.78 (0.12) for former smokers, and 0.79 (0.13) for never smokers (p <0.05 for current smokers vs. nonsmokers for both comparisons)
Jensen 1986 | 70 (70) | 77 current smokers 103 never smokers | Radius | 40.3% of smokers and 44.7% of nonsmokers had some type of fracture (hip, proximal, distal radius, vertebral, or long bones)
Johansson et al. 1992 | 70 (70) | 38 current smokers 200 never smokers | Calcaneus | r = 0.15, p <0.01 comparing current, former, and nonsmokers
Rundgren and Mellström 1984 | 70 (70) | 43 current smokers 243 never smokers | Calcaneus | Among 70-year-old current smokers, BMD (μm) = 784 (SD = 252) compared with former smokers (884 [280], p <0.05) and nonsmokers (928 [273], p <0.001); among current smokers aged 75 years, 759 (260) compared with former smokers (950 [282], p <0.05) and nonsmokers (878 [268], p <0.01); and among current smokers aged 79 years, 554 (258) compared with former smokers (748 [372], p <0.05) and nonsmokers (807 [329], p <0.001)
Rundgren and Mellström 1984 | 75 (75) | 49 current smokers 364 never smokers | Calcaneus
Rundgren and Mellström 1984 | 79 (79) | 19 current smokers 218 never smokers | Calcaneus
Bauer et al. 1993 | 71 (65–84) | 485 current smokers 4,367 never smokers | Radius | Percentage change in bone mass (g/cm^2^) = −0.04 (95% CI, −0.9–0.8) for lifetime cigarettes smoked (per 20 pack-years)
Kiel et al. 1996 | 74 (68–98) | 77 current smokers 340 never smokers | Femur | Among estrogen users, current smokers had a lower BMD of the trochanter (0.589 g/cm^2^) than nonsmokers (0.640, p = 0.05)
Cheng et al. 1993 | 75 (75) | 10 current smokers 161 never smokers | Calcaneus | Current smokers had a lower mean BMD (0.114 g/cm^3^ [SD = 0.023]) than nonsmokers (0.129 [0.036] p >0.05)
Hollenbach et al. 1993 | 76 (60–89) | 42 current smokers 320 never smokers | Femur | Current smokers had a lower mean femoral neck BMD (0.608 [SD = 1.008]) than nonsmokers (0.632 [0.005] p <0.01)

* Note: See Figure 6.2 for results. The order of the studies in this table reflects the order of the regression lines in Figure 6.2.

† BMD = Bone mineral density.

‡ SD = Standard deviation.

§ CI = Confidence interval.

Δ BMC = Bone mineral content.

¶ Pack-years = The number of years of smoking multiplied by the number of packs of cigarettes smoked per day.

Table 6.16 Studies on the association between smoking status and bone density in men and women published since the 1997 meta-analysis by Law and colleagues

Study | Population/age (years) | Smoking status | Measurement/site | Findings
Women
Brot et al. 1997 | 433 perimenopausal Danish women aged 45–58 years; 87 were followed for 2 years | 49% current smokers 39% never smokers 12% former smokers | A BMC^*^ of the whole body was measured at enrollment and after 1 and 2 years | Smoking (pack-years^†^) was a significant and independent predictor of total BMC (p <0.001)
Takada et al. 1997 | 3,867 premenopausal and postmenopausal Japanese women aged 37–69 years | A dichotomous category for current smoking (yes/no), but no data were provided | BMD^‡^ at the distal radius 1/3 of the distance from the wrist to the elbow | The combined variable of no drinking (consumption of alcohol ≤3 days/week) and current smoking has a statistically significant negative effect on radial BMD among older (56–69 years) women (p <0.05)
Grainge et al. 1998 | 580 postmenopausal women aged 45–59 years | 25.7% current smokers 74.3% nonsmokers at the time of the scan | BMD of the spine, hip, radius/ulna, and whole body | BMD was more strongly related to the number of months of smoking than to pack-years at all 5 sites (p <0.05 at all sites except the femoral neck)
Smeets-Goevaers et al. 1998 | 5,896 perimenopausal white Dutch women aged 46–54 years | Never smokers; former or current smokers were said to be identified, but no data were provided | BMD of the spine | Increased risks for a low BMD (osteopenia and osteoporosis) were associated with smoking (odds ratio = 1.25 [95% confidence interval, 1.08–1.44])
Cheng et al. 1999 | 200 white women aged 20–79 years | 38% had a history of tobacco use (average 8.2 packs/year) 7% current smokers | BUA^§^ of the calcaneus | Smoking was not associated with the BUA (p >0.05)
Gregg et al. 1999 | 393 women aged 45–53 years (7.4% white; 12.2% perimenopausal or post- menopausal) | 9.2% current smokers | BUA and SOSΔ of the calcaneus; BMD of the spine and hip | Smoking was not significantly associated with the calcaneal BUA or SOS
Jones and Scott 1999 | 263 premenopausal women; mean age 33 ± 4.5 years | 45% current smokers | BMD of the spine, hip, and whole body | Current smoking was associated with a significantly lower BMD at the hip and a lower BMD (not significant) at the spine and whole body
Varenna et al. 1999 | 6,160 postmenopausal Italian women; mean age 54.5 ± 6.4 years | 74.9% never smokers 5.0% former smokers 20.1% current smokers | BMD of the spine | Smoking was not associated with BMD or a risk for osteoporosis
Kim et al. 2000 | 238 Korean women; mean age 24.2 ± 2.5 years scanned only as a reference population 552 postmenopausal Korean women; mean age 62.5 ± 8.2 years | Data were not reported | BUA^§^ of the calcaneus | There was no association between a history of smoking and low quantitative ultrasound values after controlling for age and time since menopause
Men
Vogel et al. 1997 | 1,303 men of Japanese descent living in Hawaii; aged 61–82 years | 35% never smokers 45% former smokers 20% current smokers | BMD^‡^ of the calcaneus, and distal and proximal radius | Current and former smokers had a 1.8–4.8% lower BMD in the calcaneus and distal radius
Hagiwara and Tsumura 1999 | 1,736 Japanese men aged 20–64 years | 35.5% nonsmokers 15.7% former smokers 48.8% current smokers | BMD of the calcaneus | Men in the highest BMD quintile were younger, with a higher body mass index and a lower mean pack-year history than men in the lowest quintile
Huuskonen et al. 2000 | 140 Finnish men aged 54–63 years | Mean pack-years = 19.0 (range 1–59.5) | BMD of the neck, trochanter, Ward’s triangle, and L2–L4 | Correlation coefficient = 0.04, −0.01, 0.05, and −0.10 with pack-years for the neck, trochanter, Ward’s triangle, and L2–L4 (p >0.05), respectively

* BMC = Bone mineral content.

† Pack-years = The number of years of smoking multiplied by the number of packs of cigarettes smoked per day.

‡ BMD = Bone mineral density.

§ BUA = Broadband ultrasound attenuation.

Δ SOS = Speed of sound.

Table 6.17 Cohort studies on the association between smoking status and the risk of bone loss in men and women

Study | Population/age (years) | Smoking status | Measurement/site | Findings
Slemenda et al. 1989 | 84 perimenopausal and postmenopausal women followed for 3½ years | Data were not reported | BMD^*^ of the midradius, distal radius, and the lumbar spine | Heavy smokers (≥20 pack-years^†^) had significantly (p <0.05) lower radial (midradius = 0.76 [standard deviation (SD) ±0.10] g/cm, distal radius = 0.83 [±0.12] g/cm^2^) and vertebral (lumbar spine = 0.82 [±0.16] g/cm^2^) BMD than nonsmokers (0.84 [±0.11], 0.91 [±0.13], and 0.94 [±0.15] g/cm^2^, respectively); there were no significant differences between light smokers (<20 pack-years) and nonsmokers; there were no detect-able effects of smoking on the rates of bone loss at any site
Krall and Dawson-Hughes 1991 | 320 postmenopausal women aged 40–70 years; 2-year calcium supple-mentation trial | 55% never smokers 35% former smokers (>1 month before trial) 11% smoked during all or part of the trial | BMD of the radius, femoral neck, Os calcis, and the spine | Adjusted mean (±SD) annualized rate of bone change from the radius was greater among smokers than nonsmokers (−0.914 [±2.624]%/year, n = 34, vs. 0.004 [±2.568]%/year, n = 278, respectively; p = 0.05); variables adjusted for include supplement type (placebo, citrate malate, or calcium carbonate), current alcohol status (user or nonuser), and caffeine intake; this same significant trend was observed at 3 other sites
Slemenda et al. 1992 | 111 male veterans of World War II or the Korean War born between 1916 and 1927, all twin pairs; 16-year follow-up | Monozygotic male twins (n = 57) had mean 10.9 ± 14.9 cigarettes/day; dizygotic twins (n = 54) had mean 14.4 ± 15.9 cigarettes/day | BMD of the radius | −0.100 g/cm (standard error ±0.036) (p = 0.007) for cigarette smoking; the twin who smoked more lost more bone (p = 0.005); men with cigarette and alcohol use above median levels had the most rapid losses
Sowers et al. 1992 | 217 women aged 22–54 years; 5-year follow-up | Mean lifetime packs of cigarettes = 2,447 | BMD of the distal radius | In postmenopausal women, but not premenopausal women, smoking at baseline was associated with a lower BMD at follow-up
Jones et al. 1994 | 626 (385 women, 241 men); average follow-up was 2.5 years | Women had a median of 9 pack-years of smoking; men had a median of 31 pack-years of smoking | BMD of the hip and the spine | There were no differences in the rates of loss between current smokers and nonsmokers
Vogel et al. 1997 | 1,303 Japanese American men aged 51–82 years; average follow-up was 5 years | 20% current smokers 45% former smokers 35% never smokers | BMD of the distal and proximal radius and the calcaneus | Compared with never smokers, current smokers had significantly greater rates of bone loss: 29.4% from the calcaneus (p <0.001) and 33.8% from the distal radius (p <0.01); analyses were adjusted for age, height, weight, physical activity, and alcohol and thiazide use
Burger et al. 1998 | 1,856 Dutch men (mean age, 66.7 years), 2,452 Dutch women (mean age 67.2 years); average follow-up was 2 years | Current smokers Men (23%) Women (19%) | BMD of the hip | Smoking was accompanied by a significantly higher rate of bone loss in both men and women (men, p = 0.02; women, p = 0.01); the association was stronger when not adjusting for body mass index
Guthrie et al. 1998 | 224 women (74 premenopausal, 90 perimenopausal, and 60 postmenopausal); follow-up was 2 years | Premenopausal women 14% current smokers Early perimenopausal women 14% current smokers Late perimenopausal women 25% current smokers Postmenopausal women 15% current smokers | BMD^*^ of the hip and the spine | Of the women who became postmenopausal during the study, 6 were current smokers and their mean annual change in spine BMD was slightly greater (−3.3%) than that of the 36 nonsmokers (−2.3%); p = 0.10
Krall and Dawson-Hughes 1999 | 402 elderly men and women (32 smokers, 370 nonsmokers); 3-year placebo-controlled study | Smokers 42% men 53% women Nonsmokers 45% men 55% women | BMD at the femoral neck, total body, and the spine | BMD losses (adjusted for baseline BMD, weight, age, gender, supplementation status, and dietary calcium intake) were higher in smokers than in nonsmokers at the femoral neck (−0.714 g/cm [standard error = (±0.285)%/year vs. 0.038 [±0.084]%/year, p <0.02]), and total body (−0.360 [±0.101]%/year vs. −0.152 [±0.030]%/year, p <0.05); there were no significant differences at the spine (0.260 [±0.252]%/year in smokers vs. 0.593 [±0.074]%/year in nonsmokers, p = 0.21)
Hannan et al. 2000 | 468 women, 273 men (mean age 74.5 years); average follow-up was 4 years | Current smokers Women (10%) Men (8%) | BMD of the hip, spine, and radius | Compared with women who had never smoked, female current smokers had no increase in bone loss; in men, current smokers had greater bone loss (4–5%) than never smokers

* BMD = Bone mineral density.

† Pack-years = The number of years of smoking multiplied by the number of packs of cigarettes smoked per day.

##### Peak Bone Mass

Because BMD increases rapidly during adolescence, initiating smoking around the time of puberty might reduce peak BMD. However, the effects of smoking on the attained level of peak bone mass are uncertain because there are limited data on the skeletal effects of smoking during adolescence. Furthermore, it is possible that relatively short exposures in this age group would have little effect on bone density measurements. One prospective cohort study of children and adolescents (aged 9 to 18 years) in Finland repeatedly ascertained lifestyle factors and followed participants for 11 years, at which time they underwent bone density testing (Välimäki et al. 1994). In men, but not in women, smokers had lower BMD measurements of the hip and spine than did nonsmokers after adjusting for covariates. A cross-sectional study of 15-year-old Swedish adolescents did not find an association between smoking and total body bone mineral content (Lötborn et al. 1999). Findings were similar in a cross-sectional study of 500 children aged 4 to 20 years in the Netherlands, but only 32 were smokers (Boot et al. 1997).

Data are available from studies of premenopausal women, starting from the ages at which peak BMD is reached. A meta-analysis of cigarette smoking, BMD, and the risk for hip fractures (Law and Hackshaw 1997) identified 10 cross-sectional studies of premenopausal women (Johnell and Nilsson 1984; McCulloch et al. 1990; Mazess and Barden 1991; Daniel et al. 1992; Fehily et al. 1992; Sowers et al. 1992; Hopper and Seeman 1994; Ortego-Centeno et al. 1994; Välimäki et al. 1994; Law et al. 1997). Additional study populations included menopausal and postmenopausal women (Table 6.15). As shown in Table 6.15, the mean ages of women in the study samples ranged from 22 to 76 years. Because absolute bone density units varied among studies according to the bone site assessed and the measurement technique used, the difference between the average BMD of current smokers and nonsmokers in each of the studies was recorded as a proportion of one between-person standard deviation. In combining the studies, each bone density difference was weighted by the inverse of its variance and was age-adjusted only.

Bone densities were reported for current smokers compared with never smokers in most studies, but were reported for current compared with former and lifetime never smokers combined in a few studies. There was no evidence of a significant difference in BMD between smokers and nonsmokers in the pre-menopausal women (Figure 6.2). Two additional studies of premenopausal and postmenopausal women performed since the 1997 meta-analysis also show no significant differences in BMD between smokers and nonsmokers (Table 6.16) (Takada et al. 1997; Gregg et al. 1999); however, a study of premenopausal women from Australia did find a significantly lower BMD in female current smokers that was not found in the subgroup of female smokers who participated in sports (Jones and Scott 1999). Cross-sectional data from the Danish Osteoporosis Prevention Study showed lower BMD in current smokers compared with lifetime non-smokers in perimenopausal women (Hermann et al. 2000). It is appropriate to consider these results unadjusted for other covariates in that adjusting for one of the most important risk factors for bone density— weight—actually may mask an association. Smoking-induced weight loss may represent an intervening variable in the causal chain between smoking and bone density reduction.

Figure 6.2 Differences (95% confidence intervals), as a proportion of 1 standard deviation (SD), in bone mineral density between female smokers and nonsmokers according to age and menopausal status

Note: Fitted regression lines are shown. The 11 open circles refer to two studies (Rundgren and Mellström 1984; Law et al. 1997); the 28 solid circles refer to the other studies in the order listed in Table 6.15 (Fehily et al. 1992 through Johnell and Nilsson 1984 for premenopausal women, and Law et al. 1997 through Hollenbach et al. 1993 for postmenopausal women).

Source: Law and Hackshaw 1997, p. 843. Reprinted with permission.

One study from Spain assessed smoking and BMD in healthy young males (Ortego-Centeno et al. 1997). In this study, male volunteers aged 20 through 45 years were measured for BMD in the lumbar spine and proximal femur; blood biochemical markers were also assessed. BMD was significantly lower for smokers of 20 or more cigarettes per day compared with nonsmokers. In multiple regression analyses considering all smokers, smoking was not significantly associated with measures of BMD. Interpretations of these findings are limited by the cross-sectional data and the small sample size.

##### Smoking Cessation and Bone Mineral Density Loss

Two prospective cohort studies assessed smoking cessation and BMD in men and women (Hollenbach et al. 1993; Kiel et al. 1996). In a study in Rancho Bernardo, California, Hollenbach and colleagues (1993) found that smoking cessation later in life was beneficial for men and women in halting BMD loss at hip sites (intertrochanter, total hip, femoral neck, and trochanter) where BMD is reduced in smokers. In men, smoking cessation was followed by a reduction in the rate of loss of the spinal BMD, and women experienced a significant decrease in the rate of BMD loss at the midradius after quitting. In the Framingham study, current or former smoking (past 10 years) was not associated with a lower BMD loss at any skeletal site among women who had not taken estrogen but it was in women who had (Kiel et al. 1996). Former male smokers who had quit for less than 10 years had a lower BMD than men who had quit for 10 or more years, independent of weight, alcohol consumption, or caffeine use.

#### Evidence Synthesis

Smoking, even at a young age, might increase risk for osteoporosis later in life if it reduces the peak bone mass attained, thereby compromising the peak from which decline begins. Only a few studies address smoking during adolescence, and the findings in women during the premenopausal years are conflicting, are not based on large studies, and do not provide strong evidence for an effect of smoking on BMD before menopause. For males, data are scant for this age range. Although an effect of smoking on BMD is plausible, the available evidence from observational studies is limited and inconsistent.

#### Conclusion

1. The evidence is inadequate to infer the presence or absence of a causal relationship between smoking and reduced bone density before menopause in women and in younger men.

#### Implications

The failure to demonstrate a causal relationship between smoking and bone density in young women does not detract from the basis for concern about smoking and osteoporosis in women. For women, smoking patterns established in younger years are likely to persist past menopause, and there is substantial evidence linking smoking to low bone density during menopause (see below). Future research should quantify the combined and cumulative effects of premenopausal and postmenopausal smoking on bone density. More research is needed in young men regarding the relationship between smoking and bone density.

### Bone Density in Middle and Later Years of Life

#### Epidemiologic Evidence

In contrast to the findings for younger persons, findings of bone density studies performed in populations well beyond the years of peak bone mass demonstrate substantial differences between smokers and nonsmokers. As illustrated in Figure 6.2, based on the meta-analysis by Law and Hackshaw (1997), bone density was lower in smokers than in nonsmokers for post-menopausal women, and the difference increased linearly with age. For every 10-year increase in age, the bone density of smokers fell below that of non-smokers by approximately 2 percent of the average bone density at the time of menopause, regardless of the skeletal site that was measured.

Since the publication of this meta-analysis, there have been additional studies of smoking and bone density in postmenopausal women and in men. Of four studies that did not demonstrate an association between smoking and bone density (Cheng et al. 1999; Varenna et al. 1999; Huuskonen et al. 2000; Kim et al. 2000), two had used quantitative ultrasound to measure bone status. Seven other studies did demonstrate statistically significant associations between smoking and BMD (Table 6.16) (Brot et al. 1997; Takada et al. 1997; Vogel et al. 1997; Grainge et al. 1998; Smeets-Goevaers et al. 1998; Hagiwara and Tsumura 1999; Hermann et al. 2000).

Data from cohort studies of older men and women also implicate smoking as a significant risk factor for bone loss (Table 6.17). Of the six studies that reported smoking data (three involving women and men, two involving women only, and one involving men only) (Sowers et al. 1992; Jones et al. 1994; Vogel et al. 1997; Burger et al. 1998; Guthrie et al. 1998; Hannan et al. 2000), three documented significantly more bone loss in female smokers than in female and male nonsmokers (Sowers et al. 1992; Burger et al. 1998; Guthrie et al. 1998), and three reported higher rates of loss among male smokers than among male nonsmokers (Vogel et al. 1997; Burger et al. 1998; Hannan et al. 2000). Interpretations of several of the studies are constrained by relatively small sample sizes and limited durations of follow-up.

#### Evidence Synthesis

Extensive and consistent data are available on BMD and smoking for perimenopausal and postmenopausal women and for older men. Data from cohort studies, which track changes in BMD over time, as well as from cross-sectional studies provide generally consistent evidence of increased rates of loss in postmenopausal women who smoke compared with nonsmokers. Smoking cessation appears to benefit BMD since limited data indicate higher rates of BMD loss for heavier smokers. Data are more limited for men. The 2001 Surgeon General’s report (USDHHS 2001) found the evidence to be consistent for women and concluded that “Postmenopausal women who currently smoke have lower bone density than do women who do not smoke” (p. 321). There are a number of mechanisms that may underlie this finding.

#### Conclusions

1. In postmenopausal women, the evidence is sufficient to infer a causal relationship between smoking and low bone density.
2. In older men, the evidence is suggestive but not sufficient to infer a causal relationship between smoking and low bone density.

#### Implications

Smoking has an adverse effect on bone density in middle and later years of life; for every 10-year increase in age, the bone density of female smokers falls below that of nonsmokers by about a 0.14 standard deviation, or 2 percent of the average bone density at the time of menopause in women. Because a 1.0 standard deviation decrease in bone density doubles the risk of fracture, and because fracture incidence increases with age (Melton and Riggs 1987; Melton et al. 1987), the proportion of all fractures attributable to smoking would be expected to increase for smokers who continue smoking into older ages. Attempts to decrease smoking as early in life as possible are likely to reduce fractures that would be caused by smoking in old age.

Because bone loss is relatively small over short periods of time, studies with longer durations of follow-up and minimal avoidable losses of participants at follow-up could add important information to the understanding of how smoking contributes to bone loss. Additional information is likely to come from studies of biochemical markers of bone turnover, which might further the understanding as to mechanisms whereby smoking accelerates bone loss.

### Fractures

#### Epidemiologic Evidence

Hip fractures, the most frequently studied fractures in relation to smoking, account for a significant proportion of the morbidity and mortality attributed to osteoporosis. The meta-analysis by Law and colleagues (1997) reviewed 19 cohort and case-control studies of the risk of hip fractures in postmenopausal women according to whether they had COPDs. The studies differed with regard to the ages of the participants, duration of follow-up, and whether former smokers were included in the smoking or nonsmoking groups. Table 6.18 shows the characteristics of each of the 19 studies, demonstrating the range of ages at the time of the fracture. For the cohort studies, the duration of follow-up ranged from three years (Forsén et al. 1994) to 26 years (Kiel et al. 1992). Figure 6.3 shows the risk of hip fractures in smokers relative to non-smokers according to age; the risks for smokers increased with increasing age. Major conclusions of the meta-analysis include (1) smoking has no material effect on bone density in premenopausal women; (2) postmenopausal bone loss is greater in smokers—an additional 0.2 percent of bone mass each year; (3) in comparisons of women who are current smokers with women who are nonsmokers, the risk of hip fracture is estimated to be 17 percent greater at 60 years of age, 41 percent greater at 70 years, 71 percent greater at 80 years, and 108 percent greater at 90 years; and (4) the estimated cumulative risk of hip fracture to 85 years of age in women is 19 percent in smokers and 12 percent in nonsmokers; to 90 years it is 37 percent and 22 percent, respectively. The data for men were much more limited but suggested similar consequences.

Table 6.18 Studies on the association between smoking and the risk of hip fractures in men and women used in the 1997 meta-analysis by Law and Hackshaw^*^

Study | Age at entry (years) | Mean age at fracture (years) | Number of persons (% smokers) | | Findings
Study | Age at entry (years) | Mean age at fracture (years) | With fracture | Without fracture | Findings
Cohort studies
Hemenway et al. 1988 | 34–59 | 53 | 662 | 68,056 (28) | Compared with nonsmokers, RR^†^ = 0.98 (95% CI^‡^, 0.84–1.14) for former smokers, 0.95 (95% CI, 0.71–1.20) for current smokers of 1–14 cigarettes/day, 0.97 (95% CI, 0.79–1.20) for current smokers of 15–24 cigarettes/day, and 0.99 (95% CI, 0.78–1.25) for current smokers of ≥25 cigarettes/day
Meyer et al. 1993 | 35–49 | 56 | 124 | 20,881 (37) | Compared with never smokers, the age-adjusted RR = 0.81 (95% CI, 0.45–1.46) for former smokers, 1.04 (95% CI, 0.71–1.53) for current smokers of 1–14 cigarettes/day, and 1.46 (95% CI, 0.81–2.64) for current smokers of ≥15 cigarettes/day
Holbrook et al. 1988 | 50–79 | 75 | 33 | 924 | RR = 1.1 (not significant) for smokers compared with nonsmokers; adjusted for age, gender, body mass index (BMI), and alcohol use
Kiel et al. 1992 | 28–62 | 75 | 167 (22) | 2,243 (37) | Compared with never smokers, the age-adjusted RR = 1.08 (95% CI, 0.82–1.42) for ever smokers, 0.97 (95% CI, 0.68–1.39) for former smokers, 1.19 (95% CI, 0.84–1.69) for all current smokers, 1.16 (95% CI, 0.80–1.67) for light smokers (≤1 pack/day), and 1.45 (95% CI, 0.66–3.17) for heavy smokers (>1 pack/day)
Cummings et al. 1995 | ≥65 | 78 | 192 | 9,324 (10) | Age-adjusted RR = 2.1 (95% CI, 1.4–3.3) for current smokers compared with never smokers
Forsén et al. 1994 | ≥50 | 78 | 220 (16) | 14,598 (20) | Incidence rates/1,000 person-years for current smokers compared with nonsmokers for men: 1.3 (SD^§^ = 0.4) for ages 50–64 years, 3.4 (SD = 1.3) for 65–74 years, 10.3 (SD = 6.4) for ≥75 years; for women: 2.1 (SD = 1.4) for 50–64 years, 7.8 (SD = 3.5) for 65–74 years, and 23.9 (SD = 16.6) for ≥75 years
Paganini-Hill et al. 1991 | All ages | 82 | 242 (13) | 5,558 (13) | Compared with never smokers, the age-adjusted RR = 1.8 (p <0.001) for current female smokers and 2.2 (p <0.05) for current male smokers
Case-control studies
Wickham et al. 1989 | ≥65 | 88 | 44 | 1,375 | Crude ORΔ = 5.6 (95% CI, 1.8–17.7) for current smokers compared with nonsmokers
La Vecchia et al. 1991 | 29–74 | 62 | 158 (11) | 1,096 (6) | Compared with never smokers, RR = 1.7 (95% CI, 1.0–3.0) for former smokers and 1.5 (95% CI, 1.0–2.1) for current smokers; adjusted for age, area of residence, education, BMI, menopausal status, ERT^¶^, and alcohol use
Williams et al. 1982 | 50–74 | 64 | 160 (60) | 567 (53) | Age-standardized OR for ≥1 year of estrogen use compared with obese (based on Ponderal index: height = inches/cubed root of weight [pounds]; obese = 9.6–12.5, average = 12.6–13.5, thin = 13.6–15.5) never smokers: obese ever smokers = 1.3 (95% CI, 0.4–4.5), average never smokers = 2.1 (95% CI, 0.7–5.9), average ever smokers = 2.1 (95% CI, 0.8–5.8), thin never smokers = 2.7 (95% CI, 0.5–14.0), and thin ever smokers = 6.4 (95% CI, 2.1–19.4)
Kreiger et al. 1982 | 45–74 | 66 | 98 | 801 | No OR was given for smoking
Michaelsson et al. 1995 | 40–75 | 68 | 205 (18) | 765 (10) | Compared with never smokers, OR = 1.50 (95% CI, 1.10–2.05) for ever smokers, 1.17 (95% CI, 0.74–1.86) for former smokers of <20 pack-years^**^, 1.94 (95% CI, 0.96–3.92) for former smokers of ≥20 pack-years, 1.91 (95% CI, 1.12–3.26) for current smokers of <20 pack-years, and 1.82 (95% CI, 1.03–3.20) for current smokers of ≥20 pack-years
Kreiger et al. 1992 | 50–84 | 74 | 102 (29) | 277 (17) | OR = 1.73 (95% CI, 0.90–3.32) for current smokers compared with never or former smokers; adjusted for age, dietary calcium, ovariectomy, ERT^¶^ (months), and Quetelet index (g/cm^2^)
Grisso et al. 1994 | ≥45 | 75 | 109 (29) | 169 (15) | Compared with never smokers, OR = 1.2 (95% CI, 0.6–2.4) for former smokers, 1.3 (95% CI, 0.7–2.6) for all current smokers, 1.1 (95% CI, 0.5–2.4) for current smokers smoking <1 pack/day, and 2.0 (95% CI, 0.7–6.0) for those smoking ≥1 pack/day
Paganini-Hill et al. 1981 | <80 | 75 | 83 (35) | 166 (30) | Compared with never smokers, OR = 1.05 for current smokers of 1–10 cigarettes/day, and 1.96 for ≥11 cigarettes/day; adjusted for estrogen and ovarian status
Jaglal et al. 1993 | 55–84 | 75 | 381 (22) | 1,138 (16) | Compared with zero pack-years, crude OR for 1–29 pack-years = 1.02 (95% CI, 0.72–1.43), 30–59 pack-years = 1.49 (95% CI, 1.01–2.21) and ≥60 pack-years = 1.43 (95% CI, 0.73–2.79)
Lau et al. 1988 | All ages | 76 | 400 | 800 | RR = 1.3 (95% CI, 1.0–1.7) for current or former smokers compared with never smokers
Cooper et al. 1988 | ≥50 | 78 | 300 (48) | 600 (37) | RR = 1.7 (95% CI, 1.2–2.3) for ever smokers compared with never smokers
Cumming and Klineberg 1994 | ≥65 | 82 | 209 | 207 | Compared with never smokers, OR for ever smokers = 1.6 (95% CI, 1.0–2.6), former smokers = 1.4 (95% CI, 0.8–2.5), and current smokers = 2.2 (95% CI, 1.1–4.6); adjusted for age, gender, and proxy status (when relevant)

* Note: The order of the studies in this table reflects the order of the regression lines in Figure 6.3.

† RR = Relative risk.

‡ CI = Confidence interval.

§ SD = Standard deviation.

Δ OR = Odds ratio.

¶ ERT = Estrogen replacement therapy.

** Pack-years = The number of years of smoking multiplied by the number of packs of cigarettes smoked per day.

Source: Law and Hackshaw 1997.

Figure 6.3 Relative risk (95% confidence intervals) of hip fracture in smokers compared with nonsmokers in postmenopausal women according to age

Note: Each cohort study (8 solid circles) and case-control study (11 open circles) is in the same order as in Table 6.18. Fitted regression (dotted) line is shown.

Source: Law and Hackshaw 1997, p. 844. Reprinted with permission.

Since the publication of the meta-analysis by Law and colleagues (1997), some (Forsén et al. 1998; Burger et al. 1999; Kanis et al. 1999; Melhus et al. 1999; Baron et al. 2001) but not all subsequent studies of hip fracture (Fujiwara et al. 1997; Clark et al. 1998; Mussolino et al. 1998) have continued to show an association between smoking and an increased risk of hip fracture (Table 6.19). These studies have used various designs and have been carried out in diverse populations.

Table 6.19 Studies on the association between smoking and the risk of hip fractures in men and women reported since the 1997 meta-analysis by Law and Hackshaw

Study | Design | Population | Findings
Fujiwara et al. 1997 | Cohort | 1,586 Japanese men, 2,987 Japanese women; mean age 58.5 ± 12.2 years; during and up to the 14-year follow-up, 55 incidents of hip fractures not attributable to traffic accidents were identified | Smoking was not related to a risk for hip fractures
Grisso et al. 1997 | Case-control | 356 men with radiologically confirmed hip fractures, 402 controls from 20 hospitals in Philadelphia, Pennsylvania, and 14 Kaiser Permanente hospitals in northern California | Men in the lowest quintile of body mass had an OR^*^ = 3.8 (95% CI^†^, 2.3–6.4) compared with the highest quintile
Clark et al. 1998 | Case-control | 45 Mexican men and 107 Mexican women with hip fractures, aged ≥45 years (mean age was 70.2 for men, 73.5 for women); 143 healthy controls (37 men, 106 women) without hip fractures, mean age was 68.9 for men, 71.1 for women | Smoking was not associated with the risk of a hip fracture
Forsén et al. 1998 | Cohort | 14,428 Norwegian men, 15,364 Norwegian women aged ≥50 years; during the 3-year follow-up, 421 new cases of hip fractures were identified | Among the persons aged ≤75 years, the RR^‡^ of a hip fracture was elevated for current smokers (men = 5.0 [95% CI, 1.5–16.9]; women = 1.9 [95% CI, 1.2–3.1]); for former smokers, including those who had quit smoking >5 years previously, men = 4.4 (95% CI, 1.2–15.3); women = 1.3 (95% CI, 0.6–3.0)
Mussolino et al. 1998 | Cohort | 2,879 white U.S. men aged 45–74 years; during the 22-year follow-up, 71 cases of hip fractures were identified | Smoking was not significantly associated with hip fractures
Turner et al. 1998 | Cross-sectional | 2,325 women aged ≥50 years from the Third National Health and Nutrition Examination Survey were queried about their history of a wrist or hip fracture | The bivariate analysis showed that the percentage of former smokers in the wrist or hip fracture group was greater than in the nonfracture group; smoking was not associated with fractures in multivariate analyses
Burger et al. 1999 | Cohort | 2,193 Dutch men, 3,015 Dutch women aged ≥55 years; during a 4-year follow-up, 47 persons (14 men) experienced their first hip fracture | When adjusted for age and gender, current smoking was a statistically significant indicator of hip fracture risk (OR = 2.6 [95% CI, 1.4–5.1])
Cornuz et al. 1999 | Cohort | 116,229 female nurses (98% white) aged 34–59 years; during a 12-year follow-up, 377 hip fractures occurred because of low or moderate trauma | Current smokers experienced higher rates of hip fractures than never smokers; the risk increased with the number of cigarettes smoked daily; the age-adjusted RR of hip fracture was 1.3 (95% CI, 1.0–1.7) for all cigarette smokers and 1.6 (95% CI, 1.1–2.3) for those who smoked ≥25 cigarettes/day (p = 0.09 for trend); 10 years after quitting, the risk of a fracture was no longer significant
Høidrup et al. 1999 | Cohort | 6,159 postmenopausal Danish women; during a 15- to 17-year follow-up, 363 hip fractures were identified and validated | The use of hormone replacement therapy was associated with a lower risk for a hip fracture in former (RR = 0.55 [95% CI, 0.22–1.37]) and current (RR = 0.61 [95% CI, 0.38–0.99]) smokers but not in never smokers (RR = 1.10 [95% CI, 0.60–2.03])
Kanis et al. 1999 | Case-control | 730 southern European men with hip fractures aged ≥50 years (mean age 73.9); 1,132 age-stratified controls | A long history of smoking (>49 years) was associated with a significant increase in the risk of a hip fracture (RR = 1.44 [95% CI, 1.10–1.89]; p <0.01)
Melhus et al. 1999 | Case-control | 247 Swedish women with hip fractures and 873 controls, from a cohort study of 66,651 Swedish women aged 40–76 years | OR for hip fractures among current smokers was 2.1 (95% CI, 1.3–3.2); OR for hip fractures among current smokers with a low intake of vitamin E was 3.0 (95% CI, 1.6–5.4) and of vitamin C, 3.0 (95% CI, 1.6–5.6); OR decreased to 1.1 (95% CI, 0.5–2.4) and 1.4 (95% CI, 0.7–3.0) with high intakes of vitamins E and C, respectively; in current smokers with a low intake of vitamins E and C, OR increased to 4.9 (95% CI, 2.2–11.0)
Høidrup et al. 2000 | 3 population studies in Copenhagen, Denmark | 13,393 women and 17,379 men initially examined between 1964 and 1992, followed through 1997 | RR = 1.36 (95% CI, 1.12–1.65) for female and 1.59 (95% CI, 1.04–2.43) for male current smokers compared with nonsmokers; adjusted for body mass index
Huopio et al. 2000 | Cohort | 3,068 Finnish women aged 47–56 years; during 3.6 years of follow-up, 295 (8.4%) sustained a fracture | Smoking was associated with an increased risk of any fracture (RR = 1.8 [95% CI, 1.1–2.7]) independent of low spine or hip bone mineral density, previous fracture history, and 23 chronic illnesses
Kato et al. 2000 | Prospective cohort | 6,250 postmenopausal women aged 34–65 years at baseline; average 7.6 years follow-up | RR = 71.6 per 105 woman-years (the time from the baseline [first] examination to the date of first post-menopausal fracture) for hip fractures; risks increased with increasing age, body height, and total fat intake, and were lower for obese and African American women
Baron et al. 2001 | Case-control | 1,328 cases of postmenopausal women with a mean age of 72.5 years and low trauma hip fractures; 3,262 female controls of a similar age and residence | Current smokers had an increased risk for a hip fracture (OR = 1.66 [95% CI, 1.41–1.95]); the OR for a fracture was not significantly higher among former smokers (OR = 1.15 [95% CI, 0.97–1.37])

* OR = Odds ratio.

† CI = Confidence interval.

‡ RR = Relative risk.

Data on the association between smoking and fractures at other sites are more limited (Table 6.20). Studies from the 1980s and early 1990s that examined fractures other than those of the hip rarely found an association with smoking, although more recent studies have demonstrated positive associations between smoking and vertebral fractures (Scane et al. 1999; Lau et al. 2000), ankle fractures (Honkanen et al. 1998), and the general categories of nonhip fractures (Jacqmin-Gadda et al. 1998) and of all fractures (Huopio et al. 2000).

Table 6.20 Studies on the association between smoking and the risk of fractures at sites other than the hip in men and women

Study | Design | Population | Findings
Vertebral fracture
Aloia et al. 1985 | Age-matched case-control | 58 cases 58 controls Volunteer women Mean age 64 years United States | Percentage of smokers (p <0.01) Cases: 59% Controls: 30%
Kleerekoper et al. 1989 | Case-control | 266 cases 263 controls Postmenopausal women who were screened for an osteoporosis trial Aged 45–75 years United States | Percentage of current smokers (p >0.05) Cases: 27% Controls: 20%
Cooper et al. 1991 | Survey of general practice patients | 1,012 women Aged 48–81 years United Kingdom 79 fractures | Smoking >10 cigarettes/day for >10 years was not related to a risk for fractures
Santavirta et al. 1992 | Population-based survey | 27,278 females Aged ≥15 years Finland 105 fractures | RR^*^ = 1.1 (95% CI^†^, 0.6–2.0) for current smokers; adjusted for age, history of trauma, tuberculosis, peptic ulcer, BMI^‡^, and occupation
Scane et al. 1999 | Case-control | 91 men with vertebral fractures 91 age-matched controls Aged 27–79 years (median, 64) United Kingdom | Current smoking was associated with a significantly increased risk of a vertebral fracture (OR^§^ = 2.8 [95% CI, 1.2–6.7])
Lau et al. 2000 | Cross-sectional | 396 community-dwelling Chinese men Aged 70–79 years | Heavy smoking was a significant risk factor for a vertebral deformity (OR = 6.5 [95% CI, 1.3–32.7])
Distal forearm fracture
Williams et al. 1982 | Population-based case-control | 184 cases 567 controls Aged 50–74 years United States | There was a higher fracture risk in women smokers using estrogen
Kelsey et al. 1992 | Cohort | 9,704 women Aged ≥65 years United States 171 fractures over 2.2 years (mean) | RR = 1.0 (95% CI, 0.96–1.0) for current smokers (10 cigarettes/day) compared with never smokers
Kreiger et al. 1992 | Hospital case-control | Aged 50–84 years Canada 54 fractures | RR = 1.5 (95% CI, 0.9–2.6) for current smokers compared with former smokers or never smokers; adjusted for age and BMI^‡^
Mallmin et al. 1994 | Population-based case-control | 385 cases 385 controls Aged 40–80 years Sweden | RR = 0.9 (95% CI, 0.5–1.6) for current smokers; adjusted for multiple factors including age, BMI, physical activity, and hormone use
Honkanen et al. 1998 | Retrospective survey | 12,192 women Aged 47–56 years Finland 345 fractures | Current smoking: RR = 0.9 (95% CI, 0.6–1.4); any smoking: RR = 0.6 (95% CI, 0.3–1.1), 1–10 cigarettes/day; RR = 1.4 (95% CI, 0.9–2.3), >10 cigarettes/day; adjusted for age, BMI, menopausal status, and chronic health disorders
Kato et al. 2000 | Prospective cohort | 6,250 postmenopausal women aged 34–65 years at baseline; average 7.6 years follow-up | RR = 334.7 per 10^5^ woman-years (the time from the baseline [first] examination to the date of first post-menopausal fracture) for wrist fractures; risks increased with increasing age, body height, and total fat intake, and were lower for obese and African American women
Proximal humerus fracture
Kelsey et al. 1992 | Cohort | 9,704 women Aged ≥65 years United States 79 fractures over 2.2 years (mean) | RR = 1.2 (95% CI, 0.9–1.6) for current smokers (10 cigarettes/day)
Ankle fracture
Seeley et al. 1996 | Cohort | 9,704 women Aged ≥65 years 191 fractures over 5.9 years (mean) | There was no association with current smoking
Honkanen et al. 1998 | Retrospective survey | 12,192 women Aged 47–56 years Finland 210 fractures | Current smoking: RR = 2.2 (95% CI, 1.6–3.2); any smoking: RR = 1.6 (95% CI, 0.9–2.8), 1–10 cigarettes/day; RR = 3.0 (95% CI, 1.9–4.6) for >10 cigarettes/day; adjusted for age, BMI, menopausal status, and chronic health disorders
Foot fracture
Seeley et al. 1996 | Cohort | 9,704 women Aged ≥65 years 204 fractures over 5.9 years (mean) | There was no association with current smoking
Nonhip fracture
Jacqmin-Gadda et al. 1998 | Cohort | 3,216 French men and women aged ≥65 years (mean age 74.8); during a 5-year follow-up, 265 persons (8.2%) reported 1 fracture, 19 (0.6%) reported 2 fractures, and 1 (0.03%) reported 3 fractures | Current smoking was associated with a higher risk for nonhip fractures (OR = 1.68 [95% CI, 1.08–2.60]), but not for hip fractures (OR = 0.73 [95% CI, 0.24–2.20])

* RR = Relative risk.

† CI = Confidence interval.

‡ BMI = Body mass index.

§ OR = Odds ratio.

##### Smoking Cessation and Hip Fractures

The association between smoking cessation and the risk of hip fractures was examined in several studies, including three prospective cohort studies with follow-up periods of 5 to 12 years (Forsén et al. 1998; Cornuz et al. 1999; Høidrup et al. 2000) and two case-control studies (La Vecchia et al. 1991; Cumming and Klineberg 1994). In men, successful smoking cessation of at least five years decreased the risk of hip fracture compared with continuing smokers (Høidrup et al. 2000), although other investigations found that this risk remained elevated for men and women smokers compared with lifetime nonsmokers (Cumming and Klineberg 1994; Forsén et al. 1998). Two studies also found no decrease in the risk for hip fractures in women after five years of smoking cessation (La Vecchia et al. 1991; Cornuz et al. 1999), and another found that no benefit from quitting for women, including premenopausal women, was observed until 10 years after cessation (adjusted RR = 0.7 [95 percent confidence interval (CI), 0.5–0.9] compared with current smokers) (Cornuz et al. 1999).

#### Evidence Synthesis

The evidence on smoking and fracture has been reviewed extensively in previous reports of the Surgeon General. The 1990 report considered evidence from eight case-control studies, noting that most showed an association with risk for fracture of the hip or vertebra. Five cohort studies, however, did not show a clear increase in risk and the report found the evidence to be inconclusive. Far more extensive data were available for the 2001 report, including substantially more studies of hip fracture in women. The case-control studies reviewed all indicated excess risk for hip fracture in smokers, with the RR ranging from 1.1 to 2.0. Six reports of cohort studies published subsequent to the 1990 report were also cited, all showing an increased risk for hip fracture in current smokers. The 2001 report (USDHHS 2001) concluded that “women who currently smoke have an increased risk for hip fracture compared with women who do not smoke” (p. 321).

This report extends the review of the 2001 report with additional studies and covers the evidence on men as well. The evidence consistently indicates an increased risk for women and men who smoke. Findings of some studies show a dose-response relationship between risk for hip fracture and the amount smoked. The RR tends to rise with age as would be expected, and the effect of smoking reflects sustained, additional bone loss beyond that associated with aging. The documented effects of smoking on BMD is consistent with the observational evidence on hip fracture.

For fracture sites other than the hip, the evidence has been less consistent. The 2001 Surgeon General’s report found the evidence to be unclear. This report evaluated a number of studies for other sites, also finding the evidence to be mixed and limited in scope for any particular site.

#### Conclusions

1. The evidence is sufficient to infer a causal relationship between smoking and hip fractures.
2. The evidence is inadequate to infer the presence or absence of a causal relationship between smoking and fractures at sites other than the hip.

#### Implications

The RR of hip fractures in smokers increases with age, and hip fracture incidence increases with age, implying that the proportion of hip fractures attributable to smoking increases with age. Smoking is one of the major causes of fracture in older persons that can be prevented. Public health interventions aimed at helping smokers quit are likely to substantially reduce the number of hip fractures. Although hip fractures carry the greatest costs and risks of mortality and morbidity, other fractures also contribute to these outcomes. Further research is necessary to quantify the risks of these other fractures in smokers.

## Dental Diseases

Diseases of the teeth and their supporting structures are a major public health issue with a significant impact on personal well-being. More than $60 billion were spent on oral health care in the United States in 2000, and each year acute oral conditions result in an estimated 1.6 million missed school days and 2.4 million lost workdays. Although there have been tremendous improvements in the oral health of the U.S. public during the past several decades, oral diseases and conditions remain highly prevalent. For example, recent national data indicate that 66 percent of persons aged 12 through 17 years and 94 percent of those aged 18 years and older have experienced dental caries in their permanent teeth (USDHHS 2000).

As the oral cavity is the first part of the human anatomy to be exposed to mainstream smoke in active smokers, researchers have long hypothesized that smoking could have a deleterious effect on the teeth and their supporting structures. However, research on this association was hampered for decades by (1) lack of consensus on case definitions for some diseases; (2) difficulty in measuring oral conditions and consequent use of indices of questionable validity; (3) some incorrect assumptions about disease etiology, pathogenesis, distribution, and natural history; and (4) limited capacity for epidemiologic investigations within the dental research community. As a result, until recently the literature was sparse and findings were not definitive.

### Conclusions of Previous Surgeon General’s Reports

The previous Surgeon General’s reports on smoking and health did not include dental or periodontal effects of smoking, although oral cancer and related premalignant lesions have been addressed. During the past 15 years, however, there has been a substantial amount of research on smoking and oral health, and this topic was addressed in Oral Health in America: A Report of the Surgeon General (USDHHS 2000). This section reviews the epidemiologic evidence for smoking as a causal factor for the most common forms of non-malignant oral disease; cancers of the oral cavity are covered in Chapter 2.

### Periodontitis

The periodontium includes those hard and soft tissue structures that support the teeth: the gingiva, the cementum covering the root surfaces of the teeth, the periodontal ligament that attaches the tooth root surfaces to the adjacent alveolar bone supporting each tooth, and the alveolar bone. The gingiva covers the other periodontal structures and comprises attached and free gingiva. The attached gingiva extends from the bottom of the gingival sulcus to the mucogingival junction, where it is contiguous with the mucous membrane of the lip, cheek, and floor of the mouth. The free gingiva extends from the base of the gingival sulcus to the gingival margin.

In a healthy state, the gingival margin is approximately 0.5 to 2.5 mm coronal to the cemento-enamel junction (CEJ) (where the enamel on the crown of the tooth meets the root). The sulcus is 1 to 3 mm in depth and does not bleed when probed. The base of the sulcus is formed by the junctional epithelium, which joins the gingival connective tissue to the tooth surface. Healthy gingiva is usually pink in color, is well adapted to the teeth, has a stippled surface texture, and is tightly bound to the underlying alveolar bone and the roots of the teeth.

Based on the most recent classification system developed by the American Academy of Periodontology, there are at least eight categories of periodontal diseases and conditions (Armitage 1999). Of those, the two most common are gingivitis and chronic periodontitis. Gingivitis is defined as an inflammation of the gingiva in which the junctional epithelium remains on or near the enamel covering the crown of the tooth. It is characterized clinically by redness, gingival bleeding, edema or enlargement, and occasional gingival sensitivity and tenderness (Genco 1990a). Chronic periodontitis (previously called adult periodontitis) is an inflammation of the gingiva and the adjacent attachment apparatus that is characterized by loss of clinical attachment because of destruction of the periodontal ligament and loss of the adjacent supporting bone (Flemmig 1999). Clinical features of chronic periodontitis may include edema, erythema, gingival bleeding upon probing, periodontal pocketing, or suppuration.

The most common forms of both gingivitis and periodontitis involve bacterial infection. Severe forms of periodontitis often are associated with infection by specific bacteria that colonize the subgingival area (Genco 2000). Destruction of soft tissue and alveolar bone is thought to involve toxins and proteases produced by the bacteria as well as hyperresponsiveness and reactivity of various components of the immune system (e.g., the production of cytokines and prostaglandins). Smoking may play a role in the pathogenesis of periodontal diseases by altering immune function and tissue repair.

The understanding of the distribution and natural history of periodontitis has evolved over the past several decades. Previously, it was thought that virtually all persons were susceptible to severe disease if oral hygiene was inadequate. The disease was considered to progress in a linear fashion throughout life from gingivitis to periodontitis to bone loss to tooth loss, generally attacking the entire dentition and was nearly universal among adults (World Health Organization 1961). This concept was driven, in part, by epidemiologic indices that incorporated signs of both gingivitis and periodontitis, analytic methods that aggregated and averaged measurements within persons and populations, and assumptions about disease progression on the part of the early oral epidemiologists. In the current model of periodontal diseases, a small proportion of persons in most populations are considered to have severe periodontitis; periodontitis is usually preceded by gingivitis but few sites with gingivitis later develop periodontitis; periodontal tissues can undergo some degree of self-repair; and generalized forms of periodontitis are uncommon (American Academy of Periodontology 1996; Burt and Eklund 1999).

Based on current concepts of periodontitis, clinical or epidemiologic assessment of the disease involves detailed measurements of various signs of soft tissue or bone destruction at two to six sites per tooth either on all teeth or on selected teeth. Among the most common measurements is probing pocket depth (PPD), which is measured by inserting a calibrated probe into the gingival sulcus and recording the distance in millimeters from the gingival margin to the base of the gingival sulcus (if healthy) or pocket (if diseased). Because the pathogenesis of periodontitis involves destruction of the junctional epithelium at the base of the sulcus, a PPD greater than 4 mm may indicate disease (Genco 1990b). Another common parameter is the clinical attachment level (CAL), which is measured as distance in millimeters from the CEJ to the base of the gingival sulcus or pocket. It is a direct measure of the position of the periodontal epithelial attachment of a tooth relative to its ideal position at the CEJ. Many cross-sectional studies have used the terminology “loss of periodontal attachment” (LPA) to describe this same parameter, although more recent studies tend to reserve the use of the term LPA for longitudinal assessments of change in the CAL between two points in time. The longitudinal change in CAL is sometimes called relative attachment loss, particularly when computer-linked electronic periodontal probes are used to record the measurements from a fixed reference point such as a cusp tip. Examples of all of these parameters and terms are found in the epidemiologic literature on the association between smoking and periodontal destruction. Because periodontal destruction may occur without deep pocket formation, PPD alone will underestimate disease and may not be sufficient as the prime indicator of disease (Goodson 1990). Intraoral radiographs have been used to assess alveolar bone loss from periodontitis, but this approach can have low sensitivity and may underestimate true bone loss (Goodson 1990; Eickholz and Hausmann 2000; Pepelassi et al. 2000). In addition, radiography often is not logistically feasible or acceptable to examinees during large-scale field epidemiologic studies. At this time, change in the CAL is considered the prime indicator of periodontal destruction.

#### Biologic Basis

##### Microbiology

It is possible that cigarette smoking affects periodontal health by altering the quantity or composition of bacterial dental plaque. Although some studies found that smokers had more visible bacterial plaque than nonsmokers (Sheiham 1971; Bastiaan and Waite 1978; Lavstedt et al. 1982; Preber and Bergström 1985), many other studies reported no significant differences in mean plaque levels or rates of plaque accumulation (Alexander 1970; Swenson 1979; Bergström 1981, 1990; Feldman et al. 1983; Macgregor et al. 1985; Bergström and Eliasson 1987a,b; Lie et al. 1998). Cross-sectional differences in plaque levels between smokers and nonsmokers may be due to differences in oral hygiene practices rather than to smoking per se (Preber and Kant 1973; Andrews et al. 1998). However, the presence of specific bacterial species in periodontal plaque may be more important than the quantity of visible plaque and debris on the teeth in the pathogenesis of severe periodontitis (Genco 1996). Some evidence indicates that smokers may be more likely than nonsmokers to harbor specific periodontal pathogens. A study of adults exhibiting a wide range of periodontal conditions (Zambon et al. 1996) found that subgingival infection with Bacteroides forsythus was more common in current smokers even after adjusting for disease severity, with a dose-response relationship between the amount of smoking and infection. Current smokers were also more likely than former or lifetime nonsmokers to have subgingival infection with Actinobacillus actinomycetemcomitans. Consistent with those findings, a study of dental clinic patients found that plaque samples from smokers were 11 times more likely than samples from nonsmokers to test positive for one of three periodontal pathogens (Kazor et al. 1999). In a study of young adults with early-onset periodontitis (Kamma et al. 1999), 11 postulated periodontal pathogens were detected more frequently and in greater numbers in the subgingival plaque from smokers than from nonsmokers. Smoking may increase the likelihood of infection with periodontal pathogenic microorganisms even among persons with no clinical signs of disease. In a study of young adults who did not have periodontitis (Shiloah et al. 2000), smokers were 18 times more likely than nonsmokers to have at least one of eight periodontal pathogens in their sub-gingival plaque. Several studies, however, reported no differences in the plaque bacteria between smokers and nonsmokers (Preber et al. 1992; Stoltenberg et al. 1993). Additional evidence suggests that smoking may act synergistically to potentiate the effects of toxins produced by periodontal pathogenic bacteria (Sayers et al. 1999).

##### Immune Function

There is substantial evidence that smoking affects both localized and systemic components of the immune system, although the links between these effects and periodontal disease remain to be established. Smoking increases the number but impairs the functions of polymorphonuclear leukocytes (PMNs, or neutrophils), peripheral blood cells that represent the first line of defense against microorganisms (Noble and Penny 1975; Barbour et al. 1997). Either an impairment of the PMN’s ability to neutralize periodontal infections or an overstimulation of potentially tissue-destructive processes can lead to periodontal destruction (American Academy of Periodontology 1999). For example, smoking can impair PMN chemotaxis, phagocytosis, and oxidative burst (Eichel and Shahrik 1969; Kenney et al. 1977; Ryder et al. 1998). Impaired phagocytosis has been implicated in refractory periodontitis (MacFarlane et al. 1992). Smoking also appears to compromise the function of macrophages, which play a vital role in both humoral and cell-mediated immunity, and of B lymphocytes, the major cell type involved in the humoral immune system. Exposure to cigarette smoke also appears to have an immunosuppressive effect on T lymphocytes, which may reduce antibody response to periodontal bacteria (Barbour et al. 1997). Smokers may have a decreased production of antibodies specific to periodontal pathogens, especially IgG2 (Quinn et al. 1998). Recent evidence suggests that levels of cytokines in gingival crevicular fluid, which are secreted by mononuclear cells and are associated with collagen destruction and bone resorption, may be increased in smokers (Boström et al. 1998a,b). Furthermore, there may be a synergistic interaction between smoking and the genotype for a specific cytokine, IL-1, in the development of severe periodontitis (Kornman and di Giovine 1998).

##### Gingival Blood Flow and Soft Tissue Effects

It has long been hypothesized that the peripheral vasoconstrictive effect of tobacco smoke and nicotine reduces gingival blood flow and thereby impairs the delivery of oxygen and nutrients to gingival tissue. There is some evidence of reduced blood flow in gingival tissues (Clarke et al. 1981; Clarke and Shephard 1984) and reduced size and altered morphology of capillaries in oral mucosa and gingival tissues (Johnson et al. 1989) following exposure to tobacco smoke or nicotine. However, more recent evidence appears contradictory (Baab and Öberg 1987; Johnson et al. 1991). Smokers tend to exhibit less gingival bleeding than nonsmokers, even with control for bacterial plaque levels (Preber and Bergström 1985, 1986; Bergström and Preber 1986; Bergström 1990; Danielsen et al. 1990; Newbrun 1996). However, this reduced gingival bleeding may be related more to the suppression of an inflammatory response than to reduced gingival blood flow.

Nicotine can be stored in and released from periodontal fibroblasts, possibly affecting their morphology and ability to attach to root surfaces (Raulin et al. 1988; Hanes et al. 1991; James et al. 1999). In addition, nicotine may inhibit the growth of gingival fibroblasts and their production of collagen and fibronectin, components of the gingival extracellular matrix involved in the structure and attachment of gingiva (Tipton and Dabbous 1995). Thus, it is possible that smoking impairs the ability of periodontal tissues to repair damaged junctional epithelium. Smoking impairs wound healing and compromises the prognosis following surgical and nonsurgical periodontal therapy (Preber and Bergström 1990; Ah et al. 1994; Newman et al. 1994; Rosenberg and Cutler 1994; Preber et al. 1995; Tonetti et al. 1995; Grossi et al. 1996, 1997; Kaldahl et al. 1996; Kinane and Radvar 1997; Trombelli and Scabbia 1997; Boström et al. 1998b; Machtei et al. 1998; Renvert et al. 1998; Palmer et al. 1999; Papantonopoulos 1999; Söder et al. 1999). One study that employed statistical modeling of longitudinal changes in the CAL concluded that diminished capacity for repair, rather than direct tissue damage, probably was the major mechanism involved in smoking-associated periodontal destruction (Faddy et al. 2000).

#### Epidemiologic Evidence

Epidemiologic studies of smoking and periodontitis have employed a variety of case definitions for disease, using various combinations of PPD, CAL or LPA, and alveolar bone loss. Some studies used indices for “periodontal disease” that are no longer considered valid indicators for the prevalence of disease in populations (Burt and Eklund 1999). Other studies employed indices that originally were intended for use in population-based treatment planning and not for etiologic studies, such as the Community Periodontal Index of Treatment Needs (Ainamo et al. 1982). Some studies did not use a case definition for disease, but instead assessed mean levels of one or more clinical parameters among exposed and unexposed groups, or described the proportion of the study population that exceeded various measurement thresholds (e.g., ≥4 mm LPA). Some studies, primarily conducted before the 1970s, provided no case definition other than diagnosis by the examiner. Despite the numerous problems measuring the disease, published epidemiologic and clinical studies consistently show a moderate to strong degree of association between smoking and periodontitis.

To identify epidemiologic studies of smoking and periodontitis, the National Library of Medicine’s PubMed database was searched for English language publications from 1965–2000, using the following Medical Subject Headings (MeSH) key words: “smoking,” “tobacco,” “periodontal diseases,” and “periodontitis.” These terms also were searched as title words. The smoking and health database maintained by the Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, CDC, was also searched using those terms as key words. Reference lists from published studies, review articles, and textbooks were examined to identify additional studies.

Tables 6.21 through 6.23 summarize the findings from 6 case-control studies, 52 cross-sectional studies, and 12 cohort studies conducted between 1959 and 2000. The case-control studies consistently found that persons with periodontitis were more likely than controls without periodontitis to be smokers, although not all studies separated current smokers from former smokers in their analyses. These studies generally controlled for potential confounders in either the selection of a control group or in their analyses. Cross-sectional studies that attempted to estimate parameters such as the odds ratio (OR) consistently reported moderate to strong degrees of association between smoking and periodontitis under a wide range of case definitions (Beck et al. 1990; Horning et al. 1992; Haber et al. 1993; Stoltenberg et al. 1993; Grossi et al. 1994, 1995; Sakki et al. 1995; Tomar et al. 1995; Ahlberg et al. 1996; Dolan et al. 1997a; Norderyd and Hugoson 1998; Shizukuishi et al. 1998; Wakai et al. 1999; Tomar and Asma 2000). Consistent with the findings from case-control and cross-sectional studies, cohort studies reported RR estimates for smoking and onset or progression of periodontitis of 1.4 to more than 10, using a wide range of outcome measures. Of the cross-sectional studies that examined the relationship separately for current smokers and former smokers, current smokers were more likely than former smokers to have periodontitis (Haber et al. 1993; Dolan et al. 1997a; Wakai et al. 1999; Tomar and Asma 2000). Two case-control studies (Haber and Kent 1992; Gelskey et al. 1998) and several cross-sectional studies (Grossi et al. 1994, 1995; Norderyd and Hugoson 1998; Wakai et al. 1999; Tomar and Asma 2000) reported a significant dose-response relationship between the number of cigarettes smoked per day and disease status. Two of these studies used cigarette-years^2^ or pack-years as the measure for exposure (Grossi et al. 1994, 1995), which combined quantity and duration of smoking to characterize the exposure. One study reported a significant dose-response relationship between the duration of smoking and disease risk (Tomar and Asma 2000). That study also found a significant inverse relationship between the number of years since quitting smoking and the odds of having periodontitis.

2 Cigarette-years = The number of years of smoking multiplied by the number of cigarettes smoked per day.

Table 6.21 Case-control studies on the association between smoking and periodontitis

Study | Number of cases/controls | Case definition | Sources of cases/controls | Findings
Study | Number of cases/controls | Case definition | Sources of cases/controls | Smoking status | Odds ratio | 95% confidence interval
Preber and Bergström1986 | 260/1,769 | Moderate to severe periodontitis; advanced periodontitis (mean PPD^*^ >4.5 mm) | Dental school periodontal clinic/population- based sample | Current smokers
Preber and Bergström1986 | 260/1,769 | Moderate to severe periodontitis; advanced periodontitis (mean PPD^*^ >4.5 mm) | Dental school periodontal clinic/population- based sample | Moderate to severe periodontitis | 2.1 | 1.7–2.7
Preber and Bergström1986 | 260/1,769 | Moderate to severe periodontitis; advanced periodontitis (mean PPD^*^ >4.5 mm) | Dental school periodontal clinic/population- based sample | Advanced periodontitis | 2.4 | 1.7–3.5
Bergström and Eliasson 1987b | 134^†^ | PPD ≥4 mm on ≥1 site | Periodontal patients/population- based sample | Current smokers
Bergström and Eliasson 1987b | 134^†^ | PPD ≥4 mm on ≥1 site | Periodontal patients/population- based sample | Men | 2.8^†^ | NR^‡^
Bergström and Eliasson 1987b | 134^†^ | PPD ≥4 mm on ≥1 site | Periodontal patients/population- based sample | Women | 2.1^†^ | NR
Bergström and Eliasson 1987b | 134^†^ | PPD ≥4 mm on ≥1 site | Periodontal patients/population- based sample | Total | 2.5^†^ | NR
Haber and Kent 1992 | 196/209 | Moderate periodontitis(20–50% bone loss on≥1 surface); advanced periodontitis(>50% bone loss on ≥1 surface) | Periodontal offices/general dental practices | Never smoked | 1.0
Haber and Kent 1992 | 196/209 | Moderate periodontitis(20–50% bone loss on≥1 surface); advanced periodontitis(>50% bone loss on ≥1 surface) | Periodontal offices/general dental practices | Ever smoked(moderate or advanced disease) | 2.6 | 1.6–3.9
Haber and Kent 1992 | 196/209 | Moderate periodontitis(20–50% bone loss on≥1 surface); advanced periodontitis(>50% bone loss on ≥1 surface) | Periodontal offices/general dental practices | Current smokers(moderate or advanced disease) | 3.3 | 1.8–5.8
Haber and Kent 1992 | 196/209 | Moderate periodontitis(20–50% bone loss on≥1 surface); advanced periodontitis(>50% bone loss on ≥1 surface) | Periodontal offices/general dental practices | ≤10 cigarettes/day | 1.0 | 0.4–2.5
Haber and Kent 1992 | 196/209 | Moderate periodontitis(20–50% bone loss on≥1 surface); advanced periodontitis(>50% bone loss on ≥1 surface) | Periodontal offices/general dental practices | >10 cigarettes/day | 5.4 | 2.8–10.6
Haber and Kent 1992 | 196/209 | Moderate periodontitis(20–50% bone loss on≥1 surface); advanced periodontitis(>50% bone loss on ≥1 surface) | Periodontal offices/general dental practices | ≤10 years’ duration | 1.0 | 0.2–6.5
Haber and Kent 1992 | 196/209 | Moderate periodontitis(20–50% bone loss on≥1 surface); advanced periodontitis(>50% bone loss on ≥1 surface) | Periodontal offices/general dental practices | >10 years’ duration | 4.3 | 1.6–12.1
Haber and Kent 1992 | 196/209 | Moderate periodontitis(20–50% bone loss on≥1 surface); advanced periodontitis(>50% bone loss on ≥1 surface) | Periodontal offices/general dental practices | Moderate disease | 1.8 | 0.9–3.7
Haber and Kent 1992 | 196/209 | Moderate periodontitis(20–50% bone loss on≥1 surface); advanced periodontitis(>50% bone loss on ≥1 surface) | Periodontal offices/general dental practices | Advanced disease | 6.1 | 2.9–12.8
MacFarlane et al. 1992 | 31/12 | Refractory periodontitis: persistent failure of conventional treatment including root planing, surgery, and antibiotics | Private periodontal practices and dental school graduate periodontal clinics/laboratory personnel | Current smokers(odds ratio estimate calculated from reported raw data by adding 0.5 to each cell; 0 smokers in the control group) | 203.6 | 9.8–4, 242.4
Gelskey et al. 1998 | 205/205 | ≥1 tooth with alveolar bone loss >3 mm, or≥1 tooth with PPD^*^ ≥7 mm | Dental school Clinic | Never smoked | 1.0 | NR
Gelskey et al. 1998 | 205/205 | ≥1 tooth with alveolar bone loss >3 mm, or≥1 tooth with PPD^*^ ≥7 mm | Dental school Clinic | Ever smoked | 1.8 | 1.1–2.9
Gelskey et al. 1998 | 205/205 | ≥1 tooth with alveolar bone loss >3 mm, or≥1 tooth with PPD^*^ ≥7 mm | Dental school Clinic | Cigarette-years^§^
Gelskey et al. 1998 | 205/205 | ≥1 tooth with alveolar bone loss >3 mm, or≥1 tooth with PPD^*^ ≥7 mm | Dental school Clinic | Aged 35–87 years
Gelskey et al. 1998 | 205/205 | ≥1 tooth with alveolar bone loss >3 mm, or≥1 tooth with PPD^*^ ≥7 mm | Dental school Clinic | 1–300 | 1.2 | 0.7–1.8
Gelskey et al. 1998 | 205/205 | ≥1 tooth with alveolar bone loss >3 mm, or≥1 tooth with PPD^*^ ≥7 mm | Dental school Clinic | 301–500 | 1.8 | 0.9–2.7
Gelskey et al. 1998 | 205/205 | ≥1 tooth with alveolar bone loss >3 mm, or≥1 tooth with PPD^*^ ≥7 mm | Dental school Clinic | >500 | 3.8 | 2.9–4.7
Gelskey et al. 1998 | 205/205 | ≥1 tooth with alveolar bone loss >3 mm, or≥1 tooth with PPD^*^ ≥7 mm | Dental school Clinic | Aged 35–54 years
Gelskey et al. 1998 | 205/205 | ≥1 tooth with alveolar bone loss >3 mm, or≥1 tooth with PPD^*^ ≥7 mm | Dental school Clinic | 1–300 | 1.0 | 0.3–1.7
Gelskey et al. 1998 | 205/205 | ≥1 tooth with alveolar bone loss >3 mm, or≥1 tooth with PPD^*^ ≥7 mm | Dental school Clinic | 301–500 | 3.2 | 2.1–4.2
Gelskey et al. 1998 | 205/205 | ≥1 tooth with alveolar bone loss >3 mm, or≥1 tooth with PPD^*^ ≥7 mm | Dental school Clinic | >500 | 4.3 | 6.2–8.5
Gelskey et al. 1998 | 205/205 | ≥1 tooth with alveolar bone loss >3 mm, or≥1 tooth with PPD^*^ ≥7 mm | Dental school Clinic | Aged 55–87 years
Gelskey et al. 1998 | 205/205 | ≥1 tooth with alveolar bone loss >3 mm, or≥1 tooth with PPD^*^ ≥7 mm | Dental school Clinic | 1–300 | 1.7 | 0.7–3.9
Gelskey et al. 1998 | 205/205 | ≥1 tooth with alveolar bone loss >3 mm, or≥1 tooth with PPD^*^ ≥7 mm | Dental school Clinic | 301–500 | 1.1 | 0.01–4.0
Gelskey et al. 1998 | 205/205 | ≥1 tooth with alveolar bone loss >3 mm, or≥1 tooth with PPD^*^ ≥7 mm | Dental school Clinic | >500 | 2.2 | 0.01–7.6
Quinn et al. 1998 | 270/193 | ≥2 mm loss of periodontal attachment on ≥1 tooth | Clinical Research Center for Periodontal Diseases, Virginia | Blacks
Quinn et al. 1998 | 270/193 | ≥2 mm loss of periodontal attachment on ≥1 tooth | Clinical Research Center for Periodontal Diseases, Virginia | Former smokers | 1.0Δ | NR
Quinn et al. 1998 | 270/193 | ≥2 mm loss of periodontal attachment on ≥1 tooth | Clinical Research Center for Periodontal Diseases, Virginia | Current smokers | 2.1Δ | 0.9–5.1
Quinn et al. 1998 | 270/193 | ≥2 mm loss of periodontal attachment on ≥1 tooth | Clinical Research Center for Periodontal Diseases, Virginia | Whites
Quinn et al. 1998 | 270/193 | ≥2 mm loss of periodontal attachment on ≥1 tooth | Clinical Research Center for Periodontal Diseases, Virginia | Former smokers | 1.0Δ | NR
Quinn et al. 1998 | 270/193 | ≥2 mm loss of periodontal attachment on ≥1 tooth | Clinical Research Center for Periodontal Diseases, Virginia | Current smokers | 4.0Δ | 2.1–7.6

* PPD = Probing pocket depth.

† Odds ratio estimates in this study were based on comparisons with smoking prevalence in a general population survey in Stockholm, Sweden. However, periodontal health was not examined in this “control” group.

‡ NR = Data were not reported.

§ Cigarette-years = Number of years of smoking multiplied by the number of cigarettes smoked per day.

Δ Crude odds ratio estimates were calculated from data reported in the paper.

Table 6.22 Cross-sectional studies on the association between smoking and periodontitis

Study | Population | Findings | | Comments
Arno et al. 1959 | 728 male factory workers and staff Aged 21–45 years Norway | No quantitative results were reported | | Mean alveolar bone loss appeared to increase with more cigarettes/day in graphic plots of deviations from the sample mean; the analysis of variance verified with a significant degree of certainty that the difference could not be due to chance (mean and test scores were not reported)
Brandtzaeg and Jamison 1964 | 206 male army recruits Aged 19–25 years Norway | Mean Periodontal Index score | | An association between smoking and the Periodontal Index score was not statistically significant in the analysis of covariance
Brandtzaeg and Jamison 1964 | 206 male army recruits Aged 19–25 years Norway | Nonsmokers | 0.71 | An association between smoking and the Periodontal Index score was not statistically significant in the analysis of covariance
Brandtzaeg and Jamison 1964 | 206 male army recruits Aged 19–25 years Norway | <10 cigarettes/day | 0.79 | An association between smoking and the Periodontal Index score was not statistically significant in the analysis of covariance
Brandtzaeg and Jamison 1964 | 206 male army recruits Aged 19–25 years Norway | ≥10 cigarettes/day | 1.05 | An association between smoking and the Periodontal Index score was not statistically significant in the analysis of covariance
Brandtzaeg and Jamison 1964 | 206 male army recruits Aged 19–25 years Norway | Mean Oral Hygiene Index score | | An association between smoking and the Periodontal Index score was not statistically significant in the analysis of covariance
Brandtzaeg and Jamison 1964 | 206 male army recruits Aged 19–25 years Norway | Nonsmokers | 1.22 | An association between smoking and the Periodontal Index score was not statistically significant in the analysis of covariance
Brandtzaeg and Jamison 1964 | 206 male army recruits Aged 19–25 years Norway | <10 cigarettes/day | 1.45 | An association between smoking and the Periodontal Index score was not statistically significant in the analysis of covariance
Brandtzaeg and Jamison 1964 | 206 male army recruits Aged 19–25 years Norway | ≥10 cigarettes/day | 1.59 | An association between smoking and the Periodontal Index score was not statistically significant in the analysis of covariance
Solomon et al. 1968 | 2,182 male and 5,009 female dental clinic and hospital patients Aged 20–79 years United States (New York) | Prevalence of periodontal disease was consistently higher among ever smokers than among never smokers for both men and women (e.g., aged 40 years: white men, 75 vs. 50%; white women, 65 vs. 50%) | | Periodontal disease included both gingivitis and periodontal disease with or without pocket formation; smoking was strongly associated with periodontal disease in the age- stratified Cochran’s test for both men and women
Summers and Oberman 1968 | Probability sample of 154 men and 170 women Aged ≥20 years (mean or range not reported) | Multiple correlation coefficients for cigarette use and the Periodontal Disease Index score by gender | | The Periodontal Disease Index was used to measure periodontal disease; cigarette smoking was measured in packs per day; it is unclear if former smokers were included in this multiple correlation analysis
Summers and Oberman 1968 | Probability sample of 154 men and 170 women Aged ≥20 years (mean or range not reported) | Men | 0.591
Summers and Oberman 1968 | Probability sample of 154 men and 170 women Aged ≥20 years (mean or range not reported) | Women | 0.551
Ainamo 1971 | 167 male military recruits Aged 18–26 years Finland | Mean LPA^*^ by daily smoking habit | | LPA was measured clinically on 4 surfaces of all erupted teeth
Ainamo 1971 | 167 male military recruits Aged 18–26 years Finland | Cigarettes/day | LPA | LPA was measured clinically on 4 surfaces of all erupted teeth
Ainamo 1971 | 167 male military recruits Aged 18–26 years Finland | 0 | 0.049 | LPA was measured clinically on 4 surfaces of all erupted teeth
Ainamo 1971 | 167 male military recruits Aged 18–26 years Finland | 1–9 | 0.069 | LPA was measured clinically on 4 surfaces of all erupted teeth
Ainamo 1971 | 167 male military recruits Aged 18–26 years Finland | 10–20 | 0.072 | LPA was measured clinically on 4 surfaces of all erupted teeth
Ainamo 1971 | 167 male military recruits Aged 18–26 years Finland | >20 | 0.108 | LPA was measured clinically on 4 surfaces of all erupted teeth
Preber et al. 1980 | 134 male army conscripts Aged 19–27 years Sweden | There were no significant differences between smokers (n = 81) and nonsmokers (n = 53) in mean bone level or PPD^†^ | | PPD was clinically assessed on 6 teeth (1st molars, upper right central incisor, lower left central incisor); radiographic assessments were of lower incisors only
Bergström and Floderus-Myrhed 1983 | 164 twin pairs, selected from twin registry, discordant on smoking Aged 39–78 years Sweden | Mean alveolar bone index | | Alveolar bone index was based on a 5-category ordinal scale of radiographic bone loss, with no information on quantity or duration of smoking; the low-exposed group included both nonsmokers and twins with a lifetime exposure to smoking considered to be less than the twin
Bergström and Floderus-Myrhed 1983 | 164 twin pairs, selected from twin registry, discordant on smoking Aged 39–78 years Sweden | High-exposed twins | 1.09
Bergström and Floderus-Myrhed 1983 | 164 twin pairs, selected from twin registry, discordant on smoking Aged 39–78 years Sweden | Low-exposed twins | 0.94
Bergström and Floderus-Myrhed 1983 | 164 twin pairs, selected from twin registry, discordant on smoking Aged 39–78 years Sweden | Number of teeth lost
Bergström and Floderus-Myrhed 1983 | 164 twin pairs, selected from twin registry, discordant on smoking Aged 39–78 years Sweden | High-exposed twins | 11.3
Bergström and Floderus-Myrhed 1983 | 164 twin pairs, selected from twin registry, discordant on smoking Aged 39–78 years Sweden | Low-exposed twins | 9.6
Feldman et al. 1983 | 862 men Mean age of nonsmokers = 47.9 years; mean age of smokers = 43.8 years United States | Mean PPD (mm) | | Adjusted for age in the analysis of variance; the nonsmoking group included former smokers
Feldman et al. 1983 | 862 men Mean age of nonsmokers = 47.9 years; mean age of smokers = 43.8 years United States | Smokers | 0.73 | Adjusted for age in the analysis of variance; the nonsmoking group included former smokers
Feldman et al. 1983 | 862 men Mean age of nonsmokers = 47.9 years; mean age of smokers = 43.8 years United States | Nonsmokers | 0.56 | Adjusted for age in the analysis of variance; the nonsmoking group included former smokers
Feldman et al. 1983 | 862 men Mean age of nonsmokers = 47.9 years; mean age of smokers = 43.8 years United States | Mean bone loss | | Adjusted for age in the analysis of variance; the nonsmoking group included former smokers
Feldman et al. 1983 | 862 men Mean age of nonsmokers = 47.9 years; mean age of smokers = 43.8 years United States | Smokers | 0.70 | Adjusted for age in the analysis of variance; the nonsmoking group included former smokers
Feldman et al. 1983 | 862 men Mean age of nonsmokers = 47.9 years; mean age of smokers = 43.8 years United States | Nonsmokers | 0.42 | Adjusted for age in the analysis of variance; the nonsmoking group included former smokers
Ismail et al. 1983 | Population-based sample of 2,948 persons Aged 25–74 years United States | Mean Periodontal Index score by smoking status | | An association between Periodontal Index scores and current smoking remained significant after adjusting for the Oral Hygiene Index score, race, gender, education, poverty index, frequency of tooth-brushing, age, and income in a multiple linear regression model
Ismail et al. 1983 | Population-based sample of 2,948 persons Aged 25–74 years United States | Current smokers | 1.6
Ismail et al. 1983 | Population-based sample of 2,948 persons Aged 25–74 years United States | Former smokers | 1.1
Ismail et al. 1983 | Population-based sample of 2,948 persons Aged 25–74 years United States | Never smoked | 1.0
Markkanen et al. 1985 | Population-based sample of 2,019 men and 2,349 women Aged ≥30 years Finland | Prevalence (%) of PPD^†^ 4–6 mm | | Nonsmokers included former smokers; periodontal status was measured by the Periodontal Treatment Need System (PTNS), classifying each quadrant of the mouth by the highest score within that quadrant and each person according to the highest quadrant score; there were no significant differences between smokers and nonsmokers in periodontal pocketing when stratified by gender; smoking was not a significant correlate of the PTNS score in a log-linear model that also included gender, age, and the number of dentate quadrants
Markkanen et al. 1985 | Population-based sample of 2,019 men and 2,349 women Aged ≥30 years Finland | Men
Markkanen et al. 1985 | Population-based sample of 2,019 men and 2,349 women Aged ≥30 years Finland | Current smokers | 51.6
Markkanen et al. 1985 | Population-based sample of 2,019 men and 2,349 women Aged ≥30 years Finland | Nonsmokers | 51.7
Markkanen et al. 1985 | Population-based sample of 2,019 men and 2,349 women Aged ≥30 years Finland | Women
Markkanen et al. 1985 | Population-based sample of 2,019 men and 2,349 women Aged ≥30 years Finland | Current smokers | 50.8
Markkanen et al. 1985 | Population-based sample of 2,019 men and 2,349 women Aged ≥30 years Finland | Nonsmokers | 50.8
Markkanen et al. 1985 | Population-based sample of 2,019 men and 2,349 women Aged ≥30 years Finland | Total
Markkanen et al. 1985 | Population-based sample of 2,019 men and 2,349 women Aged ≥30 years Finland | Current smokers | 51.3
Markkanen et al. 1985 | Population-based sample of 2,019 men and 2,349 women Aged ≥30 years Finland | Nonsmokers | 51.2
Markkanen et al. 1985 | Population-based sample of 2,019 men and 2,349 women Aged ≥30 years Finland | Prevalence of PPD >6 mm
Markkanen et al. 1985 | Population-based sample of 2,019 men and 2,349 women Aged ≥30 years Finland | Men
Markkanen et al. 1985 | Population-based sample of 2,019 men and 2,349 women Aged ≥30 years Finland | Current smokers | 33.1
Markkanen et al. 1985 | Population-based sample of 2,019 men and 2,349 women Aged ≥30 years Finland | Nonsmokers | 30.6
Markkanen et al. 1985 | Population-based sample of 2,019 men and 2,349 women Aged ≥30 years Finland | Women
Markkanen et al. 1985 | Population-based sample of 2,019 men and 2,349 women Aged ≥30 years Finland | Current smokers | 20.5
Markkanen et al. 1985 | Population-based sample of 2,019 men and 2,349 women Aged ≥30 years Finland | Nonsmokers | 19.3
Markkanen et al. 1985 | Population-based sample of 2,019 men and 2,349 women Aged ≥30 years Finland | Total
Markkanen et al. 1985 | Population-based sample of 2,019 men and 2,349 women Aged ≥30 years Finland | Current smokers | 29.6
Markkanen et al. 1985 | Population-based sample of 2,019 men and 2,349 women Aged ≥30 years Finland | Nonsmokers | 24.2
Bergström and Eliasson 1987a | 203 male and 32 female professional musicians Aged 21–60 years Sweden | Alveolar bone height (% of root length) | | Radiographically determined alveolar bone height was significantly lower in smokers than in nonsmokers across age groups and plaque index scores; there were no significant differences in plaque levels between smokers and non-smokers; former smokers were excluded from the analysis
Bergström and Eliasson 1987a | 203 male and 32 female professional musicians Aged 21–60 years Sweden | Aged 21–40 years
Bergström and Eliasson 1987a | 203 male and 32 female professional musicians Aged 21–60 years Sweden | Smokers | 84.4
Bergström and Eliasson 1987a | 203 male and 32 female professional musicians Aged 21–60 years Sweden | Nonsmokers | 86.3
Bergström and Eliasson 1987a | 203 male and 32 female professional musicians Aged 21–60 years Sweden | Aged 41–50 years
Bergström and Eliasson 1987a | 203 male and 32 female professional musicians Aged 21–60 years Sweden | Smokers | 79.2
Bergström and Eliasson 1987a | 203 male and 32 female professional musicians Aged 21–60 years Sweden | Nonsmokers | 83.1
Bergström and Eliasson 1987a | 203 male and 32 female professional musicians Aged 21–60 years Sweden | Aged 51–60 years
Bergström and Eliasson 1987a | 203 male and 32 female professional musicians Aged 21–60 years Sweden | Smokers | 68.0
Bergström and Eliasson 1987a | 203 male and 32 female professional musicians Aged 21–60 years Sweden | Nonsmokers | 76.1
Bergström and Eliasson 1987a | 203 male and 32 female professional musicians Aged 21–60 years Sweden | Total
Bergström and Eliasson 1987a | 203 male and 32 female professional musicians Aged 21–60 years Sweden | Smokers | 77.9
Bergström and Eliasson 1987a | 203 male and 32 female professional musicians Aged 21–60 years Sweden | Nonsmokers | 82.3
Bergström and Eliasson 1987b | 208 male and 34 female professional musicians Aged 21–60 years Sweden | Mean number of periodontal pockets ≥4 mm | | The mean number of periodontal pockets was significantly greater in smokers than in nonsmokers across age groups and plaque index scores
Bergström and Eliasson 1987b | 208 male and 34 female professional musicians Aged 21–60 years Sweden | Aged 21–40 years | | The mean number of periodontal pockets was significantly greater in smokers than in nonsmokers across age groups and plaque index scores
Bergström and Eliasson 1987b | 208 male and 34 female professional musicians Aged 21–60 years Sweden | Smokers | 27.3 | The mean number of periodontal pockets was significantly greater in smokers than in nonsmokers across age groups and plaque index scores
Bergström and Eliasson 1987b | 208 male and 34 female professional musicians Aged 21–60 years Sweden | Nonsmokers | 13.4 | The mean number of periodontal pockets was significantly greater in smokers than in nonsmokers across age groups and plaque index scores
Bergström and Eliasson 1987b | 208 male and 34 female professional musicians Aged 21–60 years Sweden | Aged 41–60 years | | The mean number of periodontal pockets was significantly greater in smokers than in nonsmokers across age groups and plaque index scores
Bergström and Eliasson 1987b | 208 male and 34 female professional musicians Aged 21–60 years Sweden | Smokers | 39.9 | The mean number of periodontal pockets was significantly greater in smokers than in nonsmokers across age groups and plaque index scores
Bergström and Eliasson 1987b | 208 male and 34 female professional musicians Aged 21–60 years Sweden | Nonsmokers | 31.0 | The mean number of periodontal pockets was significantly greater in smokers than in nonsmokers across age groups and plaque index scores
Bergström and Eliasson 1987b | 208 male and 34 female professional musicians Aged 21–60 years Sweden | Total | | The mean number of periodontal pockets was significantly greater in smokers than in nonsmokers across age groups and plaque index scores
Bergström and Eliasson 1987b | 208 male and 34 female professional musicians Aged 21–60 years Sweden | Smokers | 36.0 | The mean number of periodontal pockets was significantly greater in smokers than in nonsmokers across age groups and plaque index scores
Bergström and Eliasson 1987b | 208 male and 34 female professional musicians Aged 21–60 years Sweden | Nonsmokers | 21.8 | The mean number of periodontal pockets was significantly greater in smokers than in nonsmokers across age groups and plaque index scores
Levy et al. 1987 | Population-based sample of 477 dentate adults Aged ≥65 years United States (Iowa) | Multiple linear regression coefficient for proportion of teeth that were periodontally healthy by the number of cigarettes smoked | | Periodontally healthy teeth were defined as PPD^†^ ≤3 mm with no gingival bleeding; other variables in the models for males were the number of teeth, age, Parkinson’s disease, ever smoked a pipe, exercise level, and proportion of teeth with calculus and with recession; for females: the number of teeth; age; and proportion of teeth with coronal decay, calculus, and recession
Levy et al. 1987 | Population-based sample of 477 dentate adults Aged ≥65 years United States (Iowa) | Males | −0.203
Levy et al. 1987 | Population-based sample of 477 dentate adults Aged ≥65 years United States (Iowa) | Females | −0.088 (not statistically significant)
Beck et al. 1990 | Population-based sample of 381 blacks and 308 whites Aged ≥65 years United States (North Carolina) | OR^‡^ estimates (95% CI^§^) for tobacco use and severe LPA | | Severe LPA^*^ was defined as ≥4 periodontal sites with LPA ≥5 mm, and ≥1 of those sites with PPD ≥4 mm; it is unclear if tobacco use included forms other than cigarettes; the prevalence of smoking or other forms of tobacco use was not provided; logistic models for whites included tobacco use, education, dentate status of sibling, most recent dental visit, periodontal plaque bacteria levels, the presence of dental caries, a perceived worsening of finances, and a perceived bother by things in life; for blacks, models included tobacco use, education, reported bleeding gums, most recent dental visit, bacteria levels, socioeconomic status, morning cough, and perceived financial status
Beck et al. 1990 | Population-based sample of 381 blacks and 308 whites Aged ≥65 years United States (North Carolina) | Whites
Beck et al. 1990 | Population-based sample of 381 blacks and 308 whites Aged ≥65 years United States (North Carolina) | Unadjusted | 6.7 (3.2–14.0)
Beck et al. 1990 | Population-based sample of 381 blacks and 308 whites Aged ≥65 years United States (North Carolina) | Adjusted | 6.2 (2.6–14.5)
Beck et al. 1990 | Population-based sample of 381 blacks and 308 whites Aged ≥65 years United States (North Carolina) | Blacks
Beck et al. 1990 | Population-based sample of 381 blacks and 308 whites Aged ≥65 years United States (North Carolina) | Unadjusted | 2.8 (1.7–4.7)
Beck et al. 1990 | Population-based sample of 381 blacks and 308 whites Aged ≥65 years United States (North Carolina) | Adjusted | 2.9 (1.6–5.1)
Goultschin et al. 1990 | 154 male and 190 female hospital workers Aged 17–74 years Israel | Mean number of sextants affected, based on CPITNΔ scores | | The mean number of affected sextants did not differ significantly between smokers and nonsmokers for CPITN scores 2 and 4; adjusted for age and gender
Goultschin et al. 1990 | 154 male and 190 female hospital workers Aged 17–74 years Israel | 0 | | The mean number of affected sextants did not differ significantly between smokers and nonsmokers for CPITN scores 2 and 4; adjusted for age and gender
Goultschin et al. 1990 | 154 male and 190 female hospital workers Aged 17–74 years Israel | Smokers | 0.32 | The mean number of affected sextants did not differ significantly between smokers and nonsmokers for CPITN scores 2 and 4; adjusted for age and gender
Goultschin et al. 1990 | 154 male and 190 female hospital workers Aged 17–74 years Israel | Nonsmokers | 0.84 | The mean number of affected sextants did not differ significantly between smokers and nonsmokers for CPITN scores 2 and 4; adjusted for age and gender
Goultschin et al. 1990 | 154 male and 190 female hospital workers Aged 17–74 years Israel | 1 | | The mean number of affected sextants did not differ significantly between smokers and nonsmokers for CPITN scores 2 and 4; adjusted for age and gender
Goultschin et al. 1990 | 154 male and 190 female hospital workers Aged 17–74 years Israel | Smokers | 0.55 | The mean number of affected sextants did not differ significantly between smokers and nonsmokers for CPITN scores 2 and 4; adjusted for age and gender
Goultschin et al. 1990 | 154 male and 190 female hospital workers Aged 17–74 years Israel | Nonsmokers | 1.01 | The mean number of affected sextants did not differ significantly between smokers and nonsmokers for CPITN scores 2 and 4; adjusted for age and gender
Goultschin et al. 1990 | 154 male and 190 female hospital workers Aged 17–74 years Israel | 2 | | The mean number of affected sextants did not differ significantly between smokers and nonsmokers for CPITN scores 2 and 4; adjusted for age and gender
Goultschin et al. 1990 | 154 male and 190 female hospital workers Aged 17–74 years Israel | Smokers | 1.52 | The mean number of affected sextants did not differ significantly between smokers and nonsmokers for CPITN scores 2 and 4; adjusted for age and gender
Goultschin et al. 1990 | 154 male and 190 female hospital workers Aged 17–74 years Israel | Nonsmokers | 1.32 | The mean number of affected sextants did not differ significantly between smokers and nonsmokers for CPITN scores 2 and 4; adjusted for age and gender
Goultschin et al. 1990 | 154 male and 190 female hospital workers Aged 17–74 years Israel | 3 | | The mean number of affected sextants did not differ significantly between smokers and nonsmokers for CPITN scores 2 and 4; adjusted for age and gender
Goultschin et al. 1990 | 154 male and 190 female hospital workers Aged 17–74 years Israel | Smokers | 2.46 | The mean number of affected sextants did not differ significantly between smokers and nonsmokers for CPITN scores 2 and 4; adjusted for age and gender
Goultschin et al. 1990 | 154 male and 190 female hospital workers Aged 17–74 years Israel | Nonsmokers | 1.71 | The mean number of affected sextants did not differ significantly between smokers and nonsmokers for CPITN scores 2 and 4; adjusted for age and gender
Goultschin et al. 1990 | 154 male and 190 female hospital workers Aged 17–74 years Israel | 4 | | The mean number of affected sextants did not differ significantly between smokers and nonsmokers for CPITN scores 2 and 4; adjusted for age and gender
Goultschin et al. 1990 | 154 male and 190 female hospital workers Aged 17–74 years Israel | Smokers | 0.47 | The mean number of affected sextants did not differ significantly between smokers and nonsmokers for CPITN scores 2 and 4; adjusted for age and gender
Goultschin et al. 1990 | 154 male and 190 female hospital workers Aged 17–74 years Israel | Nonsmokers | 0.61 | The mean number of affected sextants did not differ significantly between smokers and nonsmokers for CPITN scores 2 and 4; adjusted for age and gender
Hansen et al. 1990a | Population-based sample of 156 persons Aged 35 years Norway | Mean number of quadrants with ≥1 site with PPD^†^ ≥5 mm | | No significant difference in the mean number of quadrants affected
Hansen et al. 1990a | Population-based sample of 156 persons Aged 35 years Norway | Smokers | 0.397 | No significant difference in the mean number of quadrants affected
Hansen et al. 1990a | Population-based sample of 156 persons Aged 35 years Norway | Nonsmokers | 0.395 | No significant difference in the mean number of quadrants affected
Bergström et al. 1991 | 210 female dental hygienists Aged 24–60 years Sweden | Mean alveolar bone loss (mm) | | Bone loss was assessed radiographically for interdental septum of right posterior teeth; associations between bone loss and cigarette habits were consistent within age strata; smoking was a significant predictor of bone loss in multiple linear regression models that included age
Bergström et al. 1991 | 210 female dental hygienists Aged 24–60 years Sweden | Current smokers | 1.71
Bergström et al. 1991 | 210 female dental hygienists Aged 24–60 years Sweden | Former smokers | 1.55
Bergström et al. 1991 | 210 female dental hygienists Aged 24–60 years Sweden | Never smoked | 1.45
Bergström et al. 1991 | 210 female dental hygienists Aged 24–60 years Sweden | Mean alveolar bone loss (mm) in current smokers by cigarettes/day
Bergström et al. 1991 | 210 female dental hygienists Aged 24–60 years Sweden | ≤10 | 1.60
Bergström et al. 1991 | 210 female dental hygienists Aged 24–60 years Sweden | >10 | 2.06
Bergström et al. 1991 | 210 female dental hygienists Aged 24–60 years Sweden | Mean alveolar bone loss (mm) in current smokers by duration of smoking (years)
Bergström et al. 1991 | 210 female dental hygienists Aged 24–60 years Sweden | ≤15 | 1.39
Bergström et al. 1991 | 210 female dental hygienists Aged 24–60 years Sweden | >15 | 1.89
Horning et al. 1992 | 1,520 male and 263 female dental patients United States | OR (95% CI) for moderate or advanced periodontitis | | This logistic regression model included age, ethnicity, gender, and smoking status; it is unclear if former smokers were included in the analysis
Horning et al. 1992 | 1,520 male and 263 female dental patients United States | Smokers | 1.8 (1.2–2.7) | This logistic regression model included age, ethnicity, gender, and smoking status; it is unclear if former smokers were included in the analysis
Locker 1992; Locker and Leake 1993 | Population-based sample of 702 dentate adults Aged ≥50 years Canada (Ontario) | Mean LPA^*^ (mm) | | Severe LPA was defined as the upper 20th percentile of distribution of LPA in the full study population (≥3.8 mm)
Locker 1992; Locker and Leake 1993 | Population-based sample of 702 dentate adults Aged ≥50 years Canada (Ontario) | Current smokers | 3.7 | Severe LPA was defined as the upper 20th percentile of distribution of LPA in the full study population (≥3.8 mm)
Locker 1992; Locker and Leake 1993 | Population-based sample of 702 dentate adults Aged ≥50 years Canada (Ontario) | Former smokers | 2.9 | Severe LPA was defined as the upper 20th percentile of distribution of LPA in the full study population (≥3.8 mm)
Locker 1992; Locker and Leake 1993 | Population-based sample of 702 dentate adults Aged ≥50 years Canada (Ontario) | Never smoked | 2.7 | Severe LPA was defined as the upper 20th percentile of distribution of LPA in the full study population (≥3.8 mm)
Locker 1992; Locker and Leake 1993 | Population-based sample of 702 dentate adults Aged ≥50 years Canada (Ontario) | Sites (%) with LPA ≥2 mm | | Severe LPA was defined as the upper 20th percentile of distribution of LPA in the full study population (≥3.8 mm)
Locker 1992; Locker and Leake 1993 | Population-based sample of 702 dentate adults Aged ≥50 years Canada (Ontario) | Current smokers | 84.7 | Severe LPA was defined as the upper 20th percentile of distribution of LPA in the full study population (≥3.8 mm)
Locker 1992; Locker and Leake 1993 | Population-based sample of 702 dentate adults Aged ≥50 years Canada (Ontario) | Former smokers | 77.6 | Severe LPA was defined as the upper 20th percentile of distribution of LPA in the full study population (≥3.8 mm)
Locker 1992; Locker and Leake 1993 | Population-based sample of 702 dentate adults Aged ≥50 years Canada (Ontario) | Never smoked | 72.3 | Severe LPA was defined as the upper 20th percentile of distribution of LPA in the full study population (≥3.8 mm)
Locker 1992; Locker and Leake 1993 | Population-based sample of 702 dentate adults Aged ≥50 years Canada (Ontario) | Sites (%) with LPA ≥5 mm | | Severe LPA was defined as the upper 20th percentile of distribution of LPA in the full study population (≥3.8 mm)
Locker 1992; Locker and Leake 1993 | Population-based sample of 702 dentate adults Aged ≥50 years Canada (Ontario) | Current smokers | 30.2 | Severe LPA was defined as the upper 20th percentile of distribution of LPA in the full study population (≥3.8 mm)
Locker 1992; Locker and Leake 1993 | Population-based sample of 702 dentate adults Aged ≥50 years Canada (Ontario) | Former smokers | 15.9 | Severe LPA was defined as the upper 20th percentile of distribution of LPA in the full study population (≥3.8 mm)
Locker 1992; Locker and Leake 1993 | Population-based sample of 702 dentate adults Aged ≥50 years Canada (Ontario) | Never smoked | 13.8 | Severe LPA was defined as the upper 20th percentile of distribution of LPA in the full study population (≥3.8 mm)
Locker 1992; Locker and Leake 1993 | Population-based sample of 702 dentate adults Aged ≥50 years Canada (Ontario) | Prevalence of severe LPA | | Severe LPA was defined as the upper 20th percentile of distribution of LPA in the full study population (≥3.8 mm)
Locker 1992; Locker and Leake 1993 | Population-based sample of 702 dentate adults Aged ≥50 years Canada (Ontario) | Current smokers | 34.4 | Severe LPA was defined as the upper 20th percentile of distribution of LPA in the full study population (≥3.8 mm)
Locker 1992; Locker and Leake 1993 | Population-based sample of 702 dentate adults Aged ≥50 years Canada (Ontario) | Former smokers | 20.4 | Severe LPA was defined as the upper 20th percentile of distribution of LPA in the full study population (≥3.8 mm)
Locker 1992; Locker and Leake 1993 | Population-based sample of 702 dentate adults Aged ≥50 years Canada (Ontario) | Never smoked | 13.1 | Severe LPA was defined as the upper 20th percentile of distribution of LPA in the full study population (≥3.8 mm)
Haber et al. 1993 | 132 patients with insulin-dependent diabetes mellitus from diabetes clinics; 95 HMO^¶^ patients | OR (95% CI) of periodontitis by diabetes and smoking status | | Case definition of periodontitis: ≥1 site with PPD^†^ ≥5 mm and LPA ≥2 mm; Mantel-Haenszel summary OR estimates were adjusted for age
Haber et al. 1993 | 132 patients with insulin-dependent diabetes mellitus from diabetes clinics; 95 HMO^¶^ patients | No diabetes | | Case definition of periodontitis: ≥1 site with PPD^†^ ≥5 mm and LPA ≥2 mm; Mantel-Haenszel summary OR estimates were adjusted for age
Haber et al. 1993 | 132 patients with insulin-dependent diabetes mellitus from diabetes clinics; 95 HMO^¶^ patients | Current smokers | 8.6 (2.7–27.8) | Case definition of periodontitis: ≥1 site with PPD^†^ ≥5 mm and LPA ≥2 mm; Mantel-Haenszel summary OR estimates were adjusted for age
Haber et al. 1993 | 132 patients with insulin-dependent diabetes mellitus from diabetes clinics; 95 HMO^¶^ patients | Former smokers | 2.1 (1.1–4.2) | Case definition of periodontitis: ≥1 site with PPD^†^ ≥5 mm and LPA ≥2 mm; Mantel-Haenszel summary OR estimates were adjusted for age
Haber et al. 1993 | 132 patients with insulin-dependent diabetes mellitus from diabetes clinics; 95 HMO^¶^ patients | Never smoked | (referent) | Case definition of periodontitis: ≥1 site with PPD^†^ ≥5 mm and LPA ≥2 mm; Mantel-Haenszel summary OR estimates were adjusted for age
Haber et al. 1993 | 132 patients with insulin-dependent diabetes mellitus from diabetes clinics; 95 HMO^¶^ patients | Diabetes | | Case definition of periodontitis: ≥1 site with PPD^†^ ≥5 mm and LPA ≥2 mm; Mantel-Haenszel summary OR estimates were adjusted for age
Haber et al. 1993 | 132 patients with insulin-dependent diabetes mellitus from diabetes clinics; 95 HMO^¶^ patients | Current smokers | 6.9 (2.6–18.5) | Case definition of periodontitis: ≥1 site with PPD^†^ ≥5 mm and LPA ≥2 mm; Mantel-Haenszel summary OR estimates were adjusted for age
Haber et al. 1993 | 132 patients with insulin-dependent diabetes mellitus from diabetes clinics; 95 HMO^¶^ patients | Former smokers | 1.8 (0.8–4.2) | Case definition of periodontitis: ≥1 site with PPD^†^ ≥5 mm and LPA ≥2 mm; Mantel-Haenszel summary OR estimates were adjusted for age
Haber et al. 1993 | 132 patients with insulin-dependent diabetes mellitus from diabetes clinics; 95 HMO^¶^ patients | Never smoked | (referent) | Case definition of periodontitis: ≥1 site with PPD^†^ ≥5 mm and LPA ≥2 mm; Mantel-Haenszel summary OR estimates were adjusted for age
Stoltenberg et al. 1993 | 63 smokers (mean age 48 years) and 126 nonsmokers (mean age 49 years) matched for age, gender, and plaque and calculus levels HMO patients United States (Minnesota) | Mean PPD (mm) | | It is unclear if former smokers were included in the study; smokers also had a higher prevalence than nonsmokers of ≥1 site with PPD ≥4.5 mm or ≥5.5 mm
Stoltenberg et al. 1993 | 63 smokers (mean age 48 years) and 126 nonsmokers (mean age 49 years) matched for age, gender, and plaque and calculus levels HMO patients United States (Minnesota) | Smokers | 3.12 | It is unclear if former smokers were included in the study; smokers also had a higher prevalence than nonsmokers of ≥1 site with PPD ≥4.5 mm or ≥5.5 mm
Stoltenberg et al. 1993 | 63 smokers (mean age 48 years) and 126 nonsmokers (mean age 49 years) matched for age, gender, and plaque and calculus levels HMO patients United States (Minnesota) | Nonsmokers | 2.94 | It is unclear if former smokers were included in the study; smokers also had a higher prevalence than nonsmokers of ≥1 site with PPD ≥4.5 mm or ≥5.5 mm
Stoltenberg et al. 1993 | 63 smokers (mean age 48 years) and 126 nonsmokers (mean age 49 years) matched for age, gender, and plaque and calculus levels HMO patients United States (Minnesota) | Prevalence (%), OR, and 95% CI for having mean PPD ≥3.5 mm | | It is unclear if former smokers were included in the study; smokers also had a higher prevalence than nonsmokers of ≥1 site with PPD ≥4.5 mm or ≥5.5 mm
Stoltenberg et al. 1993 | 63 smokers (mean age 48 years) and 126 nonsmokers (mean age 49 years) matched for age, gender, and plaque and calculus levels HMO patients United States (Minnesota) | Smokers | 24 5.3 (2.0–13.8) | It is unclear if former smokers were included in the study; smokers also had a higher prevalence than nonsmokers of ≥1 site with PPD ≥4.5 mm or ≥5.5 mm
Stoltenberg et al. 1993 | 63 smokers (mean age 48 years) and 126 nonsmokers (mean age 49 years) matched for age, gender, and plaque and calculus levels HMO patients United States (Minnesota) | Nonsmokers | 6 (referent) | It is unclear if former smokers were included in the study; smokers also had a higher prevalence than nonsmokers of ≥1 site with PPD ≥4.5 mm or ≥5.5 mm
Stoltenberg et al. 1993 | 63 smokers (mean age 48 years) and 126 nonsmokers (mean age 49 years) matched for age, gender, and plaque and calculus levels HMO patients United States (Minnesota) | Prevalence (%) of ≥1 site with PPD ≥3.5 mm | | It is unclear if former smokers were included in the study; smokers also had a higher prevalence than nonsmokers of ≥1 site with PPD ≥4.5 mm or ≥5.5 mm
Stoltenberg et al. 1993 | 63 smokers (mean age 48 years) and 126 nonsmokers (mean age 49 years) matched for age, gender, and plaque and calculus levels HMO patients United States (Minnesota) | Smokers | 76.2 | It is unclear if former smokers were included in the study; smokers also had a higher prevalence than nonsmokers of ≥1 site with PPD ≥4.5 mm or ≥5.5 mm
Stoltenberg et al. 1993 | 63 smokers (mean age 48 years) and 126 nonsmokers (mean age 49 years) matched for age, gender, and plaque and calculus levels HMO patients United States (Minnesota) | Nonsmokers | 59.5 | It is unclear if former smokers were included in the study; smokers also had a higher prevalence than nonsmokers of ≥1 site with PPD ≥4.5 mm or ≥5.5 mm
Wouters et al. 1993 | Population-based sample of 378 men and 345 women Aged ≥20 years Sweden | Age-standardized mean inter-proximal alveolar bone height as a percentage of root length, by smoking status | | Current smoking (but not former smoking) was significantly associated with mean interproximal alveolar bone heights in a multiple linear regression model that included gender, age, urban/rural residence, level of education, frequency of dental and dental hygiene visits, number of tooth surfaces, plaque and calculus scores, and the presence of defective dental restorations
Wouters et al. 1993 | Population-based sample of 378 men and 345 women Aged ≥20 years Sweden | Current smokers | 77.0
Wouters et al. 1993 | Population-based sample of 378 men and 345 women Aged ≥20 years Sweden | Former smokers | 81.5
Wouters et al. 1993 | Population-based sample of 378 men and 345 women Aged ≥20 years Sweden | Never smoked | 83.1
Grossi et al. 1994 | Population-based sample of 741 women and 685 men Aged 25–74 years United States (New York) | OR (95% CI) for smoking and LPA^*^ | | This stepwise ordinal logistic regression analysis used the mean LPA as a dependent variable (5 ordinal categories), and included age, gender, education, diabetes status, anemia, allergy, and plaque bacteria levels
Grossi et al. 1994 | Population-based sample of 741 women and 685 men Aged 25–74 years United States (New York) | Pack-years^**^
Grossi et al. 1994 | Population-based sample of 741 women and 685 men Aged 25–74 years United States (New York) | 5.3–15.0 | 2.05 (1.47–2.87)
Grossi et al. 1994 | Population-based sample of 741 women and 685 men Aged 25–74 years United States (New York) | 15.1–30.0 | 2.77 (1.91–4.02)
Grossi et al. 1994 | Population-based sample of 741 women and 685 men Aged 25–74 years United States (New York) | 30.1–150.0 | 4.75 (3.28–6.91)
Linden and Mullally 1994 | Random sample of 82 regular dental attenders Aged 20–33 years Northern Ireland | Mean PPD^†^ (mm) | | Nonsmokers included never smokers and those who had quit ≥2 years before examination
Linden and Mullally 1994 | Random sample of 82 regular dental attenders Aged 20–33 years Northern Ireland | Current smokers | 2.9 | Nonsmokers included never smokers and those who had quit ≥2 years before examination
Linden and Mullally 1994 | Random sample of 82 regular dental attenders Aged 20–33 years Northern Ireland | Nonsmokers | 2.6 | Nonsmokers included never smokers and those who had quit ≥2 years before examination
Linden and Mullally 1994 | Random sample of 82 regular dental attenders Aged 20–33 years Northern Ireland | Mean number of pockets ≥4 mm | | Nonsmokers included never smokers and those who had quit ≥2 years before examination
Linden and Mullally 1994 | Random sample of 82 regular dental attenders Aged 20–33 years Northern Ireland | Current smokers | 14.6 | Nonsmokers included never smokers and those who had quit ≥2 years before examination
Linden and Mullally 1994 | Random sample of 82 regular dental attenders Aged 20–33 years Northern Ireland | Nonsmokers | 5.8 | Nonsmokers included never smokers and those who had quit ≥2 years before examination
Linden and Mullally 1994 | Random sample of 82 regular dental attenders Aged 20–33 years Northern Ireland | Mean LPA (mm) | | Nonsmokers included never smokers and those who had quit ≥2 years before examination
Linden and Mullally 1994 | Random sample of 82 regular dental attenders Aged 20–33 years Northern Ireland | Current smokers | 1.2 | Nonsmokers included never smokers and those who had quit ≥2 years before examination
Linden and Mullally 1994 | Random sample of 82 regular dental attenders Aged 20–33 years Northern Ireland | Nonsmokers | 0.7 | Nonsmokers included never smokers and those who had quit ≥2 years before examination
Linden and Mullally 1994 | Random sample of 82 regular dental attenders Aged 20–33 years Northern Ireland | Mean number of LPA sites ≥2 mm | | Nonsmokers included never smokers and those who had quit ≥2 years before examination
Linden and Mullally 1994 | Random sample of 82 regular dental attenders Aged 20–33 years Northern Ireland | Current smokers | 21.8 | Nonsmokers included never smokers and those who had quit ≥2 years before examination
Linden and Mullally 1994 | Random sample of 82 regular dental attenders Aged 20–33 years Northern Ireland | Nonsmokers | 9.3 | Nonsmokers included never smokers and those who had quit ≥2 years before examination
Söder et al. 1994 | Population-based sample of 840 men and 841 women Aged 31–40 years Sweden | Prevalence (%) of teeth (≥1) with PPD^†^ ≥5 mm by smoking status | | Smoking was a highly significant correlate of the number of teeth with PPD ≥5 mm in a multiple linear regression model that also included gender, most recent dental visit, debris and calculus index scores, and the number of teeth
Söder et al. 1994 | Population-based sample of 840 men and 841 women Aged 31–40 years Sweden | Current smokers | 23.1
Söder et al. 1994 | Population-based sample of 840 men and 841 women Aged 31–40 years Sweden | Former smokers | 18.7
Söder et al. 1994 | Population-based sample of 840 men and 841 women Aged 31–40 years Sweden | Never smoked | 10.1
Söder et al. 1994 | Population-based sample of 840 men and 841 women Aged 31–40 years Sweden | Mean number (%) of teeth with PPD ≥5 mm by smoking status
Söder et al. 1994 | Population-based sample of 840 men and 841 women Aged 31–40 years Sweden | Current smokers | 1.4 (5.3)
Söder et al. 1994 | Population-based sample of 840 men and 841 women Aged 31–40 years Sweden | Former smokers | 0.9 (3.4)
Söder et al. 1994 | Population-based sample of 840 men and 841 women Aged 31–40 years Sweden | Never smoked | 0.4 (1.6)
Grossi et al. 1995 | Population-based sample of 696 women and 665 men Aged 25–74 years United States (New York) | OR (95% CI) for smoking and alveolar bone loss | | This stepwise ordinal logistic regression analysis, with mean alveolar bone loss as a dependent variable (4 ordinal categories), also included age, gender, race, education, kidney disease, allergy, and plaque bacteria levels
Grossi et al. 1995 | Population-based sample of 696 women and 665 men Aged 25–74 years United States (New York) | Pack-years
Grossi et al. 1995 | Population-based sample of 696 women and 665 men Aged 25–74 years United States (New York) | >0–5.2 | 1.48 (1.02–2.14)
Grossi et al. 1995 | Population-based sample of 696 women and 665 men Aged 25–74 years United States (New York) | 5.3–15.0 | 3.25 (2.33–4.54)
Grossi et al. 1995 | Population-based sample of 696 women and 665 men Aged 25–74 years United States (New York) | 15.1–30.0 | 5.79 (4.08–8.27)
Grossi et al. 1995 | Population-based sample of 696 women and 665 men Aged 25–74 years United States (New York) | 30.1–150.0 | 7.28 (5.09–10.31)
Martinez-Canut et al. 1995 | 340 male and 549 female periodontal patients with mild to moderate periodontitis Aged 21–76 years Spain | Mean PPD (mm) by cigarettes/day | | The number of cigarettes smoked per day was significantly associated with log transformed mean GR, PPD, and LPA^*^ in ANOVA^‡‡^ models that also included age and gender
Martinez-Canut et al. 1995 | 340 male and 549 female periodontal patients with mild to moderate periodontitis Aged 21–76 years Spain | 0 | 3.36 | The number of cigarettes smoked per day was significantly associated with log transformed mean GR, PPD, and LPA^*^ in ANOVA^‡‡^ models that also included age and gender
Martinez-Canut et al. 1995 | 340 male and 549 female periodontal patients with mild to moderate periodontitis Aged 21–76 years Spain | 1–10 | 3.47 | The number of cigarettes smoked per day was significantly associated with log transformed mean GR, PPD, and LPA^*^ in ANOVA^‡‡^ models that also included age and gender
Martinez-Canut et al. 1995 | 340 male and 549 female periodontal patients with mild to moderate periodontitis Aged 21–76 years Spain | 11–20 | 3.68 | The number of cigarettes smoked per day was significantly associated with log transformed mean GR, PPD, and LPA^*^ in ANOVA^‡‡^ models that also included age and gender
Martinez-Canut et al. 1995 | 340 male and 549 female periodontal patients with mild to moderate periodontitis Aged 21–76 years Spain | ≥21 | 3.69 | The number of cigarettes smoked per day was significantly associated with log transformed mean GR, PPD, and LPA^*^ in ANOVA^‡‡^ models that also included age and gender
Martinez-Canut et al. 1995 | 340 male and 549 female periodontal patients with mild to moderate periodontitis Aged 21–76 years Spain | Mean GR^††^ (mm) by cigarettes/day | | The number of cigarettes smoked per day was significantly associated with log transformed mean GR, PPD, and LPA^*^ in ANOVA^‡‡^ models that also included age and gender
Martinez-Canut et al. 1995 | 340 male and 549 female periodontal patients with mild to moderate periodontitis Aged 21–76 years Spain | 0 | 0.48 | The number of cigarettes smoked per day was significantly associated with log transformed mean GR, PPD, and LPA^*^ in ANOVA^‡‡^ models that also included age and gender
Martinez-Canut et al. 1995 | 340 male and 549 female periodontal patients with mild to moderate periodontitis Aged 21–76 years Spain | 1–10 | 0.43 | The number of cigarettes smoked per day was significantly associated with log transformed mean GR, PPD, and LPA^*^ in ANOVA^‡‡^ models that also included age and gender
Martinez-Canut et al. 1995 | 340 male and 549 female periodontal patients with mild to moderate periodontitis Aged 21–76 years Spain | 11–20 | 0.68 | The number of cigarettes smoked per day was significantly associated with log transformed mean GR, PPD, and LPA^*^ in ANOVA^‡‡^ models that also included age and gender
Martinez-Canut et al. 1995 | 340 male and 549 female periodontal patients with mild to moderate periodontitis Aged 21–76 years Spain | ≥21 | 0.81 | The number of cigarettes smoked per day was significantly associated with log transformed mean GR, PPD, and LPA^*^ in ANOVA^‡‡^ models that also included age and gender
Martinez-Canut et al. 1995 | 340 male and 549 female periodontal patients with mild to moderate periodontitis Aged 21–76 years Spain | Mean LPA (mm) by cigarettes/day | | The number of cigarettes smoked per day was significantly associated with log transformed mean GR, PPD, and LPA^*^ in ANOVA^‡‡^ models that also included age and gender
Martinez-Canut et al. 1995 | 340 male and 549 female periodontal patients with mild to moderate periodontitis Aged 21–76 years Spain | 0 | 3.84 | The number of cigarettes smoked per day was significantly associated with log transformed mean GR, PPD, and LPA^*^ in ANOVA^‡‡^ models that also included age and gender
Martinez-Canut et al. 1995 | 340 male and 549 female periodontal patients with mild to moderate periodontitis Aged 21–76 years Spain | 1–10 | 3.72 | The number of cigarettes smoked per day was significantly associated with log transformed mean GR, PPD, and LPA^*^ in ANOVA^‡‡^ models that also included age and gender
Martinez-Canut et al. 1995 | 340 male and 549 female periodontal patients with mild to moderate periodontitis Aged 21–76 years Spain | 11–20 | 4.36 | The number of cigarettes smoked per day was significantly associated with log transformed mean GR, PPD, and LPA^*^ in ANOVA^‡‡^ models that also included age and gender
Martinez-Canut et al. 1995 | 340 male and 549 female periodontal patients with mild to moderate periodontitis Aged 21–76 years Spain | ≥21 | 4.50 | The number of cigarettes smoked per day was significantly associated with log transformed mean GR, PPD, and LPA^*^ in ANOVA^‡‡^ models that also included age and gender
Sakki et al. 1995 | Population-based sample of 266 men and 261 women Aged 55 years Finland | Periodontal sites (%) at risk for PPD^†^ ≥3 mm | | Current and former smokers were not separated; in this multiple logistic regression model, persons with disease were defined as those in the upper one-third of the distribution of the percentage of sites with PPD ≥3 mm; dietary habits, alcohol intake, and toothbrushing frequency were also included
Sakki et al. 1995 | Population-based sample of 266 men and 261 women Aged 55 years Finland | Never smoked | 8.4
Sakki et al. 1995 | Population-based sample of 266 men and 261 women Aged 55 years Finland | Ever smoked | 15.3
Sakki et al. 1995 | Population-based sample of 266 men and 261 women Aged 55 years Finland | OR for periodontitis (95% CI)
Sakki et al. 1995 | Population-based sample of 266 men and 261 women Aged 55 years Finland | Ever smoked | 1.73 (1.11–2.68)
Schenkein et al. 1995 | 431 male and 335 female periodontal patients and their family members Aged 5–80 years United States (Virginia) | Prevalence (%) of current smoking by disease classification | | Current smoking was determined by serum cotinine analysis; former smoking was not measured; case definitions differed for probands and family members; means were adjusted for age and plaque index scores; among persons with LJP, the mean LPA and mean number of teeth with LPA ≥2 mm or ≥5 mm did not differ between smokers and nonsmokers
Schenkein et al. 1995 | 431 male and 335 female periodontal patients and their family members Aged 5–80 years United States (Virginia) | Localized juvenile periodontitis (LJP) | 20
Schenkein et al. 1995 | 431 male and 335 female periodontal patients and their family members Aged 5–80 years United States (Virginia) | Generalized early-onset periodontitis (GEOP) | 43
Schenkein et al. 1995 | 431 male and 335 female periodontal patients and their family members Aged 5–80 years United States (Virginia) | Adult periodontitis | 38
Schenkein et al. 1995 | 431 male and 335 female periodontal patients and their family members Aged 5–80 years United States (Virginia) | Healthy | 16
Schenkein et al. 1995 | 431 male and 335 female periodontal patients and their family members Aged 5–80 years United States (Virginia) | Mean number of teeth with LPA^*^ ≥5 mm by disease and smoking status
Schenkein et al. 1995 | 431 male and 335 female periodontal patients and their family members Aged 5–80 years United States (Virginia) | GEOP
Schenkein et al. 1995 | 431 male and 335 female periodontal patients and their family members Aged 5–80 years United States (Virginia) | Current smokers | 49.0
Schenkein et al. 1995 | 431 male and 335 female periodontal patients and their family members Aged 5–80 years United States (Virginia) | Not current | 36.8
Schenkein et al. 1995 | 431 male and 335 female periodontal patients and their family members Aged 5–80 years United States (Virginia) | GEOP (probands)
Schenkein et al. 1995 | 431 male and 335 female periodontal patients and their family members Aged 5–80 years United States (Virginia) | Current smokers | 62.7
Schenkein et al. 1995 | 431 male and 335 female periodontal patients and their family members Aged 5–80 years United States (Virginia) | Not current | 49.8
Schenkein et al. 1995 | 431 male and 335 female periodontal patients and their family members Aged 5–80 years United States (Virginia) | Adult periodontitis
Schenkein et al. 1995 | 431 male and 335 female periodontal patients and their family members Aged 5–80 years United States (Virginia) | Current smokers | 16.2
Schenkein et al. 1995 | 431 male and 335 female periodontal patients and their family members Aged 5–80 years United States (Virginia) | Not current | 8.2
Söder et al. 1995 | 85 men and 59 women with at least 1 PPD site ≥5 mm, selected from population-based sample Aged 31–40 years Sweden | Mean PPD (mm) by smoking status | | There was no control group; all subjects had disease; response rate was 50% among persons with disease identified in a population-based survey; it is unclear if nonsmokers included former smokers
Söder et al. 1995 | 85 men and 59 women with at least 1 PPD site ≥5 mm, selected from population-based sample Aged 31–40 years Sweden | Current smokers | 3.0 | There was no control group; all subjects had disease; response rate was 50% among persons with disease identified in a population-based survey; it is unclear if nonsmokers included former smokers
Söder et al. 1995 | 85 men and 59 women with at least 1 PPD site ≥5 mm, selected from population-based sample Aged 31–40 years Sweden | Nonsmokers | 2.8 | There was no control group; all subjects had disease; response rate was 50% among persons with disease identified in a population-based survey; it is unclear if nonsmokers included former smokers
Söder et al. 1995 | 85 men and 59 women with at least 1 PPD site ≥5 mm, selected from population-based sample Aged 31–40 years Sweden | Number of PPD sites at ≥5 mm | | There was no control group; all subjects had disease; response rate was 50% among persons with disease identified in a population-based survey; it is unclear if nonsmokers included former smokers
Söder et al. 1995 | 85 men and 59 women with at least 1 PPD site ≥5 mm, selected from population-based sample Aged 31–40 years Sweden | Current smokers | 15.4 | There was no control group; all subjects had disease; response rate was 50% among persons with disease identified in a population-based survey; it is unclear if nonsmokers included former smokers
Söder et al. 1995 | 85 men and 59 women with at least 1 PPD site ≥5 mm, selected from population-based sample Aged 31–40 years Sweden | Nonsmokers | 11.6 | There was no control group; all subjects had disease; response rate was 50% among persons with disease identified in a population-based survey; it is unclear if nonsmokers included former smokers
Söder et al. 1995 | 85 men and 59 women with at least 1 PPD site ≥5 mm, selected from population-based sample Aged 31–40 years Sweden | Mean alveolar bone height (%) | | There was no control group; all subjects had disease; response rate was 50% among persons with disease identified in a population-based survey; it is unclear if nonsmokers included former smokers
Söder et al. 1995 | 85 men and 59 women with at least 1 PPD site ≥5 mm, selected from population-based sample Aged 31–40 years Sweden | Current smokers | 76.9 | There was no control group; all subjects had disease; response rate was 50% among persons with disease identified in a population-based survey; it is unclear if nonsmokers included former smokers
Söder et al. 1995 | 85 men and 59 women with at least 1 PPD site ≥5 mm, selected from population-based sample Aged 31–40 years Sweden | Nonsmokers | 80.2 | There was no control group; all subjects had disease; response rate was 50% among persons with disease identified in a population-based survey; it is unclear if nonsmokers included former smokers
Tomar et al. 1995 | 416 male and 58 female HIV^§§^-infected military personnel Aged 18–49 years United States | Unadjusted OR (95% CI) for having ≥1 LPA^*^ site ≥5 mm | | This multiple logistic regression model included age, stage of HIV disease, gender, retirement status, gingival cratering or ulceration, AZTΔΔ use, and the presence of oral candidiasis
Tomar et al. 1995 | 416 male and 58 female HIV^§§^-infected military personnel Aged 18–49 years United States | Current smokers | 2.6 (1.5–4.8) | This multiple logistic regression model included age, stage of HIV disease, gender, retirement status, gingival cratering or ulceration, AZTΔΔ use, and the presence of oral candidiasis
Tomar et al. 1995 | 416 male and 58 female HIV^§§^-infected military personnel Aged 18–49 years United States | Former smokers | 2.4 (1.2–4.9) | This multiple logistic regression model included age, stage of HIV disease, gender, retirement status, gingival cratering or ulceration, AZTΔΔ use, and the presence of oral candidiasis
Tomar et al. 1995 | 416 male and 58 female HIV^§§^-infected military personnel Aged 18–49 years United States | Never smoked | 1.0 (referent) | This multiple logistic regression model included age, stage of HIV disease, gender, retirement status, gingival cratering or ulceration, AZTΔΔ use, and the presence of oral candidiasis
Tomar et al. 1995 | 416 male and 58 female HIV^§§^-infected military personnel Aged 18–49 years United States | Adjusted OR (95% CI) for having ≥1 LPA site ≥5 mm | | This multiple logistic regression model included age, stage of HIV disease, gender, retirement status, gingival cratering or ulceration, AZTΔΔ use, and the presence of oral candidiasis
Tomar et al. 1995 | 416 male and 58 female HIV^§§^-infected military personnel Aged 18–49 years United States | Current smokers | 2.0 (1.1–3.5) | This multiple logistic regression model included age, stage of HIV disease, gender, retirement status, gingival cratering or ulceration, AZTΔΔ use, and the presence of oral candidiasis
Tomar et al. 1995 | 416 male and 58 female HIV^§§^-infected military personnel Aged 18–49 years United States | Former smokers | 1.0 (referent) | This multiple logistic regression model included age, stage of HIV disease, gender, retirement status, gingival cratering or ulceration, AZTΔΔ use, and the presence of oral candidiasis
Ahlberg et al. 1996 | 483 male industrial workers Aged 38–65 years Finland | Adjusted OR (95% CI) for having PPD^†^ ≥4 mm | | Used the CPITNΔ; persons who had quit smoking <6 months before the study were considered smokers; all others were nonsmokers; this logistic regression model included education, access to subsidized dental care, toothbrushing frequency, most recent dental visit, and age
Ahlberg et al. 1996 | 483 male industrial workers Aged 38–65 years Finland | Smokers | 2.1 (1.3–3.5)
Alpagot et al. 1996 | 71 female and 46 male dental patients Aged 18–70 years United States (Minnesota) | Pearson correlation coefficients, pack-years | | An association between pack-years of smoking and the mean LPA or mean PPD was statistically significant in stepwise multiple linear regression models that also included age, enzyme levels in gingival crevicular fluid (β-glucuronidase, neutrophil elastase, myeloperoxidase), and plaque bacteria levels (Fasibacterium nucleatum, Prevotella intermedia, Porphyromonas gingivalis, Eikenella corrodens, and Actinobacillus actinomycetemcomitans)
Alpagot et al. 1996 | 71 female and 46 male dental patients Aged 18–70 years United States (Minnesota) | Mean LPA (mm) | 0.23
Alpagot et al. 1996 | 71 female and 46 male dental patients Aged 18–70 years United States (Minnesota) | Mean PPD (mm) | 0.27
Bridges et al. 1996 | 118 men with diabetes (46 with type I, 72 with type II) and 115 age-matched men without diabetes, from outpatient clinics Aged 24–78 years United States (Kentucky) | Pearson correlation coefficients for smoking and periodontal parameters | | The mean PPD and LPA were described as higher among smokers with diabetes than among other groups, but the data were not reported; smoking was reported to be significantly associated with the mean PPD and LPA in a multiple linear regression model, but regression parameters were not reported; smoking included cigarettes, cigars, and pipes; the prevalence of tobacco use was not reported
Bridges et al. 1996 | 118 men with diabetes (46 with type I, 72 with type II) and 115 age-matched men without diabetes, from outpatient clinics Aged 24–78 years United States (Kentucky) | Mean PPD^†^ (mm)
Bridges et al. 1996 | 118 men with diabetes (46 with type I, 72 with type II) and 115 age-matched men without diabetes, from outpatient clinics Aged 24–78 years United States (Kentucky) | Diabetic | 0.23
Bridges et al. 1996 | 118 men with diabetes (46 with type I, 72 with type II) and 115 age-matched men without diabetes, from outpatient clinics Aged 24–78 years United States (Kentucky) | Nondiabetic | 0.25
Bridges et al. 1996 | 118 men with diabetes (46 with type I, 72 with type II) and 115 age-matched men without diabetes, from outpatient clinics Aged 24–78 years United States (Kentucky) | Mean LPA^*^ (mm)
Bridges et al. 1996 | 118 men with diabetes (46 with type I, 72 with type II) and 115 age-matched men without diabetes, from outpatient clinics Aged 24–78 years United States (Kentucky) | Diabetic | 0.34
Bridges et al. 1996 | 118 men with diabetes (46 with type I, 72 with type II) and 115 age-matched men without diabetes, from outpatient clinics Aged 24–78 years United States (Kentucky) | Nondiabetic | NR^¶¶^
González et al. 1996 | 79 persons with established periodontitis, including 30 current smokers, 34 former smokers, 15 never smokers Aged 25–64 years United States (New York) | Correlation coefficients between serum cotinine levels and periodontal measures | | None
González et al. 1996 | 79 persons with established periodontitis, including 30 current smokers, 34 former smokers, 15 never smokers Aged 25–64 years United States (New York) | Mean LPA (mm) | 0.498 | None
González et al. 1996 | 79 persons with established periodontitis, including 30 current smokers, 34 former smokers, 15 never smokers Aged 25–64 years United States (New York) | Mean crestal bone height (mm) | 0.473 | None
Mullally and Linden 1996 | 100 periodontal patients 50 current smokers (mean age 44 years) and 50 never smokers (mean age 46 years) Northern Ireland | Persons (%) with furcation involvement of ≥1 molar | | Maxillary and mandibular 1st and 2nd molars were assessed radiographically; furcation involvement was defined as the area of radiolucency at furcation of the roots of at least 1 molar; molars with fused roots were excluded from the analysis
Mullally and Linden 1996 | 100 periodontal patients 50 current smokers (mean age 44 years) and 50 never smokers (mean age 46 years) Northern Ireland | Current smokers | 74
Mullally and Linden 1996 | 100 periodontal patients 50 current smokers (mean age 44 years) and 50 never smokers (mean age 46 years) Northern Ireland | Never smoked | 40
Mullally and Linden 1996 | 100 periodontal patients 50 current smokers (mean age 44 years) and 50 never smokers (mean age 46 years) Northern Ireland | Molars with furcation involvement (%)
Mullally and Linden 1996 | 100 periodontal patients 50 current smokers (mean age 44 years) and 50 never smokers (mean age 46 years) Northern Ireland | Current smokers | 39
Mullally and Linden 1996 | 100 periodontal patients 50 current smokers (mean age 44 years) and 50 never smokers (mean age 46 years) Northern Ireland | Never smoked | 16
Dolan et al. 1997a | Population-based sample of 471 adults Aged ≥45 years United States (Florida) | Prevalence (%) of teeth (≥1) with ≥7 mm LPA^*^ | | Estimates of prevalence and extent of LPA were significantly higher among current smokers but were not adjusted for other factors; OR estimates were adjusted for diabetes status, use of dental care services, tooth-brushing, flossing, and use of toothpicks
Dolan et al. 1997a | Population-based sample of 471 adults Aged ≥45 years United States (Florida) | Current smokers | 49
Dolan et al. 1997a | Population-based sample of 471 adults Aged ≥45 years United States (Florida) | Former smokers | 33
Dolan et al. 1997a | Population-based sample of 471 adults Aged ≥45 years United States (Florida) | Never smoked | 37
Dolan et al. 1997a | Population-based sample of 471 adults Aged ≥45 years United States (Florida) | OR (95% CI) for teeth (≥1) with ≥7 mm LPA
Dolan et al. 1997a | Population-based sample of 471 adults Aged ≥45 years United States (Florida) | Current smokers | 1.9 (1.2–2.9)
Dolan et al. 1997a | Population-based sample of 471 adults Aged ≥45 years United States (Florida) | Former smokers | 1.1 (0.8–1.6)
Dolan et al. 1997a | Population-based sample of 471 adults Aged ≥45 years United States (Florida) | Never smoked | (referent)
Dolan et al. 1997a | Population-based sample of 471 adults Aged ≥45 years United States (Florida) | Teeth/person with 4–6 mm LPA (mean %)
Dolan et al. 1997a | Population-based sample of 471 adults Aged ≥45 years United States (Florida) | Current smokers | 42
Dolan et al. 1997a | Population-based sample of 471 adults Aged ≥45 years United States (Florida) | Former smokers | 36
Dolan et al. 1997a | Population-based sample of 471 adults Aged ≥45 years United States (Florida) | Never smoked | 35
Dolan et al. 1997a | Population-based sample of 471 adults Aged ≥45 years United States (Florida) | Teeth/person with ≥ 7 mm LPA (mean %)
Dolan et al. 1997a | Population-based sample of 471 adults Aged ≥45 years United States (Florida) | Current smokers | 21
Dolan et al. 1997a | Population-based sample of 471 adults Aged ≥45 years United States (Florida) | Former smokers | 10
Dolan et al. 1997a | Population-based sample of 471 adults Aged ≥45 years United States (Florida) | Never smoked | 8
Hildebolt et al. 1997 | Convenience sample of 155 postmenopausal women Aged 41–71 years United States (Missouri) | Correlation between pack-years and LPA = 0.16 (p <0.07) | | There was a significant association between age and current smoking status; pack-years of smoking were not significantly associated with the mean LPA among current smokers
Hildebolt et al. 1997 | Convenience sample of 155 postmenopausal women Aged 41–71 years United States (Missouri) | Parameter estimates for least square linear regression model: | | There was a significant association between age and current smoking status; pack-years of smoking were not significantly associated with the mean LPA among current smokers
Hildebolt et al. 1997 | Convenience sample of 155 postmenopausal women Aged 41–71 years United States (Missouri) | Intercept | 1.01 | There was a significant association between age and current smoking status; pack-years of smoking were not significantly associated with the mean LPA among current smokers
Hildebolt et al. 1997 | Convenience sample of 155 postmenopausal women Aged 41–71 years United States (Missouri) | Age | 0.02 | There was a significant association between age and current smoking status; pack-years of smoking were not significantly associated with the mean LPA among current smokers
Hildebolt et al. 1997 | Convenience sample of 155 postmenopausal women Aged 41–71 years United States (Missouri) | Years menopausal | 0.02 | There was a significant association between age and current smoking status; pack-years of smoking were not significantly associated with the mean LPA among current smokers
Hildebolt et al. 1997 | Convenience sample of 155 postmenopausal women Aged 41–71 years United States (Missouri) | Current smokers | 2.22 | There was a significant association between age and current smoking status; pack-years of smoking were not significantly associated with the mean LPA among current smokers
Hildebolt et al. 1997 | Convenience sample of 155 postmenopausal women Aged 41–71 years United States (Missouri) | Age^***^ current smokers | −0.04 | There was a significant association between age and current smoking status; pack-years of smoking were not significantly associated with the mean LPA among current smokers
Imaki et al. 1997 | 1,611 male factory workers Aged 20–59 years Japan | Persons (%) with PPD^†^ ≥4 mm by plaque bacteria levels, age, smoking status, and cigarettes/day | | Used the CPITNΔ; periodontal pocketing was significantly more prevalent among smokers than nonsmokers, and among persons with high plaque levels
Imaki et al. 1997 | 1,611 male factory workers Aged 20–59 years Japan | Low plaque levels | | Used the CPITNΔ; periodontal pocketing was significantly more prevalent among smokers than nonsmokers, and among persons with high plaque levels
Imaki et al. 1997 | 1,611 male factory workers Aged 20–59 years Japan | Aged 20–39 years | | Used the CPITNΔ; periodontal pocketing was significantly more prevalent among smokers than nonsmokers, and among persons with high plaque levels
Imaki et al. 1997 | 1,611 male factory workers Aged 20–59 years Japan | Current smokers | 15.1 | Used the CPITNΔ; periodontal pocketing was significantly more prevalent among smokers than nonsmokers, and among persons with high plaque levels
Imaki et al. 1997 | 1,611 male factory workers Aged 20–59 years Japan | 1–20 | 14.3 | Used the CPITNΔ; periodontal pocketing was significantly more prevalent among smokers than nonsmokers, and among persons with high plaque levels
Imaki et al. 1997 | 1,611 male factory workers Aged 20–59 years Japan | ≥21 | 16.9 | Used the CPITNΔ; periodontal pocketing was significantly more prevalent among smokers than nonsmokers, and among persons with high plaque levels
Imaki et al. 1997 | 1,611 male factory workers Aged 20–59 years Japan | Former smokers | 12.8 | Used the CPITNΔ; periodontal pocketing was significantly more prevalent among smokers than nonsmokers, and among persons with high plaque levels
Imaki et al. 1997 | 1,611 male factory workers Aged 20–59 years Japan | Never smoked | 17.4 | Used the CPITNΔ; periodontal pocketing was significantly more prevalent among smokers than nonsmokers, and among persons with high plaque levels
Imaki et al. 1997 | 1,611 male factory workers Aged 20–59 years Japan | Aged 40–59 years | | Used the CPITNΔ; periodontal pocketing was significantly more prevalent among smokers than nonsmokers, and among persons with high plaque levels
Imaki et al. 1997 | 1,611 male factory workers Aged 20–59 years Japan | Current smokers | 43.7 | Used the CPITNΔ; periodontal pocketing was significantly more prevalent among smokers than nonsmokers, and among persons with high plaque levels
Imaki et al. 1997 | 1,611 male factory workers Aged 20–59 years Japan | 1–20 | 40.5 | Used the CPITNΔ; periodontal pocketing was significantly more prevalent among smokers than nonsmokers, and among persons with high plaque levels
Imaki et al. 1997 | 1,611 male factory workers Aged 20–59 years Japan | ≥21 | 47.3 | Used the CPITNΔ; periodontal pocketing was significantly more prevalent among smokers than nonsmokers, and among persons with high plaque levels
Imaki et al. 1997 | 1,611 male factory workers Aged 20–59 years Japan | Former smokers | 31.6 | Used the CPITNΔ; periodontal pocketing was significantly more prevalent among smokers than nonsmokers, and among persons with high plaque levels
Imaki et al. 1997 | 1,611 male factory workers Aged 20–59 years Japan | Never smoked | 32.0 | Used the CPITNΔ; periodontal pocketing was significantly more prevalent among smokers than nonsmokers, and among persons with high plaque levels
Imaki et al. 1997 | 1,611 male factory workers Aged 20–59 years Japan | High plaque levels | | Used the CPITNΔ; periodontal pocketing was significantly more prevalent among smokers than nonsmokers, and among persons with high plaque levels
Imaki et al. 1997 | 1,611 male factory workers Aged 20–59 years Japan | Aged 20–39 years | | Used the CPITNΔ; periodontal pocketing was significantly more prevalent among smokers than nonsmokers, and among persons with high plaque levels
Imaki et al. 1997 | 1,611 male factory workers Aged 20–59 years Japan | Current smokers | 49.7 | Used the CPITNΔ; periodontal pocketing was significantly more prevalent among smokers than nonsmokers, and among persons with high plaque levels
Imaki et al. 1997 | 1,611 male factory workers Aged 20–59 years Japan | 1–20 | 49.3 | Used the CPITNΔ; periodontal pocketing was significantly more prevalent among smokers than nonsmokers, and among persons with high plaque levels
Imaki et al. 1997 | 1,611 male factory workers Aged 20–59 years Japan | ≥21 | 50.5 | Used the CPITNΔ; periodontal pocketing was significantly more prevalent among smokers than nonsmokers, and among persons with high plaque levels
Imaki et al. 1997 | 1,611 male factory workers Aged 20–59 years Japan | Former smokers | 43.4 | Used the CPITNΔ; periodontal pocketing was significantly more prevalent among smokers than nonsmokers, and among persons with high plaque levels
Imaki et al. 1997 | 1,611 male factory workers Aged 20–59 years Japan | Never smoked | 29.3 | Used the CPITNΔ; periodontal pocketing was significantly more prevalent among smokers than nonsmokers, and among persons with high plaque levels
Imaki et al. 1997 | 1,611 male factory workers Aged 20–59 years Japan | Aged 40–59 years | | Used the CPITNΔ; periodontal pocketing was significantly more prevalent among smokers than nonsmokers, and among persons with high plaque levels
Imaki et al. 1997 | 1,611 male factory workers Aged 20–59 years Japan | Current smokers | 84.8 | Used the CPITNΔ; periodontal pocketing was significantly more prevalent among smokers than nonsmokers, and among persons with high plaque levels
Imaki et al. 1997 | 1,611 male factory workers Aged 20–59 years Japan | 1–20 | 81.3 | Used the CPITNΔ; periodontal pocketing was significantly more prevalent among smokers than nonsmokers, and among persons with high plaque levels
Imaki et al. 1997 | 1,611 male factory workers Aged 20–59 years Japan | ≥21 | 88.5 | Used the CPITNΔ; periodontal pocketing was significantly more prevalent among smokers than nonsmokers, and among persons with high plaque levels
Imaki et al. 1997 | 1,611 male factory workers Aged 20–59 years Japan | Former smokers | 82.5 | Used the CPITNΔ; periodontal pocketing was significantly more prevalent among smokers than nonsmokers, and among persons with high plaque levels
Imaki et al. 1997 | 1,611 male factory workers Aged 20–59 years Japan | Never smoked | 72.3 | Used the CPITNΔ; periodontal pocketing was significantly more prevalent among smokers than nonsmokers, and among persons with high plaque levels
Taani 1997 | Convenience sample of 998 dental patients Aged 20–60 years Jordan | Prevalence (%) of PPD ≥4 mm by age and smoking status | | Nonsmokers included both never smokers and those who had quit ≥2 years earlier; periodontal status was measured by the CPITN
Taani 1997 | Convenience sample of 998 dental patients Aged 20–60 years Jordan | Aged 20–34 years | | Nonsmokers included both never smokers and those who had quit ≥2 years earlier; periodontal status was measured by the CPITN
Taani 1997 | Convenience sample of 998 dental patients Aged 20–60 years Jordan | Smokers | 17.0 | Nonsmokers included both never smokers and those who had quit ≥2 years earlier; periodontal status was measured by the CPITN
Taani 1997 | Convenience sample of 998 dental patients Aged 20–60 years Jordan | Nonsmokers | 7.5 | Nonsmokers included both never smokers and those who had quit ≥2 years earlier; periodontal status was measured by the CPITN
Taani 1997 | Convenience sample of 998 dental patients Aged 20–60 years Jordan | Aged 35–44 years | | Nonsmokers included both never smokers and those who had quit ≥2 years earlier; periodontal status was measured by the CPITN
Taani 1997 | Convenience sample of 998 dental patients Aged 20–60 years Jordan | Smokers | 21.7 | Nonsmokers included both never smokers and those who had quit ≥2 years earlier; periodontal status was measured by the CPITN
Taani 1997 | Convenience sample of 998 dental patients Aged 20–60 years Jordan | Nonsmokers | 18.8 | Nonsmokers included both never smokers and those who had quit ≥2 years earlier; periodontal status was measured by the CPITN
Taani 1997 | Convenience sample of 998 dental patients Aged 20–60 years Jordan | Aged 45–60 years | | Nonsmokers included both never smokers and those who had quit ≥2 years earlier; periodontal status was measured by the CPITN
Taani 1997 | Convenience sample of 998 dental patients Aged 20–60 years Jordan | Smokers | 27.9 | Nonsmokers included both never smokers and those who had quit ≥2 years earlier; periodontal status was measured by the CPITN
Taani 1997 | Convenience sample of 998 dental patients Aged 20–60 years Jordan | Nonsmokers | 25.7 | Nonsmokers included both never smokers and those who had quit ≥2 years earlier; periodontal status was measured by the CPITN
Axelsson et al. 1998 | Population-based sample of 536 men and 557 women Aged 35, 50, 65, and 75 years Sweden | Mean number of missing teeth | | Former smokers were excluded from the analysis; the mean number of missing teeth was significantly higher among smokers for all ages except 35 years; the mean percent of molars with furcation involvement was higher for all age groups except 75 years; the LPA^*^ was measured at mesial surfaces of all teeth
Axelsson et al. 1998 | Population-based sample of 536 men and 557 women Aged 35, 50, 65, and 75 years Sweden | Aged 35 years
Axelsson et al. 1998 | Population-based sample of 536 men and 557 women Aged 35, 50, 65, and 75 years Sweden | Smokers | 2.0
Axelsson et al. 1998 | Population-based sample of 536 men and 557 women Aged 35, 50, 65, and 75 years Sweden | Nonsmokers | 1.6
Axelsson et al. 1998 | Population-based sample of 536 men and 557 women Aged 35, 50, 65, and 75 years Sweden | Aged 50 years
Axelsson et al. 1998 | Population-based sample of 536 men and 557 women Aged 35, 50, 65, and 75 years Sweden | Smokers | 6.3
Axelsson et al. 1998 | Population-based sample of 536 men and 557 women Aged 35, 50, 65, and 75 years Sweden | Nonsmokers | 4.8
Axelsson et al. 1998 | Population-based sample of 536 men and 557 women Aged 35, 50, 65, and 75 years Sweden | Aged 65 years
Axelsson et al. 1998 | Population-based sample of 536 men and 557 women Aged 35, 50, 65, and 75 years Sweden | Smokers | 13.8
Axelsson et al. 1998 | Population-based sample of 536 men and 557 women Aged 35, 50, 65, and 75 years Sweden | Nonsmokers | 10.3
Axelsson et al. 1998 | Population-based sample of 536 men and 557 women Aged 35, 50, 65, and 75 years Sweden | Aged 75 years
Axelsson et al. 1998 | Population-based sample of 536 men and 557 women Aged 35, 50, 65, and 75 years Sweden | Smokers | 18.8
Axelsson et al. 1998 | Population-based sample of 536 men and 557 women Aged 35, 50, 65, and 75 years Sweden | Nonsmokers | 13.0
Axelsson et al. 1998 | Population-based sample of 536 men and 557 women Aged 35, 50, 65, and 75 years Sweden | Molars with furcation involvement (mean %)
Axelsson et al. 1998 | Population-based sample of 536 men and 557 women Aged 35, 50, 65, and 75 years Sweden | Aged 35 years
Axelsson et al. 1998 | Population-based sample of 536 men and 557 women Aged 35, 50, 65, and 75 years Sweden | Smokers | 6.3
Axelsson et al. 1998 | Population-based sample of 536 men and 557 women Aged 35, 50, 65, and 75 years Sweden | Nonsmokers | 2.7
Axelsson et al. 1998 | Population-based sample of 536 men and 557 women Aged 35, 50, 65, and 75 years Sweden | Aged 50 years
Axelsson et al. 1998 | Population-based sample of 536 men and 557 women Aged 35, 50, 65, and 75 years Sweden | Smokers | 28.3
Axelsson et al. 1998 | Population-based sample of 536 men and 557 women Aged 35, 50, 65, and 75 years Sweden | Nonsmokers | 14.5
Axelsson et al. 1998 | Population-based sample of 536 men and 557 women Aged 35, 50, 65, and 75 years Sweden | Aged 65 years
Axelsson et al. 1998 | Population-based sample of 536 men and 557 women Aged 35, 50, 65, and 75 years Sweden | Smokers | 42.0
Axelsson et al. 1998 | Population-based sample of 536 men and 557 women Aged 35, 50, 65, and 75 years Sweden | Nonsmokers | 22.3
Axelsson et al. 1998 | Population-based sample of 536 men and 557 women Aged 35, 50, 65, and 75 years Sweden | Aged 75 years
Axelsson et al. 1998 | Population-based sample of 536 men and 557 women Aged 35, 50, 65, and 75 years Sweden | Smokers | 60.0
Axelsson et al. 1998 | Population-based sample of 536 men and 557 women Aged 35, 50, 65, and 75 years Sweden | Nonsmokers | 33.5
Axelsson et al. 1998 | Population-based sample of 536 men and 557 women Aged 35, 50, 65, and 75 years Sweden | Mean LPA (mm)
Axelsson et al. 1998 | Population-based sample of 536 men and 557 women Aged 35, 50, 65, and 75 years Sweden | Aged 35 years
Axelsson et al. 1998 | Population-based sample of 536 men and 557 women Aged 35, 50, 65, and 75 years Sweden | Smokers | 1.1
Axelsson et al. 1998 | Population-based sample of 536 men and 557 women Aged 35, 50, 65, and 75 years Sweden | Nonsmokers | 0.7
Axelsson et al. 1998 | Population-based sample of 536 men and 557 women Aged 35, 50, 65, and 75 years Sweden | Aged 50 years
Axelsson et al. 1998 | Population-based sample of 536 men and 557 women Aged 35, 50, 65, and 75 years Sweden | Smokers | 2.4
Axelsson et al. 1998 | Population-based sample of 536 men and 557 women Aged 35, 50, 65, and 75 years Sweden | Nonsmokers | 1.5
Axelsson et al. 1998 | Population-based sample of 536 men and 557 women Aged 35, 50, 65, and 75 years Sweden | Aged 65 years
Axelsson et al. 1998 | Population-based sample of 536 men and 557 women Aged 35, 50, 65, and 75 years Sweden | Smokers | 3.1
Axelsson et al. 1998 | Population-based sample of 536 men and 557 women Aged 35, 50, 65, and 75 years Sweden | Nonsmokers | 2.3
Axelsson et al. 1998 | Population-based sample of 536 men and 557 women Aged 35, 50, 65, and 75 years Sweden | Aged 75 years
Axelsson et al. 1998 | Population-based sample of 536 men and 557 women Aged 35, 50, 65, and 75 years Sweden | Smokers | 4.0
Axelsson et al. 1998 | Population-based sample of 536 men and 557 women Aged 35, 50, 65, and 75 years Sweden | Nonsmokers | 2.7
Gunsolley et al. 1998 | Dental patients 142 nonsmokers and 51 smokers without periodontitis Mean age = 30.9 years United States (Virginia) | Mean LPA^*^ (mm) | | Analysis of covariance; covariates included age, race, gender, and mean plaque index score
Gunsolley et al. 1998 | Dental patients 142 nonsmokers and 51 smokers without periodontitis Mean age = 30.9 years United States (Virginia) | Smokers | 0.28 | Analysis of covariance; covariates included age, race, gender, and mean plaque index score
Gunsolley et al. 1998 | Dental patients 142 nonsmokers and 51 smokers without periodontitis Mean age = 30.9 years United States (Virginia) | Nonsmokers | 0.17 | Analysis of covariance; covariates included age, race, gender, and mean plaque index score
Gunsolley et al. 1998 | Dental patients 142 nonsmokers and 51 smokers without periodontitis Mean age = 30.9 years United States (Virginia) | Teeth with ≥1 LPA site ≥2 mm (mean %) | | Analysis of covariance; covariates included age, race, gender, and mean plaque index score
Gunsolley et al. 1998 | Dental patients 142 nonsmokers and 51 smokers without periodontitis Mean age = 30.9 years United States (Virginia) | Smokers | 17.0 | Analysis of covariance; covariates included age, race, gender, and mean plaque index score
Gunsolley et al. 1998 | Dental patients 142 nonsmokers and 51 smokers without periodontitis Mean age = 30.9 years United States (Virginia) | Nonsmokers | 9.9 | Analysis of covariance; covariates included age, race, gender, and mean plaque index score
Gunsolley et al. 1998 | Dental patients 142 nonsmokers and 51 smokers without periodontitis Mean age = 30.9 years United States (Virginia) | Teeth with ≥1 LPA site ≥5 mm (mean %) | | Analysis of covariance; covariates included age, race, gender, and mean plaque index score
Gunsolley et al. 1998 | Dental patients 142 nonsmokers and 51 smokers without periodontitis Mean age = 30.9 years United States (Virginia) | Smokers | 1.5 | Analysis of covariance; covariates included age, race, gender, and mean plaque index score
Gunsolley et al. 1998 | Dental patients 142 nonsmokers and 51 smokers without periodontitis Mean age = 30.9 years United States (Virginia) | Nonsmokers | 0.4 | Analysis of covariance; covariates included age, race, gender, and mean plaque index score
Norderyd and Hugoson 1998 | Population-based sample of 283 women and 269 men Aged 20–70 years Sweden | OR (95% CI) for severe generalized periodontitis by cigarettes/day | | Severe generalized periodontitis was defined as alveolar bone loss of one-third or more of the root length affecting the majority of teeth; this multiple logistic regression model included age, plaque index score, and the number of cigarettes smoked per day
Norderyd and Hugoson 1998 | Population-based sample of 283 women and 269 men Aged 20–70 years Sweden | 1–9 | 1.12 (0.19–6.62)
Norderyd and Hugoson 1998 | Population-based sample of 283 women and 269 men Aged 20–70 years Sweden | ≥10 | 11.84 (4.19–33.50)
Persson et al. 1998 | 416 dental patients Aged 15–94 years United States (Washington) | Smokers were more likely than nonsmokers to have severe vertical alveolar bone defects, and smokers had more vertical defects | | Alveolar bone defects were assessed radiographically; χ^2^ and ANOVA^‡‡^ test results were reported, but the prevalence or number of bone defects among smokers and nonsmokers was not reported
Shizukuishi et al. 1998 | 252 male and 58 female factory workers Aged 20–59 years Japan | OR (95% CI) for moderate or deep periodontal pockets | | Miller’s modified CPITNΔ was used to assess periodontal status; disease was defined as the upper 25% of the population distribution; this logistic model included age, gender, alcohol intake, frequency of tooth-brushing, and the use of the interdental cleaners; the reference group included former and never smokers
Shizukuishi et al. 1998 | 252 male and 58 female factory workers Aged 20–59 years Japan | Current smokers | 2.1 (1.2–3.8)
Kamma et al. 1999 | 40 male and 20 female dental patients with early onset periodontitis Aged 22–35 years Greece | Mean number (%) of periodontal sites with PPD^†^ >5 mm | | There was no control group
Kamma et al. 1999 | 40 male and 20 female dental patients with early onset periodontitis Aged 22–35 years Greece | Smokers | 76.3 (54.1) | There was no control group
Kamma et al. 1999 | 40 male and 20 female dental patients with early onset periodontitis Aged 22–35 years Greece | Nonsmokers | 57.5 (39.6) | There was no control group
Kamma et al. 1999 | 40 male and 20 female dental patients with early onset periodontitis Aged 22–35 years Greece | Mean PPD (mm) per diseased site | | There was no control group
Kamma et al. 1999 | 40 male and 20 female dental patients with early onset periodontitis Aged 22–35 years Greece | Smokers | 6.9 | There was no control group
Kamma et al. 1999 | 40 male and 20 female dental patients with early onset periodontitis Aged 22–35 years Greece | Nonsmokers | 5.9 | There was no control group
Kamma et al. 1999 | 40 male and 20 female dental patients with early onset periodontitis Aged 22–35 years Greece | Mean LPA^*^ (mm) per diseased site | | There was no control group
Kamma et al. 1999 | 40 male and 20 female dental patients with early onset periodontitis Aged 22–35 years Greece | Smokers | 7.6 | There was no control group
Kamma et al. 1999 | 40 male and 20 female dental patients with early onset periodontitis Aged 22–35 years Greece | Nonsmokers | 6.5 | There was no control group
Liede et al. 1999 | Random sample in 1992 and 1993 of 409 male participants in an ongoing cancer prevention trial who had ≥15 teeth and smoked ≥5 cigarettes/day at baseline (1985–1988) Aged 55–70 years Finland | Mean PPD | | Former smokers had quit for ≥6 months before the periodontal examination; gingival suppuration and the loss of alveolar bone remained significantly lower among former smokers than among current smokers in multiple logistic regression models
Liede et al. 1999 | Random sample in 1992 and 1993 of 409 male participants in an ongoing cancer prevention trial who had ≥15 teeth and smoked ≥5 cigarettes/day at baseline (1985–1988) Aged 55–70 years Finland | Current smokers | 0.76
Liede et al. 1999 | Random sample in 1992 and 1993 of 409 male participants in an ongoing cancer prevention trial who had ≥15 teeth and smoked ≥5 cigarettes/day at baseline (1985–1988) Aged 55–70 years Finland | Former smokers | 0.43
Liede et al. 1999 | Random sample in 1992 and 1993 of 409 male participants in an ongoing cancer prevention trial who had ≥15 teeth and smoked ≥5 cigarettes/day at baseline (1985–1988) Aged 55–70 years Finland | Sites (%) with gingival suppuration
Liede et al. 1999 | Random sample in 1992 and 1993 of 409 male participants in an ongoing cancer prevention trial who had ≥15 teeth and smoked ≥5 cigarettes/day at baseline (1985–1988) Aged 55–70 years Finland | Current smokers | 2.0
Liede et al. 1999 | Random sample in 1992 and 1993 of 409 male participants in an ongoing cancer prevention trial who had ≥15 teeth and smoked ≥5 cigarettes/day at baseline (1985–1988) Aged 55–70 years Finland | Former smokers | 0.4
Liede et al. 1999 | Random sample in 1992 and 1993 of 409 male participants in an ongoing cancer prevention trial who had ≥15 teeth and smoked ≥5 cigarettes/day at baseline (1985–1988) Aged 55–70 years Finland | Persons (%) with moderate or severe radiographic alveolar bone loss
Liede et al. 1999 | Random sample in 1992 and 1993 of 409 male participants in an ongoing cancer prevention trial who had ≥15 teeth and smoked ≥5 cigarettes/day at baseline (1985–1988) Aged 55–70 years Finland | Current smokers | 43
Liede et al. 1999 | Random sample in 1992 and 1993 of 409 male participants in an ongoing cancer prevention trial who had ≥15 teeth and smoked ≥5 cigarettes/day at baseline (1985–1988) Aged 55–70 years Finland | Former smokers | 28
Mullally et al. 1999 | 21 male and 50 female periodontal patients Aged <35 years; mean age = 28 years (minimum age not specified) Northern Ireland | Alveolar bone loss (mean %) | | The early onset of periodontitis was defined as persons with teeth (≥1) with ≥30% radio-graphic bone loss, aged <35 years, with no medical conditions or drug therapies known to affect periodontium; smoking was not significantly associated with the mean percent of bone loss in this ANOVA^‡‡^ model that included age and disease status (generalized vs. localized); there was no control group
Mullally et al. 1999 | 21 male and 50 female periodontal patients Aged <35 years; mean age = 28 years (minimum age not specified) Northern Ireland | Current smokers | 31.7
Mullally et al. 1999 | 21 male and 50 female periodontal patients Aged <35 years; mean age = 28 years (minimum age not specified) Northern Ireland | Never smoked | 25.0
Wakai et al. 1999 | 517 male and 113 female participants in a multiphasic health examination Aged 23–83 years Japan | Adjusted OR (95% CI) for “periodontal disease” by smoking status | | This ordinal logistic regression model with CPITNΔ scores as outcomes was adjusted for age, gender, fasting plasma glucose, and dental debris index; a dose-response relationship was highly significant
Wakai et al. 1999 | 517 male and 113 female participants in a multiphasic health examination Aged 23–83 years Japan | Current smokers (cigarettes/ day) | | This ordinal logistic regression model with CPITNΔ scores as outcomes was adjusted for age, gender, fasting plasma glucose, and dental debris index; a dose-response relationship was highly significant
Wakai et al. 1999 | 517 male and 113 female participants in a multiphasic health examination Aged 23–83 years Japan | 0–19 | 2.3 (1.2–4.3) | This ordinal logistic regression model with CPITNΔ scores as outcomes was adjusted for age, gender, fasting plasma glucose, and dental debris index; a dose-response relationship was highly significant
Wakai et al. 1999 | 517 male and 113 female participants in a multiphasic health examination Aged 23–83 years Japan | 20–39 | 3.3 (2.1–5.1) | This ordinal logistic regression model with CPITNΔ scores as outcomes was adjusted for age, gender, fasting plasma glucose, and dental debris index; a dose-response relationship was highly significant
Wakai et al. 1999 | 517 male and 113 female participants in a multiphasic health examination Aged 23–83 years Japan | ≥40 | 3.6 (2.0–6.7) | This ordinal logistic regression model with CPITNΔ scores as outcomes was adjusted for age, gender, fasting plasma glucose, and dental debris index; a dose-response relationship was highly significant
Wakai et al. 1999 | 517 male and 113 female participants in a multiphasic health examination Aged 23–83 years Japan | Former smokers | 1.4 (0.9–2.1) | This ordinal logistic regression model with CPITNΔ scores as outcomes was adjusted for age, gender, fasting plasma glucose, and dental debris index; a dose-response relationship was highly significant
Wakai et al. 1999 | 517 male and 113 female participants in a multiphasic health examination Aged 23–83 years Japan | Never smoked | 1.0 (referent) | This ordinal logistic regression model with CPITNΔ scores as outcomes was adjusted for age, gender, fasting plasma glucose, and dental debris index; a dose-response relationship was highly significant
Kerdvong-bundit and Wikesjö 2000 | 77 male and 43 female dental patients (60 current smokers and 60 never smokers) Aged 31–60 years Thailand | Mean PPD^†^ (mm) by smoking status | | Mandibular molars buccal sites only
Kerdvong-bundit and Wikesjö 2000 | 77 male and 43 female dental patients (60 current smokers and 60 never smokers) Aged 31–60 years Thailand | Current smokers | 5.1 | Mandibular molars buccal sites only
Kerdvong-bundit and Wikesjö 2000 | 77 male and 43 female dental patients (60 current smokers and 60 never smokers) Aged 31–60 years Thailand | Never smoked | 2.1 | Mandibular molars buccal sites only
Kerdvong-bundit and Wikesjö 2000 | 77 male and 43 female dental patients (60 current smokers and 60 never smokers) Aged 31–60 years Thailand | Mean LPA^*^ (mm) by smoking status | | Mandibular molars buccal sites only
Kerdvong-bundit and Wikesjö 2000 | 77 male and 43 female dental patients (60 current smokers and 60 never smokers) Aged 31–60 years Thailand | Current smokers | 4.8 | Mandibular molars buccal sites only
Kerdvong-bundit and Wikesjö 2000 | 77 male and 43 female dental patients (60 current smokers and 60 never smokers) Aged 31–60 years Thailand | Never smoked | 1.5 | Mandibular molars buccal sites only
Kerdvong-bundit and Wikesjö 2000 | 77 male and 43 female dental patients (60 current smokers and 60 never smokers) Aged 31–60 years Thailand | Persons (%) with PPD ≥4 mm by smoking status | | Mandibular molars buccal sites only
Kerdvong-bundit and Wikesjö 2000 | 77 male and 43 female dental patients (60 current smokers and 60 never smokers) Aged 31–60 years Thailand | Current smokers | 87 | Mandibular molars buccal sites only
Kerdvong-bundit and Wikesjö 2000 | 77 male and 43 female dental patients (60 current smokers and 60 never smokers) Aged 31–60 years Thailand | Never smoked | 20 | Mandibular molars buccal sites only
Kerdvong-bundit and Wikesjö 2000 | 77 male and 43 female dental patients (60 current smokers and 60 never smokers) Aged 31–60 years Thailand | Persons (%) with LPA ≥4 mm by smoking status | | Mandibular molars buccal sites only
Kerdvong-bundit and Wikesjö 2000 | 77 male and 43 female dental patients (60 current smokers and 60 never smokers) Aged 31–60 years Thailand | Current smokers | 77 | Mandibular molars buccal sites only
Kerdvong-bundit and Wikesjö 2000 | 77 male and 43 female dental patients (60 current smokers and 60 never smokers) Aged 31–60 years Thailand | Never smoked | 19 | Mandibular molars buccal sites only
Machuca et al. 2000 | 304 male military recruits Mean age 19 years Spain | Mean PPD (mm) by smoking status | | It is unclear if nonsmokers included former smokers
Machuca et al. 2000 | 304 male military recruits Mean age 19 years Spain | Current smokers | 1.68 | It is unclear if nonsmokers included former smokers
Machuca et al. 2000 | 304 male military recruits Mean age 19 years Spain | Nonsmokers | 1.56 | It is unclear if nonsmokers included former smokers
Machuca et al. 2000 | 304 male military recruits Mean age 19 years Spain | Mean LPA (mm) by smoking status and cigarettes/day | | It is unclear if nonsmokers included former smokers
Machuca et al. 2000 | 304 male military recruits Mean age 19 years Spain | Current smokers | 1.82 | It is unclear if nonsmokers included former smokers
Machuca et al. 2000 | 304 male military recruits Mean age 19 years Spain | <5 | 1.83 | It is unclear if nonsmokers included former smokers
Machuca et al. 2000 | 304 male military recruits Mean age 19 years Spain | 5–20 | 1.82 | It is unclear if nonsmokers included former smokers
Machuca et al. 2000 | 304 male military recruits Mean age 19 years Spain | >20 | 1.79 | It is unclear if nonsmokers included former smokers
Machuca et al. 2000 | 304 male military recruits Mean age 19 years Spain | Nonsmokers | 1.63 | It is unclear if nonsmokers included former smokers
Tomar and Asma 2000 | Population-based sample of 6,460 men and 7,190 women Aged ≥18 years United States | Adjusted OR for periodontitis and smoking | | Periodontitis was defined as 1 or more periodontal sites with both PPD^†^ ≥4 mm and LPA^*^ ≥4 mm; there were strong dose-response relationships for current smokers (cigarettes/day and duration) and former smokers (years since quitting)
Tomar and Asma 2000 | Population-based sample of 6,460 men and 7,190 women Aged ≥18 years United States | Current smokers
Tomar and Asma 2000 | Population-based sample of 6,460 men and 7,190 women Aged ≥18 years United States | (all) | 4.0 (3.2–4.9)
Tomar and Asma 2000 | Population-based sample of 6,460 men and 7,190 women Aged ≥18 years United States | Cigarettes/day
Tomar and Asma 2000 | Population-based sample of 6,460 men and 7,190 women Aged ≥18 years United States | ≤9 | 2.8 (1.9–4.1)
Tomar and Asma 2000 | Population-based sample of 6,460 men and 7,190 women Aged ≥18 years United States | 10–19 | 3.0 (2.1–4.1)
Tomar and Asma 2000 | Population-based sample of 6,460 men and 7,190 women Aged ≥18 years United States | 20 | 4.7 (3.5–6.4)
Tomar and Asma 2000 | Population-based sample of 6,460 men and 7,190 women Aged ≥18 years United States | 21–30 | 5.1 (3.5–7.5)
Tomar and Asma 2000 | Population-based sample of 6,460 men and 7,190 women Aged ≥18 years United States | ≥31 | 5.9 (4.0–8.6)
Tomar and Asma 2000 | Population-based sample of 6,460 men and 7,190 women Aged ≥18 years United States | Former smokers
Tomar and Asma 2000 | Population-based sample of 6,460 men and 7,190 women Aged ≥18 years United States | (all) | 1.7 (1.3–2.2)
Tomar and Asma 2000 | Population-based sample of 6,460 men and 7,190 women Aged ≥18 years United States | Years since quitting
Tomar and Asma 2000 | Population-based sample of 6,460 men and 7,190 women Aged ≥18 years United States | 0–2 | 3.2 (2.2–4.8)
Tomar and Asma 2000 | Population-based sample of 6,460 men and 7,190 women Aged ≥18 years United States | 3–5 | 2.3 (1.3–4.1)
Tomar and Asma 2000 | Population-based sample of 6,460 men and 7,190 women Aged ≥18 years United States | 6–10 | 2.0 (1.2–3.2)
Tomar and Asma 2000 | Population-based sample of 6,460 men and 7,190 women Aged ≥18 years United States | ≥11 | 1.2 (0.8–1.6)
Tomar and Asma 2000 | Population-based sample of 6,460 men and 7,190 women Aged ≥18 years United States | Never smoked | 1.0 (referent)

Note: Unless otherwise defined, current, former, and never refer to smoking status.

* LPA = Loss of periodontal attachment.

† PPD = Probing pocket depth.

‡ OR = Odds ratio.

§ CI = Confidence interval.

Δ CPITN = Community Periodontal Index of Treatment Needs.

¶ HMO = Health maintenance organization.

** Pack-years = The number of years of smoking multiplied by the number of packs of cigarettes smoked per day.

†† GR = Gingival recession.

‡‡ ANOVA = Analysis of variance.

§§ HIV = Human immunodeficiency virus.

ΔΔ AZT = Azidothymidine or zidovudine, a medication used to treat HIV infections.

¶¶ NR = Data were not reported.

** *Age was retained in the model because of its interaction with current smokers.

Table 6.23 Cohort studies on the association between smoking and periodontitis

Study | Population | Follow-up(years) | Outcome | Findings
Bolin et al. 1986 | 170 men and179 women Aged 18–65 years at baseline Sweden | 10 | Loss of interproximal alveolar bone | Mean bone loss (% of root length) by baseline smoking status and cigarettes smoked/day, standardized for plaque level
Bolin et al. 1986 | 170 men and179 women Aged 18–65 years at baseline Sweden | 10 | Loss of interproximal alveolar bone | Current
Bolin et al. 1986 | 170 men and179 women Aged 18–65 years at baseline Sweden | 10 | Loss of interproximal alveolar bone | 1–9 cigarettes/day | 5.1
Bolin et al. 1986 | 170 men and179 women Aged 18–65 years at baseline Sweden | 10 | Loss of interproximal alveolar bone | 10–20 cigarettes/day | 5.5
Bolin et al. 1986 | 170 men and179 women Aged 18–65 years at baseline Sweden | 10 | Loss of interproximal alveolar bone | >20 cigarettes/day | 5.6
Bolin et al. 1986 | 170 men and179 women Aged 18–65 years at baseline Sweden | 10 | Loss of interproximal alveolar bone | Nonsmokers | 4.0
Bolin et al. 1986 | 170 men and179 women Aged 18–65 years at baseline Sweden | 10 | Loss of interproximal alveolar bone | Unclear if nonsmokers included former smokers
Feldman et al. 1987 | 483 men from the Veterans Administration Normative Aging Study United States(Boston) | 6 | 6-year change in mean PPD^*^, tooth mobility, and radiographic alveolar bone loss | Mean change in PPD by baseline smoking status
Feldman et al. 1987 | 483 men from the Veterans Administration Normative Aging Study United States(Boston) | 6 | 6-year change in mean PPD^*^, tooth mobility, and radiographic alveolar bone loss | Smokers | 0.167
Feldman et al. 1987 | 483 men from the Veterans Administration Normative Aging Study United States(Boston) | 6 | 6-year change in mean PPD^*^, tooth mobility, and radiographic alveolar bone loss | Nonsmokers | −0.079
Feldman et al. 1987 | 483 men from the Veterans Administration Normative Aging Study United States(Boston) | 6 | 6-year change in mean PPD^*^, tooth mobility, and radiographic alveolar bone loss | Mean change in tooth mobility
Feldman et al. 1987 | 483 men from the Veterans Administration Normative Aging Study United States(Boston) | 6 | 6-year change in mean PPD^*^, tooth mobility, and radiographic alveolar bone loss | Smokers | 0.360
Feldman et al. 1987 | 483 men from the Veterans Administration Normative Aging Study United States(Boston) | 6 | 6-year change in mean PPD^*^, tooth mobility, and radiographic alveolar bone loss | Nonsmokers | 0.253
Feldman et al. 1987 | 483 men from the Veterans Administration Normative Aging Study United States(Boston) | 6 | 6-year change in mean PPD^*^, tooth mobility, and radiographic alveolar bone loss | Mean change in alveolar bone level
Feldman et al. 1987 | 483 men from the Veterans Administration Normative Aging Study United States(Boston) | 6 | 6-year change in mean PPD^*^, tooth mobility, and radiographic alveolar bone loss | Smokers | 0.287
Feldman et al. 1987 | 483 men from the Veterans Administration Normative Aging Study United States(Boston) | 6 | 6-year change in mean PPD^*^, tooth mobility, and radiographic alveolar bone loss | Nonsmokers | 0.172
Ismail et al. 1990 | 167 adults Aged 5–60 years at baseline United States(Michigan) | 28 | Change in mean LPA^†^ ≥2 mm | OR^‡^ = 14.2 (95% CI^§^, 4.1–48.7) for smoking (assessed at baseline); this multiple logistic regression model also included year of birth and amount of tooth mobility
Bolin et al. 1993 | 170 men and179 women Aged 18–65 years at baseline Sweden | 10 | Loss of interproximal alveolar bone | Mean bone loss (% of bone height/root length) by baseline and follow- up smoking status and by baseline cigarettes/day
Bolin et al. 1993 | 170 men and179 women Aged 18–65 years at baseline Sweden | 10 | Loss of interproximal alveolar bone | Smokers | 6.0
Bolin et al. 1993 | 170 men and179 women Aged 18–65 years at baseline Sweden | 10 | Loss of interproximal alveolar bone | 1–9 cigarettes/day | 5.2
Bolin et al. 1993 | 170 men and179 women Aged 18–65 years at baseline Sweden | 10 | Loss of interproximal alveolar bone | 10–20 cigarettes/day | 6.0
Bolin et al. 1993 | 170 men and179 women Aged 18–65 years at baseline Sweden | 10 | Loss of interproximal alveolar bone | >20 cigarettes/day | 6.3
Bolin et al. 1993 | 170 men and179 women Aged 18–65 years at baseline Sweden | 10 | Loss of interproximal alveolar bone | Former smokers(stopped smoking during the 10-year period) | 4.4
Bolin et al. 1993 | 170 men and179 women Aged 18–65 years at baseline Sweden | 10 | Loss of interproximal alveolar bone | Nonsmokers | 3.9
Brown et al. 1994 | 611 community- dwelling persons Aged ≥65 years at baseline United States(North Carolina) | 1.5 | 2 or more sites with incident LPA^†^≥3 mm | OR = 3.4 (95% CI, 1.6–7.5) among white adults who smoked cigarettes regularly; this logistic regression model included levels of Porphyromonas gingivalis, most recent medical care, and feelings of depression
McGuire and Nunn 1996 | 100 treated periodontal patients Aged 22–71 years at baseline United States(Texas) | 5 | 5-category clinical prognosis score | OR = 1.9 (95% CI, 1.2–3.1) for smoking and a worsening prognosis
Beck et al. 1997 | 540 persons Aged ≥65 years at baseline United States(North Carolina) | 5 | At least 1 periodontal site with LPA ≥3 mm | RRΔ = 1.6 (95% CI, 1.2–2.0); analysiswas conducted at the level of theperiodontal site; referent groupincluded both never and former smokers; this logistic regression model also included Porphyromonas gingivalis status, number of missing teeth, tooth type, periodontal site type, educational attainment, and most recent dental visit
Machtei et al. 1997 | 44 women and35 men with established periodontitis Aged 25–66 years at baseline United States(New York) | 1 | Increased periodontal breakdown(mean bone loss exceeding 2 standard deviations based on radiographic examination) | OR = 5.41 (95% CI, 1.50–19.5) for smoking and increased periodontal breakdown
Machtei et al. 1997 | 44 women and35 men with established periodontitis Aged 25–66 years at baseline United States(New York) | 1 | Increased periodontal breakdown(mean bone loss exceeding 2 standard deviations based on radiographic examination) | Sites that experienced loss of clinical attachment (mean %)
Machtei et al. 1997 | 44 women and35 men with established periodontitis Aged 25–66 years at baseline United States(New York) | 1 | Increased periodontal breakdown(mean bone loss exceeding 2 standard deviations based on radiographic examination) | Smokers | 8.35
Machtei et al. 1997 | 44 women and35 men with established periodontitis Aged 25–66 years at baseline United States(New York) | 1 | Increased periodontal breakdown(mean bone loss exceeding 2 standard deviations based on radiographic examination) | Nonsmokers | 6.00
Machtei et al. 1997 | 44 women and35 men with established periodontitis Aged 25–66 years at baseline United States(New York) | 1 | Increased periodontal breakdown(mean bone loss exceeding 2 standard deviations based on radiographic examination) | Mean clinical attachment loss (mm)
Machtei et al. 1997 | 44 women and35 men with established periodontitis Aged 25–66 years at baseline United States(New York) | 1 | Increased periodontal breakdown(mean bone loss exceeding 2 standard deviations based on radiographic examination) | Smokers | 0.27
Machtei et al. 1997 | 44 women and35 men with established periodontitis Aged 25–66 years at baseline United States(New York) | 1 | Increased periodontal breakdown(mean bone loss exceeding 2 standard deviations based on radiographic examination) | Nonsmokers | 0.09
Machtei et al. 1997 | 44 women and35 men with established periodontitis Aged 25–66 years at baseline United States(New York) | 1 | Increased periodontal breakdown(mean bone loss exceeding 2 standard deviations based on radiographic examination) | Mean bone height loss (mm)
Machtei et al. 1997 | 44 women and35 men with established periodontitis Aged 25–66 years at baseline United States(New York) | 1 | Increased periodontal breakdown(mean bone loss exceeding 2 standard deviations based on radiographic examination) | Smokers | 0.24
Machtei et al. 1997 | 44 women and35 men with established periodontitis Aged 25–66 years at baseline United States(New York) | 1 | Increased periodontal breakdown(mean bone loss exceeding 2 standard deviations based on radiographic examination) | Nonsmokers | 0.12
Machtei et al. 1997 | 44 women and35 men with established periodontitis Aged 25–66 years at baseline United States(New York) | 1 | Increased periodontal breakdown(mean bone loss exceeding 2 standard deviations based on radiographic examination) | Sites with bone height loss (mean %)
Machtei et al. 1997 | 44 women and35 men with established periodontitis Aged 25–66 years at baseline United States(New York) | 1 | Increased periodontal breakdown(mean bone loss exceeding 2 standard deviations based on radiographic examination) | Smokers | 15.4
Machtei et al. 1997 | 44 women and35 men with established periodontitis Aged 25–66 years at baseline United States(New York) | 1 | Increased periodontal breakdown(mean bone loss exceeding 2 standard deviations based on radiographic examination) | Nonsmokers | 11.4
Elter et al. 1999 | 697 community- dwelling persons Aged ≥65 years at baseline United States(North Carolina) | 7 | At least 1 site with incident LPA^†^≥3 mm | RR = 1.4 (95% CI, 1.1–1.7) among whites and 1.9 (95% CI, 1.6–2.2) among blacks for current smoking; multivariable Poisson regression models included a number of site- level and person-level variables
Machtei et al. 1999 | 415 persons with little or no periodontal disease Aged 25–75 years at baseline United States(New York) | 2–5 | Mean LPA ≥1.95 mm | Mean annual LPA (mm)
Machtei et al. 1999 | 415 persons with little or no periodontal disease Aged 25–75 years at baseline United States(New York) | 2–5 | Mean LPA ≥1.95 mm | Smokers | 0.19
Machtei et al. 1999 | 415 persons with little or no periodontal disease Aged 25–75 years at baseline United States(New York) | 2–5 | Mean LPA ≥1.95 mm | Nonsmokers | 0.10
Machtei et al. 1999 | 415 persons with little or no periodontal disease Aged 25–75 years at baseline United States(New York) | 2–5 | Mean LPA ≥1.95 mm | Sites experiencing LPA (mean %)
Machtei et al. 1999 | 415 persons with little or no periodontal disease Aged 25–75 years at baseline United States(New York) | 2–5 | Mean LPA ≥1.95 mm | Smokers | 5.28
Machtei et al. 1999 | 415 persons with little or no periodontal disease Aged 25–75 years at baseline United States(New York) | 2–5 | Mean LPA ≥1.95 mm | Nonsmokers | 3.75
Machtei et al. 1999 | 415 persons with little or no periodontal disease Aged 25–75 years at baseline United States(New York) | 2–5 | Mean LPA ≥1.95 mm | Smoking also was a strong predictor of annual changes in PPD^*^ in multiple linear regression models
Norderyd et al. 1999 | Population-based sample of 357 persons Aged 20, 30, 40, 50, and 60 years at baseline Sweden | 17 | 6 or more sites with radiographic alveolar bone loss>20% | OR = 12.0 (95% CI, 4.5–32.1) for smoking and bone loss
Faddy et al. 2000 | 456 university staff members Aged 18–65 years Australia | 3 | 4 or more sites with PPD ≥4 mm | Current smokers had a 28% higher rate of disease regression than non- smokers of the same age and gender; used Markov chain models to model transition probabilities of changes in disease state

* PPD = Probing pocket depth, measured in millimeters.

† LPA = Loss of periodontal attachment.

‡ OR = Odds ratio.

§ CI = Confidence interval.

Δ RR = Relative risk.

Nearly all other reviewed studies reported either mean measures of PPD or CAL/LPA or radiographically demonstrated alveolar bone loss by smoking status, or they reported the percentage of persons with some specified number or percentage of sites exceeding some threshold on one or more of these clinical parameters. With only one exception (Preber et al. 1980), all cross-sectional and cohort studies that measured differences in mean CAL/LPA or mean PPD found a worse periodontal status among smokers than among nonsmokers. That 1980 study (Preber et al. 1980), however, was conducted with young military recruits whose duration of smoking must have been relatively short because of their age.

#### Evidence Synthesis

The available epidemiologic literature is highly consistent in showing a moderate to strong association between cigarette smoking and periodontal destruction. The association is robust across a wide range of case definitions, populations, and study designs. There is also evidence of a dose-response relationship between smoking intensity and risk for periodontitis. Both number of cigarettes smoked and duration of smoking are positively associated with disease risk. The risk of periodontitis appears to decrease after smokers stop smoking, with a decreasing risk as the duration of successful cessation increases. Although only a few prospective cohort studies have been carried out, they consistently found that smokers were more likely than nonsmokers to experience the onset or progression of disease. The association cannot be explained by confounding.

The mechanisms involved in smoking-associated periodontal destruction are still not fully understood. However, available evidence supports several hypotheses. An immune mechanism is plausible because smoking affects many elements of the human immune system. The effects of smoking on local and systemic immune factors may make the smoker more susceptible to bacterial infection. In addition, substantial evidence indicates that smoking impairs the regeneration and repair of periodontal tissues. The evidence is inconsistent in suggesting that smoking quantitatively or qualitatively alters the microflora of subgingival plaque.

#### Conclusion

1. The evidence is sufficient to infer a causal relationship between smoking and periodontitis.

#### Implications

Smoking intervention should be a major component of prevention and treatment of periodontitis. A recent study (Tomar and Asma 2000) concluded that more than 50 percent of the cases of adult periodontitis in the United States are attributable to cigarette smoking. In light of this conclusion, and because more than one-half of U.S. adult smokers visit a dentist each year (Tomar et al. 1996), the dental care community has both the opportunity and the professional obligation to counsel patients who smoke to quit. The dental office may also provide an opportune setting for tobacco use prevention efforts among young people (Hovell et al. 1996). Unfortunately, a lack of awareness and inadequate skills may be barriers to further involvement by dentists and dental hygienists (Secker-Walker et al. 1994; Dolan et al. 1997b).

Further research is needed to achieve a greater understanding of the mechanisms involved in smoking-associated periodontitis. In addition, more behavioral research is needed to enhance the willingness and ability of dentists and dental hygienists to intervene in their patients’ use of tobacco and to counsel younger patients against tobacco use. Educational research should identify effective methods for training students of dentistry and dental hygiene, as well as licensed clinicians, to become competent at counseling their patients to stop using tobacco and assisting patients who want to quit (Tomar et al. 1996; Barker and Williams 1999; Cabana et al. 1999).

### Dental Caries

Dental caries is an infectious, communicable, multifactorial disease in which bacterially produced acids dissolve the hard enamel surface of a tooth (Featherstone 1999). Unchecked, the bacteria may then penetrate the underlying dentin and progress into the soft pulp tissue, which is rich in blood and nerve tissue. Dental caries commonly results in loss of tooth structure and discomfort. Untreated dental caries commonly progresses to incapacitating pain and a bacterial infection that leads to pulpal necrosis, tooth extraction, and loss of dental function, and can progress to an acute systemic infection. The major etiologic factors for this disease are thought to be specific bacteria in dental plaque (particularly Streptococcus [S.] mutans and S. lactobacilli) on susceptible tooth surfaces and the availability of fermentable carbohydrates.

Most epidemiologic studies conducted during the past 60 years have used some variation of the decayed, missing (due to caries), or filled permanent teeth (DMFT) index (Klein et al. 1938) to measure the frequency of dental caries. Until the mid-1980s the proportion of the population with dental caries was rarely used to estimate disease prevalence in industrialized populations because the disease was nearly universal. The DMFT index is more a measure of disease severity than of disease prevalence; it is simply the sum of the number of permanent teeth (T) that are decayed (D), missing due to dental caries (M), or filled (F). This index, if applied to the number of coronal (i.e., enamel-covered) tooth surfaces (S), is designated the DMFS. The M component is often omitted in adult studies because of the inherent uncertainty as to why a tooth is missing. Thus, some studies report DFT or DFS scores. Other studies report the components of DMFT individually, such as DS, FS, and MS. Nearly all studies aggregate DMF data by reporting the population mean. The number of root surfaces affected by caries is almost always scored and reported separately from coronal caries, and usually is designated as RDFS or RDS (the M component is not reported for root-surface caries).

#### Biologic Basis

There are several hypothesized mechanisms that may underlie the association between smoking and dental caries. As discussed in the section on smoking and periodontitis, evidence is inconsistent in showing that smoking per se alters either the bacterial profile in the gingivi or the rate of formation of dental plaque (Alexander 1970; Swenson 1979; Bergström 1981, 1990; Feldman et al. 1983; Macgregor et al. 1985; Bergström and Eliasson 1987a,b; Lie et al. 1998). Differences in oral care behavior between smokers and nonsmokers provide an indirect explanation. Perhaps the most consistent explanation is that smokers tend to practice less frequent or less effective oral hygiene and plaque removal (Preber and Kant 1973; Macgregor and Rugg-Gunn 1986; Andrews et al. 1998).

Several studies concluded that smoking might lower the pH or reduce the buffering capacity of saliva (Heintze 1984; Parvinen 1984), impairing the function of saliva as a protective factor against enamel demineralization (Edgar and Higham 1996). In contrast, one review concluded that smoking increases salivary flow rate (Macgregor 1989), raising pH and increasing salivary calcium concentration (ten Cate 1996). These factors would tend to favor enamel remineralization, but benefit would come only if the flow rate increase were sustained. Another comprehensive review concluded that smoking has a minor effect on saliva flow rate and its chemical composition, at least in terms of factors thought to affect dental cariogenesis (Christen et al. 1991). In sum, an effect of smoking on salivary function does not appear to be a key mechanism in causing dental caries.

The association between smoking and root-surface caries suggested by several studies may be due, in part, to the periodontal effects of smoking. The loss of periodontal attachment and subsequent exposure of root surfaces are necessary conditions for root-surface caries to occur (Burt et al. 1986; Stamm et al. 1990). Persons who experience a loss of periodontal attachment attributable to smoking may also be at greater risk for subsequent root-surface caries.

#### Epidemiologic Evidence

To identify the epidemiologic studies on smoking and dental caries, the National Library of Medicine’s PubMed database was searched for English language publications from 1965–2000. The following MeSH key words were used: “smoking,” “tobacco,” “dental caries,” and “tooth demineralization.” These terms also were searched as title words. The smoking and health database maintained by CDC’s Office on Smoking and Health was also searched using the same terms as key words. Reference lists from published studies, review articles, and textbooks were sources for additional studies.

Table 6.24 summarizes 12 cross-sectional studies and 3 cohort studies published between 1952 and 1999. Most cross-sectional studies used some variation of the DMF index to measure caries prevalence; all but two (Hart et al. 1995; Tomar and Winn 1999) found that smokers experienced more coronal dental caries than nonsmokers, as measured by mean DS, DFS, DMFS, or DMFT. In general, differences between smokers and nonsmokers in mean DMFT or DMFS were small, even in studies in which the differences were reported to be “statistically significant.” The largest differences in numbers of carious lesions were reported in studies that used DMFS (Ludwick and Massler 1952; Ainamo 1971; Zitterbart et al. 1990; Axelsson et al. 1998). None of those studies, however, appeared to limit the “missing” component of DMFS to those tooth surfaces lost due to caries. Consequently, these studies may mix caries caused by smoking with the advanced periodontal destruction that can cause tooth loss in adults.

Table 6.24 Cross-sectional and cohort studies on the association between smoking and dental caries

Study | Population | Design | Results
Ludwick and Massler 1952 | 2,577 male navy enlistees Aged 17–21 years United States | Cross-sectional | Mean DMFS^*^ by mean number of cigarettes/day
Ludwick and Massler 1952 | 2,577 male navy enlistees Aged 17–21 years United States | Cross-sectional | Cigarettes/day | | DMFT^†^ | DMFS
Ludwick and Massler 1952 | 2,577 male navy enlistees Aged 17–21 years United States | Cross-sectional | 0 | | 9.5 | 20.4
Ludwick and Massler 1952 | 2,577 male navy enlistees Aged 17–21 years United States | Cross-sectional | 5 | | 9.1 | 20.5
Ludwick and Massler 1952 | 2,577 male navy enlistees Aged 17–21 years United States | Cross-sectional | 10 | | 9.8 | 21.7
Ludwick and Massler 1952 | 2,577 male navy enlistees Aged 17–21 years United States | Cross-sectional | 15 | | 9.75 | 21.2
Ludwick and Massler 1952 | 2,577 male navy enlistees Aged 17–21 years United States | Cross-sectional | ≥20 | | 10.2 | 23.0
Ludwick and Massler 1952 | 2,577 male navy enlistees Aged 17–21 years United States | Cross-sectional | A statistically significant difference was reported in DMFT and DMFS means between those smoking ≤5 cigarettes/day and those smoking ≥15 cigarettes/day
Ainamo 1971 | 167 army recruits Aged 18–26 years Finland | Cross-sectional | Mean DS^‡^ and DMFS by cigarettes/day
Ainamo 1971 | 167 army recruits Aged 18–26 years Finland | Cross-sectional | Cigarettes/day | | DS | DMFS
Ainamo 1971 | 167 army recruits Aged 18–26 years Finland | Cross-sectional | 0 | | 13.8 | 36.4
Ainamo 1971 | 167 army recruits Aged 18–26 years Finland | Cross-sectional | 1–9 | | 20.7 | 51.7
Ainamo 1971 | 167 army recruits Aged 18–26 years Finland | Cross-sectional | 10–20 | | 19.9 | 41.5
Ainamo 1971 | 167 army recruits Aged 18–26 years Finland | Cross-sectional | >20 | | 23.3 | 58.5
Ainamo 1971 | 167 army recruits Aged 18–26 years Finland | Cross-sectional | F-test | | p <0.05 | p <0.01
Modéer et al. 1980 | 232 schoolchildren Aged 13–14 years Sweden | Cross-sectional | The number of cigarettes/day was a significant correlate of the number of decayed tooth surfaces (β = 0.311; p <0.01) and filled tooth surfaces (β = 0.309; p <0.05) in this stepwise multiple linear regression(R^2^§ = 0.22)
Zitterbart et al. 1990 | 95 male dental patients Aged 18–52 years(34 current smokers and 61 never smokers) United States(Illinois) | Cross-sectional | Mean DS and DMFS by smoking status
Zitterbart et al. 1990 | 95 male dental patients Aged 18–52 years(34 current smokers and 61 never smokers) United States(Illinois) | Cross-sectional | | | DS | DMFS
Zitterbart et al. 1990 | 95 male dental patients Aged 18–52 years(34 current smokers and 61 never smokers) United States(Illinois) | Cross-sectional | Current smokers | | 3.9 | 24.6
Zitterbart et al. 1990 | 95 male dental patients Aged 18–52 years(34 current smokers and 61 never smokers) United States(Illinois) | Cross-sectional | Never smoked | | 2.4 | 19.4
Zitterbart et al. 1990 | 95 male dental patients Aged 18–52 years(34 current smokers and 61 never smokers) United States(Illinois) | Cross-sectional | In analysis of variance modeling, smokingwas significantly associated with the numberof untreated decayed tooth surfaces and thenumber of missing surfaces; dose-response relationships were seen between daily cigarette use and both MSΔ and DMFS; it is unclear if missing tooth surfaces were limited to those lost due to dental caries
Hirsch et al. 1991 | 1,122 male and 1,023 female dental patients Aged 14–19 years Sweden | Cross-sectional | Mean DMFT^†^ by smoking status (but not adjusted for age)
Hirsch et al. 1991 | 1,122 male and 1,023 female dental patients Aged 14–19 years Sweden | Cross-sectional | Smokers | 9.0
Hirsch et al. 1991 | 1,122 male and 1,023 female dental patients Aged 14–19 years Sweden | Cross-sectional | Nonsmokers | 7.0
Hirsch et al. 1991 | 1,122 male and 1,023 female dental patients Aged 14–19 years Sweden | Cross-sectional | The text suggests that smoking was significantly associated with DMFT across age groups, but data were not presented
Källestål 1991 | Population-based sample283 persons aged 16 years and 287 persons aged 18 years Sweden | Cross-sectional | Among persons aged 18 years, smokers had more DFS^¶^ than nonsmokers (p <0.05), but data were not presented
Locker 1992 | Population-based sample 907 persons Aged ≥50 years Canada (Ontario) | Cross-sectional | Mean DS^‡^, FS^**^, and RDS^††^ by smoking status
Locker 1992 | Population-based sample 907 persons Aged ≥50 years Canada (Ontario) | Cross-sectional | | DS | FS | RDS
Locker 1992 | Population-based sample 907 persons Aged ≥50 years Canada (Ontario) | Cross-sectional | Current smokers | 1.2 | 18.7 | 1.2
Locker 1992 | Population-based sample 907 persons Aged ≥50 years Canada (Ontario) | Cross-sectional | Former smokers | 0.8 | 22.1 | 0.6
Locker 1992 | Population-based sample 907 persons Aged ≥50 years Canada (Ontario) | Cross-sectional | Never smoked | 0.7 | 25.6 | 0.6
Jette et al. 1993 | Population-based sample of community-dwelling persons Aged 70–96 years United States(New England) | Cross-sectional | Current smokers were significantly more likely than never smokers to have current coronal or root surface decay; prevalence of current decay was not specified
Ravald et al. 1993 | 27 periodontal patients Aged 47–79 years Sweden | Cohort, 12-year follow-up | Compared with nonsmokers, smokers experienced higher median (8 vs. 1) and mean(14 vs. 7) numbers of new RDS following periodontal treatments
Thomas et al. 1994 | Population-based sample300 persons Aged ≥60 years India | Cross-sectional | Mean decayed or missing teeth, by smoking status
Thomas et al. 1994 | Population-based sample300 persons Aged ≥60 years India | Cross-sectional | Smokers | 16.8
Thomas et al. 1994 | Population-based sample300 persons Aged ≥60 years India | Cross-sectional | Nonsmokers | 13.0
Hart et al. 1995 | Convenience sample 200 dental patients Aged 14–88 years United States(Tennessee) | Cross-sectional | No significant difference in mean DMFT between smokers (23.9) and nonsmokers(21.2); not age-adjusted; unclear if missing teeth included only those missing due to dental caries
Locker 1996 | Population-based sample493 persons (of 699 in the baseline survey) Aged ≥50 years at baseline Canada (Ontario) | Cohort, 3-year follow-up | Mean RDFS^‡‡^ and RDS^††^ increments by smoking status
Locker 1996 | Population-based sample493 persons (of 699 in the baseline survey) Aged ≥50 years at baseline Canada (Ontario) | Cohort, 3-year follow-up | | | RDFS | RDS
Locker 1996 | Population-based sample493 persons (of 699 in the baseline survey) Aged ≥50 years at baseline Canada (Ontario) | Cohort, 3-year follow-up | Current or former smokers | | 0.75 | 0.36
Locker 1996 | Population-based sample493 persons (of 699 in the baseline survey) Aged ≥50 years at baseline Canada (Ontario) | Cohort, 3-year follow-up | Never smoked | | 0.47 | 0.24
Locker 1996 | Population-based sample493 persons (of 699 in the baseline survey) Aged ≥50 years at baseline Canada (Ontario) | Cohort, 3-year follow-up | Persons (%) experiencing RDFS or RDS increments (≥1) by smoking status (RDS differences were not statistically significant)
Locker 1996 | Population-based sample493 persons (of 699 in the baseline survey) Aged ≥50 years at baseline Canada (Ontario) | Cohort, 3-year follow-up | | | RDFS | RDS
Locker 1996 | Population-based sample493 persons (of 699 in the baseline survey) Aged ≥50 years at baseline Canada (Ontario) | Cohort, 3-year follow-up | Current or former smokers | | 31.6 | 19.0
Locker 1996 | Population-based sample493 persons (of 699 in the baseline survey) Aged ≥50 years at baseline Canada (Ontario) | Cohort, 3-year follow-up | Never smoked | | 24.0 | 12.7
Locker 1996 | Population-based sample493 persons (of 699 in the baseline survey) Aged ≥50 years at baseline Canada (Ontario) | Cohort, 3-year follow-up | Smoking was not a significant predictor of RDFS or RDS increments in this multiple logistic model
Drake et al. 1997 | Noninstitutionalized population-based sample234 blacks, 218 whites Aged ≥65 years United States(North Carolina) | Cohort, 3-year follow-up | Blacks who smoked cigarettes or cigars were more likely than black nonsmokers to experience new DFS^¶^ (odds ratio = 2.5[95% confidence interval, 1.1–5.3]) in this stepwise logistic regression model; smoking was not significant among whites
Axelsson et al. 1998 | Population-based sample Aged 35 years (n = 155) Aged 50 years (n = 510) Aged 65 years (n = 310) Aged 75 years (n = 310) Sweden | Cross-sectional | Mean DMFS^*^ by age and smoking status
Axelsson et al. 1998 | Population-based sample Aged 35 years (n = 155) Aged 50 years (n = 510) Aged 65 years (n = 310) Aged 75 years (n = 310) Sweden | Cross-sectional | Aged 35 years
Axelsson et al. 1998 | Population-based sample Aged 35 years (n = 155) Aged 50 years (n = 510) Aged 65 years (n = 310) Aged 75 years (n = 310) Sweden | Cross-sectional | Current smokers | 48.9
Axelsson et al. 1998 | Population-based sample Aged 35 years (n = 155) Aged 50 years (n = 510) Aged 65 years (n = 310) Aged 75 years (n = 310) Sweden | Cross-sectional | Never smoked | 38.1
Axelsson et al. 1998 | Population-based sample Aged 35 years (n = 155) Aged 50 years (n = 510) Aged 65 years (n = 310) Aged 75 years (n = 310) Sweden | Cross-sectional | Aged 50 years
Axelsson et al. 1998 | Population-based sample Aged 35 years (n = 155) Aged 50 years (n = 510) Aged 65 years (n = 310) Aged 75 years (n = 310) Sweden | Cross-sectional | Current smokers | 84.4
Axelsson et al. 1998 | Population-based sample Aged 35 years (n = 155) Aged 50 years (n = 510) Aged 65 years (n = 310) Aged 75 years (n = 310) Sweden | Cross-sectional | Never smoked | 76.7
Axelsson et al. 1998 | Population-based sample Aged 35 years (n = 155) Aged 50 years (n = 510) Aged 65 years (n = 310) Aged 75 years (n = 310) Sweden | Cross-sectional | Aged 65 years
Axelsson et al. 1998 | Population-based sample Aged 35 years (n = 155) Aged 50 years (n = 510) Aged 65 years (n = 310) Aged 75 years (n = 310) Sweden | Cross-sectional | Current smokers | 98.8 (not significant)
Axelsson et al. 1998 | Population-based sample Aged 35 years (n = 155) Aged 50 years (n = 510) Aged 65 years (n = 310) Aged 75 years (n = 310) Sweden | Cross-sectional | Never smoked | 93.0
Axelsson et al. 1998 | Population-based sample Aged 35 years (n = 155) Aged 50 years (n = 510) Aged 65 years (n = 310) Aged 75 years (n = 310) Sweden | Cross-sectional | Aged 75 years
Axelsson et al. 1998 | Population-based sample Aged 35 years (n = 155) Aged 50 years (n = 510) Aged 65 years (n = 310) Aged 75 years (n = 310) Sweden | Cross-sectional | Current smokers | 114.6
Axelsson et al. 1998 | Population-based sample Aged 35 years (n = 155) Aged 50 years (n = 510) Aged 65 years (n = 310) Aged 75 years (n = 310) Sweden | Cross-sectional | Never smoked | 100.2
Axelsson et al. 1998 | Population-based sample Aged 35 years (n = 155) Aged 50 years (n = 510) Aged 65 years (n = 310) Aged 75 years (n = 310) Sweden | Cross-sectional | Largest difference at ages 50, 65, and 75 years was in the number of MSΔ; at 35 years, smokers had a higher mean DFS than never smokers (39.3 vs. 31.2); MS were not limited to those missing teeth due to caries
Tomar and Winn 1999 | Population-based sample6,945 dentate men Aged ≥18 years United States | Cross-sectional | Mean DFT^§§^, DFS^¶^, and RDFS^‡‡^ by smoking status, adjusted for age, race, and ethnicity
Tomar and Winn 1999 | Population-based sample6,945 dentate men Aged ≥18 years United States | Cross-sectional | | DFT | DFS | RDFS
Tomar and Winn 1999 | Population-based sample6,945 dentate men Aged ≥18 years United States | Cross-sectional | Current smokers | 6.3 | 16.0 | 2.3
Tomar and Winn 1999 | Population-based sample6,945 dentate men Aged ≥18 years United States | Cross-sectional | Never smoked | 7.0 | 17.4 | 1.1
Tomar and Winn 1999 | Population-based sample6,945 dentate men Aged ≥18 years United States | Cross-sectional | DFT and DFS differences were not statistically significant; current smokers were not significantly more likely than men who had never used tobacco to have ≥1 RDFS in multiple logistic regression models

* DMFS = Decayed, missing (due to caries), or filled coronal permanent tooth surfaces.

† DMFT = Decayed, missing (due to caries), or filled permanent teeth.

‡ DS = Decayed coronal permanent tooth surfaces.

§ R^2^ = Prediction values.

Δ MS = Missing tooth surfaces.

¶ DFS = Decayed or filled coronal permanent tooth surfaces.

** FS = Filled coronal permanent tooth surfaces.

†† RDS = Decayed root surfaces.

‡‡ RDFS = Decayed or filled root surfaces.

§§ DFT = Decayed or filled permanent teeth.

Few of the studies on the association between smoking and dental caries controlled for potential confounding factors. Although the observed association between smoking and dental caries may reflect a causal relationship, it is also possible that it reflects factors common to both smoking and the risk of dental caries. For example, in industrialized nations both dental caries (USDHHS 2000) and cigarette smoking (Giovino et al. 1995) are more prevalent among groups with lower socioeconomic status (SES) than among higher SES groups. SES is a strong correlate of factors that affect dental caries status, such as diet, use of dental services, and oral hygiene practices (USDHHS 2000). None of the studies adjusted for SES or other potential confounding factors in examining the association between smoking and dental caries. Several literature reviews do suggest that the association between smoking and dental caries may reflect the tendency for smokers to practice less effective dental hygiene and plaque removal (Macgregor 1989; Christen et al. 1991; Kassirer 1994; Andrews et al. 1998).

Few studies adjusted for other notable correlates of both smoking and dental caries in their analyses. The DMF index is a cumulative, irreversible index. As persons experience decayed or filled permanent tooth surfaces or lose teeth over their lifetimes, their DMFT or DMFS scores will increase. Therefore, DMFT and DMFS can be associated strongly with age even if age per se is not a risk factor for incidence of dental caries. Few studies, however, adjusted for age in their analyses. Several studies provided age-specific mean caries scores (Ludwick and Massler 1952; Zitterbart et al. 1990; Axelsson et al. 1998) or age-specific significance testing of differences in means (Hirsch et al. 1991), which revealed an inconsistent association between smoking and caries within age groups. In the one study that used a nationally representative sample of U.S. adults and adjusted for age and race or ethnicity, DFT and DMS were actually slightly lower among male smokers than among those who had never used tobacco (Tomar and Winn 1999).

Two studies attempted to investigate a dose-response relationship between smoking and dental caries (Ludwick and Massler 1952; Ainamo 1971). Although smokers in the highest category of cigarettes smoked per day had experienced slightly higher DMFT, DMFS, or DS than those in the lowest dose categories, the relationship was not consistent. The first study presented age-specific comparisons of mean DMFT and DMFS by the number of cigarettes smoked per day, which showed no clear pattern within age strata. The second study did not present age-stratified or age-adjusted estimates, which potentially could present difficulties in interpreting the association between a disease index that is cumulative with age and an exposure that probably was increasing with age in the study population (aged 18 through 26 years).

Smoking may be associated more with root-surface caries than with coronal caries. Two cohort studies (Ravald et al. 1993; Locker 1996) and two cross-sectional studies (Locker 1992; Tomar and Winn 1999) reported higher mean RDFS or RDS scores among smokers, but in one cohort study (Locker 1996) smoking was not found to be a significant predictor of root-surface caries in multiple logistic regression modeling.

#### Evidence Synthesis

Few studies have investigated the association between cigarette smoking and dental caries. The available literature is fairly consistent in suggesting that smokers may experience slightly more decayed, missing, or filled coronal tooth surfaces. In addition, smokers generally experienced more decayed or filled root surfaces than nonsmokers. However, many of the published studies did not address potential confounders of these associations. It is therefore possible that the observed associations could reflect in part the presence of other factors associated with both smoking and dental caries. Evidence for a dose-response relationship is sparse and inconsistent. Studies that examined whether quitting smoking reduced the risk of caries development were not identified.

There is little evidence for a biologic mechanism that would explain the role of smoking in the development of coronal dental caries. Methodologic considerations limit the interpretation of findings from epidemiologic studies. The few lines of investigation undertaken have been inconsistent in identifying either bacterial or salivary effects that would be expected to increase this risk.

Some evidence suggests that smoking may indirectly increase the risk for root-surface caries. The mechanism probably involves an increased exposure of root surfaces of teeth secondary to loss of periodontal attachment. This relationship may reflect the impact of smoking on periodontium and the subsequent exposure of tooth root surfaces to the oral environment.

#### Conclusions

1. The evidence is inadequate to infer the presence or absence of a causal relationship between smoking and coronal dental caries.
2. The evidence is suggestive but not sufficient to infer a causal relationship between smoking and root-surface caries.

#### Implications

To better characterize the relationship between cigarette smoking and dental caries, future investigations will need to control for potential confounding factors. These studies should be of the cohort design to allow for assessments of the effect of smoking on carious lesion formation and to determine whether smoking cessation reduces disease incidence. Investigations into an association between smoking and root-surface caries will need to apply indices that take into account the number of root surfaces at risk, such as the Root Caries Index (Katz 1980), or control for root surface exposure in trying to identify whether smoking acts through a direct or indirect mechanism.

The increased risk for root-surface caries may be due to smoking-associated periodontal destruction and subsequent exposure of root surfaces of teeth to the oral environment. Because of the causal relationship between smoking and periodontitis as well as with many other diseases, and because more than one-half of U.S. adult smokers visit a dentist each year, the dental care community has both the opportunity and the professional obligation to counsel patients who smoke to quit.

## Erectile Dysfunction

Erectile dysfunction, defined as the persistent inability to attain and maintain penile erection adequate for satisfactory sexual performance (National Institutes of Health [NIH] Consensus Development Panel on Impotence 1993), has recently received considerable attention as a major medical issue in the United States. Additional emphasis has been given to this condition with increasing recognition of its profound impact on quality of life (Wagner et al. 2000). Epidemiologic data, though sparse, indicate its importance as a public health problem. The prevalence of erectile dysfunction in 1992 was estimated to be 18 percent among men 50 through 59 years of age according to the National Health and Social Life Survey, a United States probability sample of men and women aged 18 through 59 years (Laumann et al. 1999). Among men 40 through 70 years of age, prevalence estimates of complete erectile dysfunction during 1987–1989 exceeded 10 percent and estimates of at least mild erectile dysfunction exceeded 50 percent, according to the Massachusetts Male Aging Study (Feldman et al. 1994). Incidence estimates of erectile dysfunction during 1995–1997, derived from longitudinal results of the Massachusetts Male Aging Study, approach 26 cases per 1,000 men annually (Johannes et al. 2000).

Many conditions have been implicated as causes of erectile dysfunction, including hormonal derangement, psychogenic influences, neurologic disorders, and vascular impairment, which may all interfere with the basic physiologic mechanisms involved in penile erection. Vascular impairment, which commonly refers to disease states that hamper penile blood flow, warrants particular attention for several reasons. Most importantly, vascular diseases are commonly associated with presentations of erectile dysfunction. Objectively demonstrable erectile dysfunction has been found in patients with myocardial infarction, coronary bypass surgery, cerebral vascular accidents, peripheral vascular disease, and hypertension (Melman and Gingell 1999). Furthermore, reports of patients with vasculogenic erectile dysfunction have suggested predisposing vasculopathic risk factors, which include cigarette smoking, fatty diets, adverse serum lipid levels, hypertension, physical inactivity, and obesity (Goldstein and Hatzichristou 1994). Several large epidemiologic studies have explored the extent to which these factors impair erectile function (Feldman et al. 1994; Derby et al. 2000b; Feldman et al. 2000; Johannes et al. 2000). The results of these studies also imply that modifications of risk factors may reduce the occurrence of erectile dysfunction.

Among widespread concerns about adverse health effects associated with cigarette smoking is the growing belief that this activity adversely affects sexual health and, in particular, erectile function. It is plausible that cigarette smoking exerts atherogenic effects on penile circulation relevant to erectile function, akin to effects on coronary circulation associated with heart disease (Fried et al. 1986; Raichlen et al. 1986). Furthermore, cigarette smoking cessation may afford a preventive strategy for reducing erectile dysfunction rates. However, each of these hypotheses requires a critical examination of the evidence regarding the effects of smoking on penile erection. This chapter summarizes and evaluates current observational and experimental data linking cigarette smoking and tobacco use with erectile dysfunction, including the patho-physiologic concepts.

### Conclusions of Previous Surgeon General’s Reports

This topic has received some coverage in prior Surgeon General’s reports. The 1964 report (U.S. Department of Health, Education, and Welfare [USDHEW] 1964) included a discussion on masculinity in relation to COPD. The discussion drew from an investigation that defined the “element of masculinity as indicated by external morphologic features,” and contended that “weakness of the masculine component is significantly more frequent in smokers than in nonsmokers, and most frequent in heavier smokers” (USDHEW 1964, pp. 383–4). This vaguely described element merely relates to the theme of male sexual prowess, as erectile ability or lack thereof was not directly assessed. The Advisory Committee to the Surgeon General recognized the tentative nature of the conclusions and the need for further confirmation. The 1990 report carried out a comprehensive review of sexual activity and performance, and sperm density and quality (USDHHS 1990). This review did not lead to specific conclusions, reflecting limitations of the available data and their inconsistency. This section reviews the issue of male sexual function, examining the influence of cigarette smoking on penile erection, one specific component of male sexual function.

### Biologic Basis

Direct biologic evidence establishing plausible mechanisms for the effects of cigarette smoking on penile erection certainly would strengthen the premise that cigarette smoking constitutes a risk factor for erectile dysfunction. One possible mechanism is smoking-induced endothelial dysfunction of the penile vasculature. This hypothesis is supported by recent investigations into the physiology of penile erection affirming that the endothelium of the blood vessels supplying the penis, as well as that lining the lacunar spaces within the penis, releases vasoactive substances that contribute to the control of penile smooth muscle relaxation required for penile erection (Lue and Tanagho 1987).

Saenz de Tejada and colleagues (1989) probed whether smoking affects penile vasculature endothelium as part of an investigation of the consequences of diabetes mellitus on endothelial function in the penis in men with erectile dysfunction. Using isolated strips of human corpora cavernosa of the penis, the investigators compared isometric tension results from men with and without diabetes who were smokers (having at least a five pack-year history of cigarette smoking) or nonsmokers. The findings indicate that a history of smoking was not associated with a worsened impairment of endothelium-mediated relaxation responses. The study did not assess responses of tissue from smokers independently while controlling for other possible erectile dysfunction risk factors, nor did it carry out a subset analysis of responses from smokers specified to have had large amounts of cigarette smoke exposure. These limitations restrict the conclusions that can be drawn concerning the effects of smoking on endothelial function in the penis.

In a study of rats, Xie and colleagues (1997) examined the long-term effects of smoking on the endothelial synthesis of nitric oxide in the penis. Nitric oxide is now known to be the principal vasoactive mediator of penile erection (Burnett 1997). Nitric oxide is released by endothelial cells in response to direct cholinergic stimulation and in response to dynamic factors of changing penile blood flow. In the study, rats were passively exposed to cigarette smoke in 60-minute sessions once per day, five days per week, for eight weeks. Immunoblot analyses of the protein expression of endothelial nitric oxide synthase (eNOS) in penile tissue from the exposed rats did not reveal any diminution of eNOS expression compared with tissue from control rats. However, these investigators confirmed that overall nitric oxide synthase enzymatic activity (which combines neuronal and endothelial sources) and specifically the protein expression of the neuronal form of nitric oxide synthase in the penis were both markedly reduced following passive exposure to cigarette smoke in rats as compared with rats not exposed to smoke. Their findings mainly suggest that smoking selectively impairs neuronal mechanisms, in particular the neuronally based nitric oxide signal transduction pathway associated with penile erection. But the relevance of the rat model for humans is uncertain.

The investigation by Saenz de Tejada and colleagues (1989) also evaluated whether smoking affects the neurogenic mechanisms responsible for penile erection. The overall finding was that the impairment of neurogenically mediated relaxation of penile smooth muscle from smokers (combining results from men with and without diabetes) was not different from the impairment observed in nonsmokers (both men with and without diabetes). However, these conclusions have the same limitations as those concerning endothelial effects observed in this study (see above). An in vitro investigation of neuromuscular transmission in human corpus cavernosum also studied nicotine and found that the actions of this agent are both contractile and relaxant (Adaikan and Ratnam 1988). If erectile dysfunction results from exogenously administered nicotine during cigarette smoking, it may be due to the acute vasoactive modulatory effects of this agent on the penile vasculature.

### Epidemiologic Evidence

#### Observational Data

This section explores the association between cigarette smoking, as well as other forms of tobacco use, and the occurrence of erectile dysfunction based on a review of available observational data. A literature search was conducted using the National Library of Medicine’s PubMed system and was supplemented with professional knowledge of other resources. The critical feature of the observational data is the necessary reliance on self-reporting and other subjective instruments (e.g., logs, questionnaires, and sexual function inventories) to determine tobacco exposure and erectile performance, rather than quantitative measurements of these variables. A single-item assessment (e.g., “Do you experience difficulty getting and/or maintaining an erection that is rigid enough for satisfactory sexual intercourse?”) has gained prominence particularly for population-based epidemiologic studies (Derby et al. 2000a). This assessment has been useful as a single, direct practical tool to ascertain the presence of erectile dysfunction, whereas clinical questions are impractical (Derby et al. 2000a). This data collection methodology does introduce the possibility of information bias, probably toward underreporting. Differential underreporting by smoking status would bias estimates of the effects of smoking; however, the findings do prove insightful as to its probable significance within the general population. Furthermore, aspects of compromised sexual function are fundamentally issues of a subjective nature, wherein patient self-reporting may accurately serve as the main, or even the sole, criterion for establishing the existence and severity of the problem.

##### Case Series

Cigarette smoking has been linked to erectile dysfunction in several clinical reports, most qualifying as observational case series. As such, they are limited by not having true comparison groups, but they are reviewed here because they are often cited and data from more formal studies are limited. Wabrek and colleagues (1983) found that approximately 50 percent of 120 men referred for evaluation and management of erectile dysfunction to a hospital-based medical sexology program were smokers, counting users of cigarettes, cigars, or pipes. Virag and colleagues (1985) confirmed a 64 percent rate of cigarette smoking, defined as tobacco use exceeding 15 cigarettes per day for at least 15 years, among 440 men referred for clinical evaluation of erectile dysfunction. Bornman and Du Plessis (1986) similarly observed a 62 percent cigarette smoking rate, based on approximately 25 cigarettes per day for more than 20 years among 300 men screened at an andrology clinic. An attempt to provide comparative information was made by Condra and colleagues (1986), who studied 178 men with erectile dysfunction referred for clinical evaluation and found that 51.4 percent were current smokers and 81 percent were current or former cigarette smokers. These rates exceeded the 38.6 percent and 58.3 percent rates, respectively, ascertained in the general population using concurrent survey data. A recently published meta-analysis of smoking prevalence in men with erectile dysfunction also included a comparative assessment that controlled for age distribution, time period, and geographic location (Tengs and Osgood 2001). This meta-analysis, which consisted of 19 clinical studies published in the last 20 years with data on current smoking, revealed that 40 percent of the combined total of 3,819 men with erectile dysfunction were current smokers compared with 20 percent of men in the general population (Tengs and Osgood 2001).

##### Population-Based Studies

More valid appraisals of the effects of cigarette smoking on erectile dysfunction have been obtained through cross-sectional, random surveys of a sample population (Table 6.25). The Vietnam Experience Study of 1985–1986, which surveyed 4,462 U.S. Army Vietnam-era veterans aged 31 through 49 years, found erectile dysfunction prevalence rates of 2.2 percent among nonsmokers, 2.0 percent among former smokers, and 3.7 percent among current smokers (p = 0.005). The association (OR = 1.5 [95 percent CI, 1.0–2.2]) was maintained even after adjustments for comorbidity factors including vascular disease, psychiatric problems, hormonal factors, substance abuse, marital status, race, and age (Mannino et al. 1994).

Table 6.25 Cross-sectional studies on the association between smoking and the risk of erectile dysfunction (ED)

Study | Population | Smoking status | ED rate (%) | p value
Feldman et al. 1994 * | Boston, Massachusetts, residents aged 40–70 years; studied during 1987–1989 | Never and former smokers | 9.3 | >0.200
Feldman et al. 1994 * | Boston, Massachusetts, residents aged 40–70 years; studied during 1987–1989 | Current smokers | 11.0 | >0.200
Mannino et al. 1994 * | U.S. veterans aged 31–49 years; studied during 1985–1986 | Never smokers | 2.2 | 0.005^†^
Mannino et al. 1994 * | U.S. veterans aged 31–49 years; studied during 1985–1986 | Current smokers | 3.7 | 0.005^†^
Mannino et al. 1994 * | U.S. veterans aged 31–49 years; studied during 1985–1986 | Former smokers | 2.0 | 0.005^†^
Feldman et al. 2000 ‡ | Boston, Massachusetts, residents aged 40–70 years; studied during 1987–1996 | Never and former smokers | 14 | 0.010
Feldman et al. 2000 ‡ | Boston, Massachusetts, residents aged 40–70 years; studied during 1987–1996 | Current smokers | 24 | 0.010
Parazzini et al. 2000 * | Italian men aged ≥18 years; studied during 1996–1997 | Never smokers | 24.2 | NR^§^
Parazzini et al. 2000 * | Italian men aged ≥18 years; studied during 1996–1997 | Current smokers | 35.6 | NR^§^
Parazzini et al. 2000 * | Italian men aged ≥18 years; studied during 1996–1997 | Former smokers | 40.2 | NR^§^
Bacon et al. 2001 * | U.S. male health professionals aged 53–90 years; data gathered in 2000 | Never smokers | 22.4 | NR
Bacon et al. 2001 * | U.S. male health professionals aged 53–90 years; data gathered in 2000 | Current smokers | 27.9 | NR
Bacon et al. 2001 * | U.S. male health professionals aged 53–90 years; data gathered in 2000 | Former smokers | 26.2 | NR
Blanker et al. 2001 * | Dutch men aged 50–78 years; studied during 1995–1998 | Never and former smokers | NR | NR
Blanker et al. 2001 * | Dutch men aged 50–78 years; studied during 1995–1998 | Current smokers | NR | NR
Martin-Morales et al. 2001 * | Spanish men aged 25–95 years; studied during 1998–1999 | Never and former smokers | NR | NR
Martin-Morales et al. 2001 * | Spanish men aged 25–95 years; studied during 1998–1999 | Current smokers | NR | NR

* Prevalence study.

† Significant results.

‡ Incidence study.

§ NR = Data were not reported.

Additional recent studies support the direct association between cigarette smoking and erectile dysfunction. A cross-sectional study assessing the prevalence of erectile dysfunction in 2,010 men aged over 18 years in Italy in 1996–1997 showed that smoking was associated with an increased risk of the condition (Parazzini et al. 2000). Although the study was controlled for multiple variables including age, marital status, SES, and chronic diseases, it found an increased risk of erectile dysfunction for current smokers (OR = 1.7 [95 percent CI, 1.2–2.4], p <0.05) and for former smokers (OR = 1.6 [95 percent CI, 1.1–2.3], p <0.05) in comparison with lifetime nonsmokers (Parazzini et al. 2000). The Krimpen Study, a community-based study conducted in Rotterdam, the Netherlands, between 1995 and 1998 that surveyed 1,688 men aged 50 to 78 years, also confirmed that smokers professed significant erectile dysfunction (adjusted OR = 1.6 [95 percent CI, 1.1–2.3], p <0.05) to a greater extent than non-smokers (Blanker et al. 2001). A cross-sectional study of erectile dysfunction prevalence conducted in Spain in 1998–1999, consisting of 2,476 men aged 25 to 75 years, demonstrated that cigarette smoking was significantly associated with erectile dysfunction (adjusted OR = 2.5 [95 percent CI, 1.64–3.80], p <0.05) (Martin-Morales et al. 2001).

Another recent study supports the direct association between cigarette smoking and erectile dysfunction (Bacon et al. 2001). The Health Professionals Follow-up Study, a prospective cohort study of heart disease and cancer among U.S. male health professionals (Rimm et al. 1991; Ascherio et al. 1996), surveyed 34,282 men aged 53 through 90 years in 2000. The study showed an increased probability of erectile dysfunction among current smokers compared with nonsmokers (OR = 1.3 [95 percent CI, 1.1–1.6], p <0.05), while controlling for age, marital status, and chronic diseases (Bacon et al. 2001).

Evidence against an independent association between cigarette smoking and erectile dysfunction comes from the baseline phase of the Massachusetts Male Aging Study, a community-based survey conducted from 1987–1989 of 1,290 men aged 40 through 70 years living in the Boston, Massachusetts, area (Feldman et al. 1994). The probabilities of complete erectile dysfunction were 11 percent in smokers and 9.3 percent in nonsmokers, including both former smokers and those who had never smoked (p >0.20) (Feldman et al. 1994). However, the longitudinal phase of the Massachusetts Male Aging Study, extending over a nine-year median interval, showed the comorbidity-adjusted rate of incident erectile dysfunction to be significantly higher among cigarette smokers (24 percent) than nonsmokers (14 percent) (OR = 1.97 [95 percent CI, 1.07–3.63], p = 0.03) (Feldman et al. 2000). The classification of erectile dysfunction was based on an algorithm derived by the discriminant analysis of 13 questions.

Kleinman and colleagues (2000) reanalyzed the baseline data from the Massachusetts study using new methods for classifying erectile dysfunction. One method corresponded to the approach used by Feldman and colleagues (2000), based on responses from men attending a urology clinic to an original questionnaire and to an additional global question for self-rating erectile dysfunction. Another analysis was based on responses to an expanded follow-up questionnaire. Cross-sectional analyses of predictors of erectile dysfunction were carried out in the 1987–1989 baseline data. With the clinic-based method for classification, current smoking was not associated with erectile dysfunction (OR = 0.95 [95 percent CI, 0.72–1.22]) while with the study-based method it was (OR = 1.39 [95 percent CI, 1.07–1.80]).

##### Disease Correlates

Type of Tobacco Exposure. The prospective analysis of the Massachusetts Male Aging Study examined various types of tobacco exposures to identify associations with erectile dysfunction. The odds of incident erectile dysfunction were more than doubled both for passive exposure to cigarette smoke, if present both at home and at work (adjusted OR = 2.07 [95 percent CI, 1.04–4.13]) (p = 0.04), and for cigar smoking (adjusted OR = 2.45 [95 percent CI, 1.09–5.50]) (p = 0.03). Passive exposure at home or at work alone did not increase the odds of incident erectile dysfunction in nonsmokers, but each increment of exposure did increase the estimated likelihood of erectile dysfunction in smokers (Feldman et al. 2000).

Dose-Response. The relationship between the amount of tobacco exposure and the extent of erectile dysfunction has been subjected preliminarily to epidemiologic analyses. Several population-based studies further explored the effects of measures of exposure on erectile dysfunction. The Vietnam Experience Study did not show any relationship between the number of cigarettes smoked daily or the number of years smoked and erectile dysfunction among currently smoking veterans (Mannino et al. 1994). Similarly, the baseline phase of the population-based Massachusetts Male Aging Study did not reveal any dependence of packs per day or lifetime pack-years smoked on reported erectile dysfunction among current smokers (Feldman et al. 1994). By contrast, an Italian cross-sectional study showed an increased erectile dysfunction risk with duration of the behavior, based on an OR of 1.6 (95 percent CI, 1.1–2.3) for men smoking 20 or more years and an OR of 1.2 (95 percent CI, 1.0–2.4) for men smoking less than 20 years (Parazzini et al. 2000).

Risk Factor Covariates and Effects of Medication. The combined effects (i.e., synergistic or additive interactions) of cigarette smoking and other risk factors in the development of erectile dysfunction have been analyzed. Goldstein and colleagues (1984) examined clinical characteristics in 19 potent patients who underwent pelvic irradiation for prostate cancer, finding that 14 out of 15 who displayed diminished erectile capacity were cigarette smokers, whereas only 1 out of 4 who preserved erectile capacity was a cigarette smoker. The strong association of cigarette smoking with erectile impairment in this study led the investigators to propose a synergistic role of smoking, and conceivably other vasculopathic risk factors, with the radiation effects associated with radiation-induced erectile dysfunction (Goldstein et al. 1984). In the baseline phase of the Massachusetts Male Aging Study, Feldman and colleagues (1994) found that cigarette smoking did not constitute an independent risk factor for erectile dysfunction; however, in that same study, the association of erectile dysfunction with certain risk factors was greatly amplified in current cigarette smokers. This amplification was demonstrated for persons having erectile dysfunction with treated heart disease (from 21 percent for current nonsmokers to 56 percent for current smokers), treated hypertension (from 8.5 to 20 percent), and untreated arthritis (from 9.4 to 20 percent), and for those persons receiving various medications including cardiac drugs (from 14 to 41 percent), antihypertensive medications (from 7.5 to 21 percent), and vasodilators (from 21 to 52 percent). Similarly, in an Italian cross-sectional study, smoking increased the adjusted ORs for erectile dysfunction associated with diabetes by 13 percent and with hypertension by 39 percent (Parazzini et al. 2000).

Effects of Smoking Cessation. The hypothesis that cigarette smoking adversely affects erectile function would seemingly be strengthened by epidemiologic evidence demonstrating that smoking cessation leads to erectile function recovery. Forsberg and colleagues (1979) presented the case reports of two cigarette smokers aged 20 and 27 years with erectile dysfunction whose erectile function returned in concordance with improved penile vascular testing results following smoking cessation. Elist and colleagues (1984) determined that 8 (40 percent) out of 20 men with erectile dysfunction who had smoked one to two packs of cigarettes per day for at least 15 years recovered functional erections after abstaining from cigarette smoking for six weeks. In this study, seven responders (35 percent) were confirmed by objective testing criteria to have recovered normal erectile activity from baseline abnormal levels.

Population-based reports add additional perspectives to the premise that modifying cigarette smoking behavior affects the occurrence of erectile dysfunction. One study in this regard is the Vietnam Experience Study of 1985–1986, which determined that the prevalence of erectile dysfunction among former smokers was comparable to that among nonsmokers, and the prevalence rates were significantly lower than those found in current smokers (Mannino et al. 1994). Similarly, the longitudinal phase of the Massachusetts Male Aging Study determined that incident erectile dysfunction was no more likely among former smokers than among nonsmokers, in contrast to current smokers (Feldman et al. 2000). Results from the Health Professionals Follow-up Study also suggest that former smokers carry a lower risk of erectile dysfunction than current smokers, although this risk for former smokers still exceeds that of nonsmokers (Bacon et al. 2001).

From these population-based study results, one might further conclude that the discontinuation of smoking results in a recovery of functional erection status. However, this simple conclusion is challenged by recent results from the prospective evaluation of men participating in the Massachusetts Male Aging Study who discontinued smoking during the almost nine-year follow-up period of this study. This latter analysis found that the covariate-adjusted incidence of erectile dysfunction was not significantly reduced after smoking discontinuation (p = 0.28). Important considerations of this investigation are that the men who quit smoking had begun smoking at an early age (mean age 16.6 years) and had accumulated a high lifetime exposure to tobacco smoke before quitting (mean pack-years 39.4). The data provide a refined understanding of the effects of cigarette smoking cessation on erectile dysfunction: smoking cessation in middle age after a significant lifetime exposure to cigarette smoke may fail to modify erectile dysfunction occurrence, because long-term vascular effects of smoking conceivably persist after smoking cessation (Derby et al. 2000b).

#### Clinical Data

This section examines the link between tobacco exposure and erectile dysfunction based on objective clinical criteria. The erectile dysfunction specialty has developed quantitative measurements that serve as indices of erectile function, including physiologic and anatomic descriptions of the physical state of the penis. Numerous investigations have applied these methodologies to ascertain the effects of cigarette smoking and other forms of tobacco use on penile erection.

##### Penile Tumescence Studies

Nocturnal penile tumescence (NPT) monitoring provides a noninvasive diagnostic technique to quantify erection physiology objectively during the naturally occurring cycle of sleep-related penile erections. These spontaneous episodes of tumescence normally accompany rapid eye movement (REM) sleep and are diminished in men with presumably organic erectile dysfunction (Karacan et al. 1978; Allen and Brendler 1992). Several early investigations of the objective basis for vasculogenic erectile dysfunction applied NPT monitoring. Elist and colleagues (1984) confirmed NPT-monitored abnormalities in 20 smokers with erectile dysfunction, among whom 7 (35 percent) displayed normal NPT-monitored results after six weeks of smoking cessation. Virag and colleagues (1985) determined that smokers comprised 72 percent of patients with abnormal NPT results but only 32 percent of patients with normal NPT results. In a study of 168 men who smoked one or more packs per day (heavy smokers) and 632 men who smoked less than one pack per day (light smokers), Karacan and colleagues (1988) found that sleep-related penile erection rigidity was significantly lower at each decade of life after 30 years of age in heavy smokers compared with light smokers, and the duration of maximal tumescence was significantly lower for heavy smokers aged less than 30 years and 51 through 60 years compared with age-equivalent light smokers. In an investigation of 314 smokers with erectile dysfunction, Hirshkowitz and colleagues (1992) confirmed a significant inverse correlation between sleep-related penile erection rigidity and the number of cigarettes smoked per day (r = −0.12; p = 0.04). These investigators also showed that the duration of maximal tumescence was significantly shorter at the penile base (p ≤0.05), and the duration of detumescence (which refers to the decline from full erection to penile flaccidity) was also shorter (p = 0.06) among men who smoked 40 or more cigarettes per day compared with men who smoked 1 to 19 per day and 20 to 39 per day (p = 0.14).

##### Penile Vascular Hemodynamics

Impaired blood flow to the penis can be assessed using various measurement techniques. One widely used early technique to assess arterial vascular competence within the penis was the Doppler ultrasound of arterial pulsations in the flaccid, unstimulated organ. Although this method is no longer applied, the findings of these studies may still be relevant with respect to the pathogenesis of smoking-related vascular disease of the penis. With the values obtained, the penile-brachial index (PBI) can be calculated (the PBI refers to the ratio of penile to brachial systolic blood pressures). Reduced PBI values have been associated with impairment of the erectile process (Kempczinski 1979). Using this technique, Wabrek and colleagues (1983) did not find a significant association between cigarette smoking and abnormal PBI values. Virag and colleagues (1985) also did not find an independent smoking effect on PBI, although a synergistic effect was observed with smoking in combination with other arterial risk factors such as diabetes, hyperlipidemia, and hypertension. In contrast, Condra and colleagues (1986) demonstrated significantly lower PBI values among smokers than among nonsmokers. This same study also noted that the amount of time smoked correlated with abnormal PBI values: smokers with normal PBI values had smoked for a mean duration of 19.95 years while those with abnormal PBI values had smoked for a mean duration of 26.55 years. DePalma and colleagues (1987) likewise found that cigarette smoking carried a significantly higher probability of abnormal (49 percent) than normal (28 percent) vascular laboratory findings including PBI, which was not observed for age, hypertension, diabetes, or prior myocardial infarction. Hirshkowitz and colleagues (1992) confirmed consistent PBI reductions among 314 cigarette smokers with erectile dysfunction, finding significant correlations between the number of cigarettes smoked per day and the magnitude of these reductions for the left dorsal artery (r = −0.14; p = 0.01) and right cavernosal artery (r = −0.13; p = 0.03) of the penis.

The vascular evaluation of the penis has more recently employed a pharmacologic stimulus in combination with penile duplex ultrasonography to characterize the penile arteries. This application followed the discovery that a pharmacologic stimulus to induce an artificial erection provides an improved assessment of the physiologic responsiveness of these arteries over that provided during the resting state (Abber et al. 1986). Using this technique and applying a combined set of ultrasonographic parameters to establish normal vascular findings, Shabsigh and colleagues (1991) showed a consistent, nearly statistically significant difference in vascular impairment in smokers compared with nonsmokers. Kadioĝlu and colleagues (1995) also observed that penile vascular parameters were abnormal to a greater extent among smokers than among nonsmokers, although the differences were not statistically significant.

In summary, PBI testing suggests deleterious effects of smoking on the “resting state” circulation of the penis, and sonographic evaluation of the penis following pharmacostimulation additionally demonstrates apparent deleterious effects of smoking on dynamic blood flow changes in the penis.

##### Penile Vascular Morphology

Arteriographic studies have been conducted in patients with erectile dysfunction to characterize the vascular anatomy of the penis. Investigations have been carried out among cigarette smokers to confirm the presence and location of arteriographic lesions. Virag and colleagues (1985) calculated a 67.8 percent rate of arteriographic abnormalities among patients in whom organic erectile dysfunction had been established by NPT monitoring, of whom 86 percent were smokers. Bähren and colleagues (1988) similarly showed that 82 percent of their patient group with arteriographically proven peripheral arteriosclerotic lesions were heavy smokers. In a study by Forsberg and colleagues (1989), men with erectile dysfunction underwent screening studies of penile blood flow to identify abnormalities. Using both pharmacostimulation and angiography in 17 men, this study found significant distal penile vessel lesions; 14 (82 percent) of the men were identified as smokers. Rosen and colleagues (1991) carried out a comprehensive evaluation of penile circulation in cigarette smokers with erectile dysfunction, finding that smoking represented a significant independent risk factor in the development of atherosclerotic lesions in the internal pudendal and common penile arteries. These investigators also determined that the number of pack-years smoked was independently associated with hemodynamically significant atherosclerotic disease in the hypogastric cavernous arterial bed supplying the penis (for each 10 pack-years smoked, RR = 1.31 [95 percent CI, 1.05– 1.64]).

##### Histopathology

The effects of cigarette smoking on erectile tissue were investigated by Mersdorf and colleagues (1991), who confirmed degenerative tissue changes (including a decrease in smooth muscle content, sinusoidal endothelium, nerve fibers, and capillaries, and an increase in collagen density) in erectile tissue of smokers. These tissue alterations are consistent with tissue alterations seen in other vascular diseases.

#### Experimental Data

This section reviews experiments carried out to test the effects of cigarette smoking on erectile function (Table 6.26). These experimental approaches controlled cigarette smoking exposures and provided the possibility for a rigorous evaluation of the consequences for erectile ability. The value of the information was enhanced when experiments involved robust scientific methodology (e.g., a random allocation of people to experimental and control groups, the use of different control groups, and the application of blinding procedures to reduce bias).

Table 6.26 Experimental studies on the association between smoking and erectile dysfunction

Study | Population | Study design | Stimulus | Outcome
Human studies
Gilbert et al. 1986 | 42 smokers aged 18–44 years | Randomized controlled trial | Visual sexual stimulation | High-nicotine cigarettes reduced the amount of penile diameter increase
Glina et al. 1988 | 12 smokers aged 22–65 years | Acute experiment | Erection pharmacostimulation | Two cigarettes reduced intracavernous pressure measurements
Guay et al. 1998 | 10 smokers aged 32–62 years | Acute experiment | Sleep-related erections | Cigarette smoking discontinuation improved erectile parameters
Animal studies
Juenemann et al. 1987 | Dogs | Acute experiment | Cavernous nerve electrostimulation | Cigarette smoke inhalation reduced erectile parameters
Xie et al. 1997 | Rats | Chronic experiment | Cavernous nerve electrostimulation | Cigarette smoke inhalation did not alter erection parameters

##### Human Studies

Perhaps the first reported study to experimentally evaluate the hypothesized association between cigarette smoking and erectile dysfunction was performed by Gilbert and colleagues (1986), who made polygraphic recordings of penile erection responses in smokers during the viewing of erotic videos. Several aspects of this study are noteworthy: (1) the study population consisted of 42 male self-reported heterosexual cigarette smokers in good health, aged 18 through 44 years; (2) participants were assigned to high-nicotine exposure (0.9 mg nicotine per cigarette smoked), low-nicotine exposure (0.002 mg nicotine per cigarette smoked), or control (sucking on a hard mint candy) groups randomly selected and unknown to the experimenter; (3) at enrollment, a counterdemand was issued to the effect that nicotine enhanced sexual potency, to militate against contaminating hypotheses held by the participants about the effects of smoking on erections; (4) smoking abstention was required for two hours before the experiment; (5) baseline erotic videos were shown for participant acclimation; and (6) concomitant measures of cardiovascular response were obtained. The study found that smoking two, but not one, high-nicotine cigarettes significantly decreased the rate of penile diameter increase compared with the other conditions during the erectile stimulus (p < 0.001). It also determined that high-nicotine cigarettes caused significantly more vasoconstriction and heart rate increase than did low-nicotine cigarettes, which did not differ from control conditions (p < 0.001).

In another experiment undertaken to assess the acute effects of cigarette smoking exposure on penile erection, Glina and colleagues (1988) studied the interference of smoking on vasoactive drug-induced erectile responses monitored by intracavernous pressure recording. Study design features were as follows: (1) 12 chronic cigarette smokers, aged 22 through 65 years, were enrolled; (2) subjectively reported erectile function status of the participants at enrollment was not stated; (3) smoking was prohibited on test days; (4) each participant underwent pharmacostimulation consisting of intracavernous injection of 100 mg pa-paverine hydrochloride at baseline (without smoking) and one week later immediately after nicotine exposure (smoking two cigarettes containing 1.3 mg nicotine per cigarette); and (5) intracavernous pressure measurements were performed 20 minutes following pharmacostimulation by the same experimenter. The study found that all men obtained an erection by clinical judgment at baseline compared with only four (33 percent) after smoking, corresponding to a significant decrease in mean intracavernous pressures from 85.83 mm Hg at baseline to 53.50 mm Hg after smoking. As part of an earlier, larger investigation of the use of pa-paverine injections to test diagnostically for erectile dysfunction, Abber and colleagues (1986) described a similar experiment involving a chronic smoker with erectile dysfunction who displayed an acutely worsened erectile response immediately following smoking a cigarette compared with his baseline results.

In a visual depiction of the effects of cigarette smoking on arterial flow to the penis, Levine and Gerber (1990) described their pelvic arteriographic study of a 38-year-old man with a 25 pack-per-year smoking history who presented for evaluation of erectile dysfunction. Whereas a complete baseline evaluation including pelvic arteriographic studies showed no abnormalities, repeat pelvic arteriography immediately after the patient smoked two cigarettes revealed a decrease in the caliber of the entire pudendal artery and nonvisualization of the deep penile artery. The investigators suggested that acute vasospasm was responsible for the observed effects.

Further experimental evidence of the deleterious effects of cigarette smoking on erectile function was recently documented in an acute smoking cessation study by Guay and associates (1998). Ten men, 32 to 62 years of age who had at least a current 30 pack-year smoking history and were smoking one pack of cigarettes or more per day, were enrolled in a study monitoring NPT and rigidity by a home RigiScan^®^ technique. The study required monitoring of sleep-related penile erections on two successive nights, the first night following a usual day of smoking and the second night following discontinuation of smoking for one 24-hour interval. An additional component of the study involved repeat monitoring in four men who did not smoke for one month although they were administered transdermal nicotine patches (21 mg) during this time. The study results show that erectile parameters improved to a statistically significant degree in men who had stopped smoking for 24 hours, with further observed improvements in those not smoking and wearing nicotine patches for one month. The investigators concluded that eliminating cigarette smoking improves erectile function although factors contained in cigarette smoke other than nicotine primarily exert the damaging effects.

##### Animal Studies

Animal models have provided another useful approach for investigating the association between cigarette smoking and erectile dysfunction. The study by Juenemann and colleagues (1987) using an in vivo canine model represents a comprehensive, well-controlled investigation that combined stimulatory and monitoring techniques relevant to the physiology of erection. The methodology involved monitoring arterial inflow, intracavernous pressure, and venous outflow of the penis during cavernous nerve stimulation of erection alone, and with regulated penile perfusion before and after acute inhalation of cigarette smoke (1.4 mg nicotine per cigarette). Following smoking exposure (one to six cigarettes), compared with nonsmoking baseline conditions, peak arterial inflow was significantly diminished, peak intracavernous pressure was significantly diminished and could not be maintained, and venous outflow was not significantly restricted. Measurable serum nicotine and cotinine levels, obtained in the dogs following smoking exposure and used as markers, were consistent with concentrations found in human smokers, whereas no changes in arterial blood gases or systemic blood pressure were observed throughout the investigation. The investigators concluded that smoking exerts a localized deleterious effect on the neurovascular mechanisms required for penile erection, with a particular impairment of the veno-occlusive mechanism associated with maintenance of penile erections.

In a rat model, Xie and colleagues (1997) evaluated the long-term effects of cigarette smoking on penile erection. The methodology involved monitoring in vivo neurostimulated erections after exposing rats to a constant influx of cigarette smoke in an enclosed cage for a 60-minute session once per day, five days per week, for eight weeks. The investigation surprisingly found increases in intracavernous pressures in smoke-exposed rats compared with controls. However, the rats exposed to cigarette smoke also developed systemic hypertension. Intracavernous pressures standardized to systemic blood pressures in rats exposed to cigarette smoke did not differ from intracavernous pressures found in controls. The investigators explained their findings on the basis of tobacco smoke-associated vasoconstriction, and they conceded that vascular damage commonly associated with long-term cigarette smoking is inappreciable in the rat model, which is resistant to atherosclerosis.

### Evidence Synthesis

Available evidence indicates that cigarette smoking constitutes a risk factor for erectile dysfunction. However, the causal basis for this relationship must be carefully evaluated. With regard to the consistency of the relationship, both case series and population-based studies evaluating rates of erectile dysfunction among smokers provide support. The population-based studies afford a more accurate observational basis for this assessment than do uncontrolled case series, although the paucity of these studies hampers reaching a definitive conclusion. The strength of the relationship also rests on limited available information, but is similarly supported by observational evidence showing that a variety of tobacco exposures (including active and passive cigarette smoking and cigar smoking) is associated with erectile dysfunction. Consideration of a dose-response relationship is supported by a few observational and experimental investigations that have shown an increased risk of erectile dysfunction associated with increased exposures to cigarette smoking. The temporality of the relationship seems likely, with a few observational studies showing some evidence of erectile dysfunction following exposure to tobacco smoke. Intriguingly, preliminary observational findings demonstrate that cigarette smoking cessation apparently leads to a recovery of erectile function only if the discontinuation occurs after a limited extent of lifetime smoking.

Coherence of the relationship is supported by several biologic studies that have proposed plausible mechanisms for the deleterious effects of cigarette smoking on erections. The acute deleterious effects of smoking on erectile function result at least in part from nicotine carried in cigarette smoke. The nicotine pharmacologically induces vasospasm of penile arteries, and hence alters the dynamics of local blood flow required for penile erection. The chronic deleterious effects of smoking on erectile function result from impaired vascular physiology of the erectile tissue, as evidenced by degenerative morphologic changes in tissue of smokers. Although the exact mechanism of the impairment remains unclear, early studies in animals point to damaging effects on tissue-dependent erection regulatory factors. In sum, several lines of evidence contribute toward the inference of a causal relationship between cigarette smoking and erectile dysfunction. However, because the scope of observational and experimental evidence remains limited and incomplete, it seems reasonable to consider the evidence to be suggestive but insufficient to establish a causal relationship at this time.

### Conclusion

1. The evidence is suggestive but not sufficient to infer a causal relationship between smoking and erectile dysfunction.

### Implications

The clinical studies and basic scientific research summarized in this section suggest a relationship between cigarette smoking and erectile dysfunction. A strong inference that smoking causes erectile dysfunction requires more evidence to confirm initial findings and to fill in gaps in the knowledge base. Additional observational studies of sufficient size and with well-validated outcome measures are needed. More basic scientific studies to identify biologic mechanisms for the deleterious effects of smoking on penile erections also are necessary. In the meantime, current knowledge about the problem still prompts recommendations for smoking cessation and avoidance to limit the risk of erectile dysfunction. Promoting nonsmoking to prevent erectile dysfunction seems clinically appropriate. There may be significant public health benefits by reducing morbidity rates of this increasingly recognized, widespread condition.

## Eye Diseases

Diseases of the visual system, and possible subsequent visual loss, represent substantial social and economic concerns to the U.S. public. In the last three decades, Gallup polls have consistently indicated that blindness is second only to mental incapacity as the disability Americans fear most (National Advisory Eye Council [NAEC] 1998). There is ample reason for concern. An estimated 3.4 million Americans aged 40 years and older have visual impairment and 1 million of these people are legally blind. Because most vision loss results from eye disease associated with advancing age, and the “baby boom” population in the United States is aging, the public health impact of this problem is projected to double by 2030 (Prevent Blindness America 2002).

The economic consequences of eye disease for the U.S. population are huge. For example, sight-restoring cataract surgery was the most frequently performed surgical procedure among Medicare beneficiaries, at an estimated annual cost of $3.4 billion in 1991 (Steinberg et al. 1993). Altogether, the economic impact of visual disabilities and disorders was estimated at more than $38.4 billion in 1995 (NAEC 1998). Thus, substantial contributions to the social and economic welfare of the public are possible by finding and controlling the causes of these eye diseases, particularly the factors that present the opportunity to prevent the disease or loss of sight.

### Conclusions of Previous Surgeon General’s Reports

Epidemiologic investigation into risk factors for eye disease did not begin in earnest until the 1970s, bolstered by the establishment of the National Eye Institute (NEI) in 1968. Reports of the Surgeon General on smoking and health published before 2001 did not include eye disease as a topic simply because there were scant data indicating that smoking was related to ocular morbidity, although a compelling biologic basis did exist for postulating such associations. At least two of the three leading causes of visual loss worldwide, cataract and age-related macular degeneration (AMD), probably are due, at least in part, to smoking.

### Cataract

Cataract is the leading cause of blindness worldwide and a leading cause of visual loss in the United States (Thylefors et al. 1995; Muñoz et al. 2000). Currently, the most common and effective means of restoring vision is through surgical removal of the opacified lens and insertion of an artificial lens into the eye. According to NEI, about 1.35 million cataract operations are performed annually in the United States for Medicare beneficiaries (NAEC 1998), at an estimated cost of $3.4 billion in 1991 (Steinberg et al. 1993). If risk factors that either delay the onset or slow the progression of cataracts could be identified, major socioeconomic gains would be realized. The research findings that link cigarette smoking to cataract, specifically nuclear cataract, have identified one of the few modifiable risk factors for cataract.

The ocular lens is a normally transparent organ having a purely optical function. The lens, situated behind the pupil, focuses radiant energy on the retina to produce an image, much like the lens of a camera. The shape of the lens changes, or accommodates, in response to the distance of the viewed object to focus a sharp image onto the retina.

The transparency of the lens is a function of its peculiar characteristics. The lens itself is composed of a central core, or nucleus, of inert, protein-filled, former epithelial cells. The interior proteins are highly structured to ensure transparency. The lens grows by the constant addition of protein-filled, elongated, former epithelial cells that have differentiated into lens fibers that do not have a nucleus or other organelles. Of interest in this process is that the lens contains every fiber cell ever incorporated into it, including cells formed in the embryo stage through those formed very recently. These cells must maintain transparency throughout the life of an individual to ensure visual clarity, yet this central core is metabolically inert and cannot renew itself. Thus, the central lens is severely restricted in its ability to repair damage. The outermost layer of the lens is composed of a layer of epithelial cells, which are responsible for most of the metabolic activity of the lens. These cells are the source of new cells, as the old cells differentiate into fiber cells and are displaced toward the nucleus. These newest lens fibers make up the lens cortex, which surrounds the nucleus.

The loss of lens transparency is termed lens opacity, and lens opacification becomes increasingly common with advancing age. When the opacity becomes sufficiently dense or extensive or both so as to interfere with vision, the lens opacity is called a cataract. There are three main types of lens opacity or cataract, which are distinct in terms of risk factors, location in the lens, and epidemiologic pattern: nuclear, cortical, and posterior subcapsular lens opacity (West and Valmadrid 1995). The different types of opacities also can occur together in the lens, resulting in a “mixed” opacity.

The frequency of each type of lens opacity in the population increases with age and varies by racial or ethnic group. In one population-based study of 2,520 older Americans (West et al. 1998), aged 65 to 69 years, 32 percent of whites had nuclear, 15 percent had cortical, and 8 percent had posterior subcapsular cataract in at least one eye; comparable figures for African Americans were 20 percent, 42 percent, and 4 percent, respectively. At least 4 percent of the study participants in that age group had undergone cataract surgery as well.

#### Biologic Basis

Several hypotheses have been advanced to explain a possible association of smoking and cataract. Given the plethora of aromatic compounds and trace metals in cigarette smoke that are capable of damaging lens proteins, it is difficult to know which mechanism is likely to be the most important. Harding (1995) has postulated that cadmium, lead, thiocyanate, and aldehydes from cigarette smoke lead to lens damage. Investigators analyzing blood and lenses from cataract surgery patients have shown significant accumulations of cadmium in the blood and lenses of smokers compared with lenses of nonsmokers, with cadmium in lenses proportional to the amount smoked (Ramakrishnan et al. 1995; Cekic 1998).

Harding (1991) also has suggested that the damage to the lens may be from thiocyanate, which can cause carbamylation of crystallins (lens proteins) and enzymes. Smokers do have elevated thiocyanate levels in their blood, but levels in lenses have not been measured.

Others suggest that smoking may cause cataract through an indirect route, by lowering antioxidants (Taylor et al. 1995). However, the role of antioxidants in protecting against cataractogenesis still is controversial. Few studies have determined the level of anti-oxidants in the lens and the relationship between lens levels and blood or serum levels. One of the better studied antioxidants is vitamin C, which appears to be concentrated in the lens, and ocular levels of vitamin C are sensitive to plasma levels of this vitamin (Taylor et al. 1997). A review of research linking vitamin C and cataract found studies that reported a protective effect of vitamin C, an increased risk with serum levels of vitamin C, and no association at all; the conflicting results do not provide evidence of an association (West and Valmadrid 1995). In one study, smokers compared with nonsmokers had lower serum values of vitamin C, and in another, both smokers and nonsmokers had similar blood and lens levels of vitamin C (Kallner et al. 1981; Ramakrishnan et al. 1995). At present, the antioxidant pathway for lens damage from smoking requires more corroborative research.

#### Epidemiologic Evidence

The relevant articles for this section on eye diseases were identified initially through a search in PubMed from 1966 through 2000 by using the following search terms: “lens opacity,” “cataract,” “lens,” “nuclear lens opacity,” “cortical lens opacity,” “posterior subcapsular lens opacity,” “age-related macular degeneration,” “senile macular degeneration,” “age related maculopathy,” “choroidal neovascularization,” “drusen,” “geographic atrophy,” “atrophic macular degeneration,” “diabetic retinopathy,” “diabetic eye disease,” “glaucoma,” “intraocular pressure,” “Graves’ ophthalmopathy,” “thyroidopathy,” “eye pathology,” and “eye disease.” These terms were searched with the Boolean operator “and” followed by the terms “cigarette,” “smoking,” and “tobacco” in appropriate combinations. All articles were reviewed, and their bibliographies were reviewed for relevant articles not captured by the search strategy. The final selection of articles for citation in this section was made in consideration of the adequacy of the research or review and the relevance to the topic. The selection of eye diseases for review was based on the public health importance of the disease and the availability of research relevant to an association with smoking.

Several key methodologic issues should be addressed in any research on risk factors for cataract. First, there are different types of cataract, with largely unique risk factors for each type. Early research on risk factors often did not differentiate cataract type, making interpretation difficult because the mix of cataract types was unknown. For example, a surgical series of cataract patients is likely to be heavily weighted for posterior subcapsular cataract, whereas a population-based series will have few posterior subcapsular cataract cases. Surgical notes, or ophthalmologist notes, of the cataract type may lead to misclassification, as only the major cataract type usually is recorded. Ideally, studies on cataractogenesis would use one of several reliable, valid grading schemes for documentation of the presence and severity of lens opacity types.

The second methodologic issue is that each type of lens opacity has a different impact on the visual system. Research that defines cataract to include a visual acuity criterion effectively excludes asymptomatic, early lens changes or may include substantial numbers of persons with lens opacity not yet affecting acuity in the control group. Such research is less desirable from an etiologic standpoint.

Finally, issues of bias and confounding must be addressed with any research. Selection bias in clinic-based, case-control studies of cataract can be problematic, because controls sometimes have eye problems that may share risk factors in common with cataract. In population-based studies, patients with bilateral cataract surgery often are excluded from the analyses, because the type of cataract or date of surgery may be unknown. If the risk factor of interest drives progression of cataract, the exclusion of bilateral surgical cases will result in an underestimation of the risk. Potential confounders for the relationship of smoking and nuclear or posterior subcapsular cataract include age, race, gender, steroid use, and possibly alcohol use.

Ten epidemiologic studies reviewed have found an association between smoking and nuclear opacity and four found an association between smoking and posterior subcapsular opacity (Table 6.27). The studies reporting an association between nuclear cataract and smoking were carried out in diverse populations using different methodologies and different lens grading systems (Flaye et al. 1989; West et al. 1989a, 1995; Leske et al. 1991, 1998; Christen et al. 1992; Hankinson et al. 1992; Klein et al. 1993b; Cumming and Mitchell 1997; Hiller et al. 1997). The association with smoking generally was consistent (with most RRs ranging between 2 and 3); a dose-response relationship with the amount smoked was found. Four prospective cohort studies have found an association with smoking at baseline and subsequent risk of developing new nuclear opacities, surgery for nuclear opacities, or progression of existing nuclear opacities (Christen et al. 1992; West et al. 1995; Hiller et al. 1997; Leske et al. 1998).

Table 6.27 Studies on the association between smoking and cataracts

Study | Population | Design | Cataract assessment | Results
Association found
Clayton et al. 1982 | 931 cataract surgery patients; 325 controls | Case-control | No type specified; surgical cases | Heavy smoking was twice as common in cases; no data were reported; confounding was not addressed
Klein et al. 1985 | 1,370 persons with diabetes | Cross-sectional | Clinical exam for cataract type | Smoking was associated with cataracts (cataract type not stated, smoking not characterized)
Harding and Van Heyningen 1988 | 300 cataract surgery patients; 609 controls | Case-control | No type specified; surgical cases | Heavy smoking (>75 pack-years^*^) was associated with cataracts, OR^†^ = 1.97 (95% CI^‡^, 1.05–3.67); confounding was not addressed
Flaye et al. 1989 | 983 volunteers with complete data | Cross-sectional | Clinical exam for nuclear, cortical, and posterior subcapsular opacities | Nuclear opacity was associated with current smoking: OR = 2.5 for light smokers (95% CI, 1.6–4.0), 2.7 for moderate (95% CI, 1.6–4.3), and 2.9 for heavy (95% CI, 1.4–5.9); also related to past heavy smoking, OR = 2.6 (95% CI, 1.4–5.0); there were no associations with past light to moderate smoking or with other cataract types
West et al. 1989a | 838 male fishermen | Cross-sectional | Photographs for nuclear, cortical, and posterior subcapsular opacities; Wilmer grading system used | There was an association between cumulative pack-years and risk of nuclear opacities, p <0.004 (too few posterior subcapsular opacities to analyze); risk declined if participants had stopped smoking for ≥10 years; adjusted for age and gender
Leske et al. 1991 | 945 clinic cases; 435 controls | Case-control | Photographs for nuclear, cortical, and posterior subcapsular cataracts; Lens Opacities Classification System II used | Nuclear cataracts were associated with current smoking, OR = 1.68 (95% CI, 1.03–2.75); there were no associations with other cataract types or any analyses of former smokers; adjusted for confounders
Christen et al. 1992 | 17,824 male physicians without self-reported cataracts at baseline | 5-year prospective | Self-reported development of cataracts; medical records for date of diagnosis, date of extraction, type, and loss of vision | For current smokers of ≥20 cigarettes/day, RR^§^ = 2.24 for nuclear (95% CI, 1.47–3.41) and 3.17 (95% CI, 1.81–5.53) for posterior subcapsular cataracts; there was no association with <20 cigarettes/day; former smokers had no increased risk of nuclear or posterior subcapsular cataracts; adjusted for confounders
Hankinson et al. 1992 | 50,828 female nurses without self-reported cataracts at baseline | Approximately 8-year prospective | Self-reported cataract extractions; medical records for type | Smokers of 65 pack-years had increased risks for nuclear cataracts, RR = 1.79 (95% CI, 0.83–3.88), and posterior subcapsular cataracts, RR = 2.59 (95% CI, 1.59–4.50) (few current smokers, few cases of nuclear cataracts); former smokers had no increased risk unless they had smoked ≥35 cigarettes/day; adjusted for confounders
Klein et al. 1993b | Population-based sample of 4,926 adults | Cross-sectional | Photographs for nuclear, cortical, and posterior subcapsular opacities; Wisconsin grading system used | Smoking was associated with nuclear opacity, OR = 1.09 for 10 pack-years (95% CI, 1.04–1.16), and with posterior subcapsular cataracts among men, OR = 1.05 (95% CI, 1.00–1.11), and women, OR = 1.06 (95% CI, 0.98–1.14); former smokers were not studied; adjusted for confounders
West et al. 1995 | 442 male fishermen with photographs 5 years apart | 5-year prospective for incidence and progression | Photographs for nuclear, cortical, and posterior subcapsular opacities; Wilmer grading system used | OR for current smokers = 2.45 (95% CI, 1.00–6.04) for progression of nuclear opacity, which was associated with interim 5-year smoking, OR = 1.18 (95% CI, 1.06–1.32) for pack-years in 1 pack-year increments; adjusted for baseline severity and age; there was no association with incident nuclear opacity
Cumming and Mitchell 1997 | Population-based sample of 3,654 adults | Cross-sectional | Photographs of nuclear, cortical, and posterior subcapsular opacities; Wisconsin cataract system used | Ever smokers had increased ORs for nuclear opacity, OR = 1.3 (95% CI, 1.1–1.6), and posterior subcapsular opacity, OR = 1.5 (95% CI, 1.1–2.1); there was no risk for cortical opacity; former smokers (no time since quitting was specified) had similar risks
Hiller et al. 1997 | 660 members of Framingham Eye Study with no lens opacities | 12.5-year prospective | Clinical exam for nuclear, cortical, and posterior subcapsular opacities; Wilmer grading system used | Light smoking at baseline was associated with incident nuclear opacity, OR = 1.68 (95% CI, 1.14–2.49), as was heavy smoking, OR = 2.37 (95% CI, 1.43–3.93); former smokers (but could be interim smokers) had an increased risk of incident nuclear opacity, OR = 2.02 (95% CI, 1.14–3.57); there was no association with other cataract types
Leske et al. 1998 | 764 of 1,380 participants in a case-control study | 4-year prospective of cases and controls | Photographs for nuclear, cortical, and posterior subcapsular opacities; Lens Opacities Classification System III used | There was an increase in nuclear opacity with smoking at baseline, RR = 1.58 (95% CI, 1.06–2.35); interim smoking, quitting smoking, and other opacities were not studied
Christen et al. 2000 | 20,907 male physicians with no cataracts at baseline | 13-year prospective | Self-reported development of cataracts; medical records with dates of diagnosis and extraction, and loss of vision (type not specified) | Former smokers had a lower risk of cataracts (type not specified) compared with current smokers, and a lower risk of cataract surgery, adjusting for number of cigarettes smoked and other confounders, RR = 0.79 (95% CI, 0.67–0.92)
No association found
Bochow et al. 1989 | Posterior subcapsular cataract cases and controls | Case-control | Chart reviews for and absence of posterior subcapsular cataracts | Current and former smoking were not related to posterior subcapsular cataracts
Italian-American Cataract Study Group 1991 | 1,008 clinic cases; 469 controls | Case-control | Slit lamp exam for nuclear, cortical, and posterior subcapsular cataracts; Lens Opacities Classification System I used | Compared never, former, and current smokers among cases and controls; no differences were reported (data were not shown)
Mohan et al. 1989 | 1,441 patients in India with cataracts; 549 controls | Case-control | Nuclear, cortical, and posterior subcapsular cataracts on clinical exam; no grading scheme described | Compared never, former, and current smokers among cases and controls; no differences were reported (data were not shown)

* Pack-years = The number of years of smoking multiplied by the number of packs of cigarettes smoked per day.

† OR = Odds ratio.

‡ CI = Confidence interval.

§ RR = Relative risk.

Smoking has been less consistently associated with an increased risk of posterior subcapsular opacity. Two prospective cohort studies have found an increased risk, between 2.5- and 3-fold, associated with heavy smoking (smoking 20 or more cigarettes per day and smokers of 65 or more pack-years) (Christen et al. 1992; Hankinson et al. 1992). Two cross-sectional, population-based studies found a weaker association, and one reported an association only among men (Klein et al. 1993b; Cumming and Mitchell 1997). Two other population-based surveys did not find any association with posterior subcapsular cataract (Flaye et al. 1989; Hiller et al. 1997).

One limitation of population-based studies of risk factors for posterior subcapsular cataract is the rarity of that cataract type, making it difficult to acquire enough cases to precisely characterize risk. Another limitation is that posterior subcapsular cataract is highly visually disabling, and generally progresses quickly, so while it is overrepresented in surgical series it may be underrepresented in population-based studies because affected persons already have had cataract surgery (West et al. 1998). Thus, prospective cohort studies on posterior subcapsular cataract in populations are likely to provide more compelling data about the association.

The three studies that found no association between smoking and cataract deserve comment. The case-control study in India (Mohan et al. 1989) was hospital-based and relied on patients from one center. The possibility of selection bias, especially in terms of cases with vision loss and controls without vision loss and their COPDs, must be considered. The case-control study in Italy (Italian-American Cataract Study Group 1991) had a design similar to the study in India but used cases and controls from three clinics covering the population in Parma, Italy. This broader coverage reduced the possibility for selection bias. However, the recruitment rates of cases of posterior subcapsular cataract and nuclear cataract were lower than expected; the smoking data were not shown for this study, so an assessment of the power to detect an increased risk associated with smoking could not be done. The third study (Bochow et al. 1989), a case-control study of risk factors for posterior subcapsular cataract, did not evaluate the association of smoking with other cataract types. The controls included patients with nuclear cataract alone or with AMD, which may have increased the prevalence of smoking in the comparison group. Thus, the three studies that did not find an association between smoking and cataract have limitations that may have introduced bias toward the null.

There are no clinical trials of smoking cessation and determinations of either reduced risk of onset or progression of lens opacities. Six studies examined the risk in former smokers, and the data in general support a lower risk of progression or development of cataract after cessation. The mechanism is likely to be a reduction in the smoking-related dose of injurious agents to the lens rather than any reversal of the cataractogenic process. A cross-sectional survey looked in detail at time since smoking cessation and reported that cessation of 10 or more years reduces the risk of nuclear opacity (West et al. 1989a). In two large prospective cohort studies, former smokers at baseline had no increased risk of new nuclear opacities (Christen et al. 1992) or new cataract surgery (Hankinson et al. 1992). The 13-year follow-up study among male physicians of self-reported development of visually significant cataract found a lower risk among former smokers compared with current smokers (Christen et al. 2000). The prospective data are compatible with previous work showing that ongoing smoking drives progression. Other researchers who found similar risks for former smokers as for current smokers did not evaluate risk by years since cessation (Cumming and Mitchell 1997; Hiller et al. 1997). Studies of risk for cataract among smokers using low-yield cigarettes or low-tar products have not been reported.

#### Evidence Synthesis

Substantial evidence based on cross-sectional and prospective cohort studies now has accrued linking nuclear, and possibly posterior subcapsular, cataract to cigarette smoking. There is a dose-response relationship and evidence that former smokers have a lower risk of cataract and of progression of cataract compared with current smokers. On the basis of the epidemiologic studies, researchers now are investigating the mechanisms by which smoking may damage the lens, by using animal and lens cell culture models. The laboratory data are not yet sufficiently mature to inform the discussion of smoking and cataract, in part because there are few animal models of age-related cataract; most require an external insult to initiate the cataractogenic process. However, smokers are exposed to a number of agents that may cumulatively damage the lens, which lacks reparative capacity.

#### Conclusions

1. The evidence is sufficient to infer a causal relationship between smoking and nuclear cataract.
2. The evidence is suggestive but not sufficient to infer that smoking cessation reduces the risk of nuclear opacity.

#### Implications

There is moderate evidence to suggest that smoking also may be associated with an increased risk of posterior subcapsular opacities as well, but more research is needed before a causal association can be inferred for this cataract type. The difficulty the lens has in repairing damage suggests that opacification at the time of smoking cessation is likely to be irreversible. Studies of cataract in clinical trials of smoking cessation would provide more definitive evidence for any protective effect, although feasibility would be constrained by the need for large populations.

### Age-Related Macular Degeneration

AMD is the leading cause of blindness in whites aged 65 years and older in the United States (Sommer et al. 1991; Muñoz et al. 2000). There currently is no well accepted treatment to prevent or halt the progression of atrophic AMD, the most common form of AMD. Treatment to halt vision loss from the less common, severe form of AMD, exudative (neovascular) AMD, often is short lived, as neovascularization (new blood vessel formation) often recurs. A recent large-scale clinical trial has provided evidence that antioxidant supplements plus zinc may delay the progression of some signs of AMD (Age-Related Eye Disease Study Research Group 2001). Otherwise, no preventive therapy for AMD is available, so considerable attention has focused on identifying risk factors for this disease.

The macula is a component of the retina at the center of the optical axis; it contains the fovea, a highly specialized area of the retina responsible for high-resolution vision. The retina consists of neural tissues, including the photoreceptors that convert energy from visible light into electrical signals sent on to the brain for processing. The photoreceptors—rods and cones— have high metabolic requirements and replace their outer segments daily. The metabolic functions of the retina are supported by the retinal pigment epithelium, which phagocytizes an estimated 2,000 outer segment membranes daily. This high rate of activity is made possible by the exchange of nutrients (and removal of waste) through the retinal blood supply, the choriocapillaris. There is a blood retinal barrier to this exchange, which is formed by both the retinal pigment epithelium and its anchor, Bruch’s membrane (lamina basalis choroideae). Thus, the complex of the retinal pigment epithelium, Bruch’s membrane, and the choriocapillaris serve as the nutritional source for the sensory retina. Changes in each of the tissues in this complex have been hypothesized to result in AMD. However, the pathogenesis of AMD, indeed the differentiation of changes in early AMD from those of normal aging, is uncertain (Sarks and Sarks 1994).

AMD is an umbrella designation for a variety of degenerative changes in the macula. The degeneration is characterized in its early stages by pigmentary disturbances and atrophic changes. The late stages of AMD are characterized by widespread atrophy of the retinal pigment epithelium, loss of photoreceptors (atrophic AMD), and, less commonly, exudative AMD. With exudative AMD, new, unstable blood vessels develop in the choroid and grow under or through the retinal pigment epithelium via breaks in Bruch’s membrane. Leakage from these neovascular membranes may lead to detachment of the retinal pigment epithelium, hemorrhage, and formation of a disciform scar. The late stages are associated with vision loss, classically loss of central vision, the part of vision responsible for activities such as reading and close work.

Morphologic changes associated with AMD include basal laminar deposits at the level of the retinal pigment epithelium, thickening of Bruch’s membrane, and drusen. Drusen are deposits of extracellular material thought to be accumulations or “garbage bags” of waste products from the retinal pigment epithelium. At least two types of drusen are recognized clinically on the basis of their appearance: small, hard drusen, which are a common feature of aging; and larger, soft drusen, which also are common with aging but are a likely risk factor for developing severe AMD. The presence of drusen in the fundus, thought to be the hallmark of early AMD, is being challenged as a marker by observations that drusen can appear and disappear over time (Bressler et al. 1995; Klein et al. 1997), that most people with large, soft drusen do not develop advanced AMD (Klein et al. 1997), and that epidemiologic patterns associated with advanced AMD are different from those for drusen-defined early AMD. This debate has relevance in evaluating the evidence for an association of smoking and early versus advanced AMD.

#### Biologic Basis

Of the postulated mechanisms underlying the retinal changes in AMD, three have bearing on the hypothesis that smoking is associated with AMD. The first can be characterized as oxidative stress leading to changes in the ability of the retinal pigment epithelium to phagocytize cellular products, which in turn leads to accumulations of debris that interfere with the nutrient exchange between the retinal pigment epithelium and the choriocapillaris. Oxidative stress can result from free-radical damage to proteins, lipids, and possibly, mitochondrial DNA. The stress is considered to contribute to malfunctions of the retinal pigment epithelium. The macula is a particularly likely target for oxidative stress because of the macula’s high exposure to light, high metabolic rate, and high concentrations of fatty acids. But the macula also is very rich in antioxidative, protective mechanisms, including an array of antioxidant nutrients and enzymes, as well as melanin. Smoking, through its actions on reducing plasma levels of antioxidants in addition to reducing macular pigment, is hypothesized to increase the oxidative stress on the macula by robbing it of its defenses (Hammond et al. 1996).

The second hypothesis for the pathogenesis of AMD proposes that the degradation of Bruch’s membrane, as manifested by thickening and changes in the composition, leads to interference with nutrient exchange between the retinal pigment epithelium and its blood supply. Vascular endothelial growth factor (VEGF) has been reported in the retinal pigment epithelium cells; these cells may liberate VEGF in response to the interference in nutrient exchange. Investigators are working on the role of VEGF, released in connection with hypoxia, in the pathogenesis of AMD, particularly for the neovascular type (Mousa et al. 1999). Smoking has been associated with an increase in plasma immunoreactive VEGF, at least acutely, operating likely through its ability to cause tissue hypoxia (Wasada et al. 1998).

The third hypothesis for the pathogenesis, or at least a possible contributing cause, of AMD is vascular insufficiency. Changes in the choroidal circulation may impair the ability of the retinal pigment epithelium to dispose of waste substances, leading to the accumulation of waste material. The rate and volume of blood flow through the choriocapillaris are high in response to the demands of the pigmented epithelium and the photoreceptors. Smoking has been shown to alter choroidal blood flow (Bettman et al. 1958). Smoking also affects the vasculature through platelet adhesions and hypoxia from elevated levels of carboxy-hemoglobin, which might add to the stimulation of new vessel growth.

It is likely that multiple pathways are responsible for the degenerative changes in the macula with age, and a reasonable basis exists for presuming that smoking may operate through one or more of these pathways.

#### Epidemiologic Evidence

Two methodologic issues add to the complexity of assessing the relationship between AMD and smoking. The first issue is that advanced, or severe, AMD mostly occurs in the very old. About 7 percent of the white population aged 75 years and older will have advanced AMD (Klein et al. 1992). The second issue is that life expectancy of smokers is less than that of non-smokers, so selective survival of smokers to even develop AMD is an issue. Together, the relatively low incidence of AMD and the low prevalence of smoking in very elderly populations diminish the power to detect associations in all but the largest studies, which is evident in the population-based studies of AMD that have low numbers of cases of severe AMD.

One way to circumvent the problem is to study the association of smoking in precursor lesions or early AMD; however, there is no uniform agreement on the clinical signs of early AMD. Many of the signs currently in use are common in the population and can be so unstable as to be almost uninformative about who will develop advanced AMD. Data are accumulating on predictors of advanced AMD, the presence of very large drusen, and the retinal area covered by drusen. In part, the difficulty of determining the relevant early signs may be due to the limitations of photographic systems to detect such changes in, for example, Bruch’s membrane; for research purposes, however, no alternative detection systems are available for accurately detecting early changes.

With these caveats in mind, the research findings to date suggest a strong likelihood that smoking is related to advanced or severe AMD, particularly exudative AMD, but there is scant evidence that smoking is related to the apparent early signs of AMD (Table 6.28). One cross-sectional, population-based study (Smith et al. 1996) found increased odds of early AMD among smokers compared with nonsmokers (OR = 1.89 [95 percent CI, 1.25–2.84]). However, two others, using identical grading methods, found no increased odds (Klein et al. 1993c; Delcourt et al. 1998). In another cross-sectional survey of fishermen who were heavy smokers, a paradoxical protective effect was seen for smoking and the odds of early AMD, primarily cases of moderate drusen (West et al. 1989b). A prospective cohort study of the risk of developing early signs of AMD found an increased risk of developing large (>250 μm) drusen among smokers compared with lifetime nonsmokers; the RR was 3.21 (95 percent CI, 1.09–9.45) among men and 2.20 (95 percent CI, 1.04– 4.66) among women. No other early sign was associated with smoking (Klein et al. 1998). The lack of association with presumed early AMD may be due to the imprecision of the signs chosen to represent early AMD, thus biasing the results toward the null. Further work on improving this classification is warranted. It is also possible that smoking is related to progression of AMD to the exudative form but not to the onset of early lesions.

Table 6.28 Studies on the association between smoking and age-related macular degeneration (AMD)

Study | Population | Design | AMD assessment/type studied | Results
Paetkau et al. 1978 | 114 cases of exudative AMD from 1 clinic | Cross-sectional | Fluorescein angiography | Current smokers had an earlier age of onset of vision loss (64 years) compared with nonsmokers (71 years), p <0.001
Maltzman et al. 1979 | 30 persons with AMD and 30 normal controls from 1 clinic matched for age, gender, and race | Case-control | Data were not reported | 10 persons with AMD reported smoking at some point, compared with 7 controls; no association was concluded
Hyman et al. 1983 | 162 persons with AMD and 175 controls from 34 practices matched for age and gender | Case-control | Diagnosis of drusen and/or macular degeneration confirmed by fundus photographs | Male smokers (not defined) had an increased risk of AMD: OR^*^ = 2.6 (95% CI^†^, 1.2–5.8); there was no dose-response pattern
Blumenkranz et al. 1986 | 26 persons with exudative AMD compared with 23 controls matched for age and gender (spouses or partners) | Case-control | Fundus photographs to determine cases and controls without AMD | Smokers were not significantly more likely to have exudative AMD, OR = 1.3 (95% CI, 0.3–4.4)
Macular Photocoagulation Study Group 1986 | 119 eyes with neovascular AMD assigned to argon laser photocoagulation | 3-year prospective | Angiograms showing choroidal neovascularization within 200–2,500 μm of the fovea; outcome: recurrence of choroidal neovascularization on photographs | Current smokers of ≥10 cigarettes/day had greater rates of choroidal neovascularization recurrences, RR^‡^ = 1.8 (p <0.02); dose-response was not studied
West et al. 1989b | 838 male fishermen, 96 with early AMD (large drusen, confluence, and hyperpigmentation) | Cross-sectional | Fundus photographs to diagnose AMD | Ever smokers had a lower risk than never smokers of AMD, OR = 0.54 (95% CI, 0.30–0.95); there was no dose-response relationship after adjusting for confounders
Eye Disease Case-Control Study Group 1992 | 421 persons with neovascular AMD from 5 centers; 615 controls (control group matched for age, gender, race, and center) | Case-control | Physician-diagnosed AMD with visual loss, drusen, and 1 of several signs of choroidal neovascularization; verification by fundus photographs | Current smoking was associated with neovascular AMD, OR = 2.2 (95% CI, 1.4–3.5); former smokers also had an increased risk, OR = 1.5 (95% CI, 1.2–2.1); dose-response was not studied
Vinding et al. 1992 | Population-based sample of 773 participants in Copenhagen aged ≥60 years; 88 cases of atrophic AMD and 24 of exudative AMD | Cross-sectional | Physician-diagnosed atrophic and exudative AMD, with visual loss | Both atrophic OR = 2.5 (p <0.01) and exudative OR = 1.5 (p >0.05, small sample size) AMD cases were more likely to be found in smokers than in nonsmokers
Klein et al. 1993c | Population-based sample of 4,771 participants aged ≥43 years; 41 cases of exudative AMD and 29 of atrophic AMD | Cross-sectional | Fundus photographs; Wisconsin grading scheme used for early and late AMD | There was no relationship of early AMD (drusen characteristics, pigmentary disturbances) to smoking status, dose, or passive smoking; current smokers had a higher frequency of exudative AMD, OR = 2.50 (95% CI, 1.01–6.20) among women and 3.29 (95% CI, 1.03–10.5) among men; it was not associated with passive smoking; a dose-response pattern was reported only for women; there was no association with atrophic AMD
Christen et al. 1996 | 21,157 male physicians aged ≥40 years with no AMD at baseline, followed for ≥7 years; 268 had AMD with vision loss and 64 had exudative AMD | Prospective | Self-reports with vision loss of 20/30 or worse; chart review by ophthalmologist/optometrist | Current smokers of ≥20 cigarettes/day had an increased risk of AMD with vision loss, RR = 2.57 (95% CI, 1.70–3.90); there was no increased risk with smoking <20 cigarettes/day, RR = 1.18 (95% CI, 0.57–2.42); former smokers had an increased risk, RR = 1.30 (95% CI, 1.01–1.69); dose-response relationship was present; quitting for ≥20 years decreased the risk; current smokers (no dose was given) had an increased risk of exudative AMD, RR = 1.95 (95% CI, 0.89–4.24); no increased risk with former smoking; cases of AMD without vision loss had no association with smoking
Seddon et al. 1996 | 31,843 female nurses aged ≥50 years with no AMD at baseline, followed for 2–12 years; 215 had AMD with vision loss and 77 had exudative AMD | Prospective | Self-reports with vision loss of 20/30 or worse; chart review by ophthalmologist/optometrist; subset validated by fundus photographs | Current smokers had an increased risk of AMD with vision loss, RR = 1.7 (95% CI, 1.2–2.5), greatest in those smoking ≥25 cigarettes/day, RR = 2.4 (95% CI, 1.4–4.0); former smokers had an increased risk, RR = 1.8 (95% CI, 1.3–2.5); dose-response relationship was present; former smokers had RRs similar to current smokers with no evidence of effects from quitting even after ≥15 years; a dose-response relationship was also seen with exudative AMD
Smith et al. 1996 | Population-based study of 3,654 participants aged ≥49 years; 50 cases of exudative AMD and 22 of atrophic AMD | Cross-sectional | Fundus photographs graded according to Wisconsin grading scheme for early and late AMD | Current smokers had a higher prevalence of neovascular AMD, OR = 3.26 (95% CI, 1.45–7.33); atrophic AMD, OR = 4.94 (95% CI, 1.29–18.82); and early AMD, OR = 1.89 (95% CI, 1.25–2.84); ORs were elevated for neovascular and atrophic AMD, but not significantly for men; passive smoking was not associated with any AMD; there were no associations between late or early AMD and pack-years^§^
Vingerling et al. 1996 | Population-based study of 6,251 participants aged ≥55 years; 65 cases of neovascular AMD and 36 of atrophic AMD | Cross-sectional | Fundus photographs graded according to Wisconsin grading system | Current smokers aged <85 years had an increased prevalence of neovascular AMD, OR = 3.6 (95% CI, 1.8–7.4); no increase in atrophic AMD; there was a dose-response relationship with ≥10 pack-years, OR = 9.1 (95% CI, 3.2–25.9); stopping smoking for ≥20 years decreased the risk of neovascular AMD among nonsmokers
Tamakoshi et al. 1997 | 56 cases of exudative AMD among Japanese men aged 50–69 years in 5 hospitals; 82 male controls with no macular changes (coming for physical exam) | Case-control | Fundus photographs and fluorescein angiography | Neovascular AMD was associated with current smoking, OR = 3.07 (95% CI, 1.09–8.63), and former smoking, OR = 2.09 (95% CI, 0.71–6.13); a dose-response relationship was present, with a high risk for those who started smoking before 20 years of age, OR = 3.41 (95% CI, 1.20–9.73)
Delcourt et al. 1998 | 2,196 participants aged ≥60 years in a population-based survey; 41 cases of late AMD (neovascularization or geographic atrophy) | Cross-sectional | Fundus photographs graded according to Wisconsin grading system | Current smoking, OR = 3.5 (95% CI, 1.0–12.2), and former smoking, OR = 2.8 (95% CI, 1.1–6.9), were associated with late AMD (not further separated into atrophic vs. neovascular AMD); dose-response relationship was present; those who stopped smoking within 20 years had the same risk as current smokers; there were no associations with early AMD
Klein et al. 1998 | 3,583 participants aged ≥43 years in a longitudinal, population-based study (reported low incidence of atrophic and exudative AMD) | 5-year prospective | Fundus photographs graded according to Wisconsin grading system | Current smokers were more likely to develop large (>250 μm) drusen compared with never smokers, RR = 3.21 (95% CI, 1.09–9.45) among men and 2.20 (95% CI, 1.04–4.66) among women; dose-response relationship was present; no other sign was associated; male (not female) current smokers progressed to age-related maculopathy in a dose-response pattern

* OR = Odds ratio.

† CI = Confidence interval.

‡ RR = Relative risk.

§ Pack-years = The number of years of smoking multiplied by the number of packs of cigarettes smoked per day.

Gender differences appear in the findings as well. In one case-control study of severe AMD, the relationship with smoking was observed in men only (Hyman et al. 1983). In one prospective cohort study in a population having primarily early AMD, progression of AMD among smokers was observed with a dose-response pattern only among men (Klein et al. 1998). A prospective cohort study of exudative AMD among men found a benefit of quitting smoking after 20 years of cessation (Christen et al. 1996), but a similar study among women found no benefit after 15 or more years of cessation (Seddon et al. 1996). There are not evident explanations for these differences, except that the significantly lower prevalences of smoking among women may reduce the power to detect associations with AMD, especially if heavy smoking is the risk-determining factor.

The strongest and most consistent association seen in the literature is the association of current smoking and risk of severe AMD, especially exudative AMD. Because several studies tended to combine atrophic and exudative AMD into “late” or “severe” AMD, it is difficult to know whether to attribute the association to either one or both, unless specified. Four case-control studies have been reported to date. A large case-control study of exudative disease (Eye Disease Case-Control Study Group 1992) found an increased OR with current and past smoking of 2.2 (95 percent CI, 1.4–3.5) and 1.5 (95 percent CI, 1.2–2.1), respectively. Three other case-control studies also found an increased risk for severe AMD in smokers, with estimated ORs between 2 and 3 (Hyman et al. 1983; Macular Photocoagulation Study Group 1986; Tamakoshi et al. 1997). Four cross-sectional, population studies found increased odds of exudative AMD among current smokers, with ORs between 1.5 and 3.6; two of the four studies found a dose-response relationship. Two of the four cross-sectional studies found increased odds of atrophic AMD with current smoking (Vinding et al. 1992; Smith et al. 1996), but the other two did not (Klein et al. 1993c; Vingerling et al. 1996). Two prospective studies found a significant association with either exudative disease or severe AMD in current heavy smokers (20 or more cigarettes per day) (Christen et al. 1996; Seddon et al. 1996). Former smokers also had an increased risk of AMD, although lower than that for current heavy smokers. Quitting more than 20 years previously appeared to decrease the risk in two cross-sectional studies (Vingerling et al. 1996; Delcourt et al. 1998), as well as in a prospective cohort study in men (Christen et al. 1996). In the prospective study in women (Seddon et al. 1996), however, quitting 15 or more years prior did not decrease the risk of severe AMD.

The data from cross-sectional studies suggest that passive smoking is not related to early or late AMD (Klein et al. 1993c; Smith et al. 1996). There are no corroborating data from animal models. Although animal models of induced retinal damage exist, no good animal models present the spectrum of features of AMD.

#### Evidence Synthesis

These data provide evidence that current smoking is associated with exudative AMD and possibly atrophic AMD. Dose-response relationships with the amount of smoking have been described. Maintaining smoking cessation at least 20 years decreased the risk of severe AMD and exudative AMD. The possibility that smoking is associated with the neovascular form of AMD is further bolstered by the findings from a study of ocular histoplasmosis (Ganley 1973), where neovascularization can result from the infection. In that study, smokers were twice as likely as nonsmokers to develop disciform scars. Moreover, in a clinical trial of photocoagulation to halt progression of neovascularization, smokers were more likely than nonsmokers to have recurrent neovascularization over time (Macular Photocoagulation Study Group 1986). However, smoking did not predict development of neovascularization in the previously unaffected companion eyes of the eyes with neovascularization (Macular Photocoagulation Study Group 1997).

#### Conclusions

1. The evidence is suggestive but not sufficient to infer a causal relationship between current and past smoking, especially heavy smoking, with risk of exudative (neovascular) age-related macular degeneration.
2. The evidence is suggestive but not sufficient to infer a causal relationship between smoking and atrophic age-related macular degeneration.

#### Implications

There is a need for more research into gender differences, dose-response relationships, and a possible threshold effect. Further research is also needed to determine the effect of smoking cessation on the risk of neovascular AMD.

### Diabetic Retinopathy

Diabetic retinopathy is a serious ocular complication of diabetes associated primarily with long-term duration of diabetes and poor control in both type 1 and type 2 diseases. The retinopathy is likely the result of vascular changes occurring in the retinal circulation that feeds the inner layers of the retina. Diabetic retinopathy in the early stages (mild, non-proliferative retinopathy) is characterized by excessive permeability of the vasculature, with ballooning of the retinal capillaries to form microaneurysms, dot hemorrhages, and hard and soft exudates. Preproliferative retinopathy includes, in addition to the aforementioned features, vascular occlusion and dilation and/or venous beading. Proliferative diabetic retinopathy is characterized by new vessel growth or fibrous proliferation or both. Vitreous hemorrhage secondary to the neovascularization also may be seen. Clinically significant macular edema, the result of extensive vessel leakage, can be a feature of chronic diabetic eye disease that may occur at any stage of the process. The prevalence of diabetic retinopathy increases with duration of diabetes, and most persons with diabetes have signs after 10 years’ duration. Moreover, diabetic retinopathy is an important cause of vision loss. Although photocoagulation is an effective means of treating proliferative diabetic retinopathy, too often the retinopathy is not diagnosed at an early stage when treatment can be maximally effective.

#### Biologic Basis

Several investigators have postulated that smoking may contribute to the onset of diabetic retinopathy and/or drive progression of existing retinopathy through its effect on the retinal circulation (Morgado et al. 1994). If such relationships exist, one mechanism of action is likely to be hypoxia from chronic exposure to carbon monoxide, which may be toxic to retinal vasculature. Carbon monoxide also is associated with separation of arterial endothelial cells, causing edema, which also is a feature of diabetic retinopathy. Nicotine exposure increases levels of plasma vasoconstrictors, such as angiotensin and vasopressin, which have binding sites on retinal blood vessels. In addition, nicotine exposure increases platelet adhesiveness, and persons with diabetic retinopathy are more likely to have increased platelet aggregation compared with persons with diabetes but without retinopathy. Although there is a reasonable biologic basis to the hypothesis that smoking is related to diabetic retinopathy, the data suggest otherwise.

#### Epidemiologic Evidence

Many studies have examined the association between smoking and diabetic retinopathy (Table 6.29), and the data from several studies do not support the proposed association. The well-controlled studies, including prospective cohort studies in large populations of persons with diabetes, found no association between smoking and the amount smoked and the prevalence, incidence, or progression of diabetic retinopathy (Klein et al. 1983; Moss et al. 1991, 1996). Studies that found an association in general did not adjust for level of control of diabetes, a major risk factor for diabetic retinopathy. One study did adjust for level of control and other risk factors and found an association between smoking and a six-year progression of diabetic retinopathy (Mühlhauser et al. 1996). However, progression was defined as any progression, from onset of diabetic retinopathy to becoming blind, if proliferative diabetic retinopathy was present at baseline. There were no data shown on whether smokers tended to have worse retinopathy at baseline, but the analyses should have adjusted for baseline status of diabetic retinopathy as a risk factor for progression. When the progression was confined to the subgroup with no retinopathy at baseline, smoking was not significantly associated with either the incidence or progression of diabetic retinopathy.

Table 6.29 Studies on the association between smoking and diabetic retinopathy (DR)

Study | Population | Design | Diabetes/DR assessment | Results
Paetkau et al. 1977 | 150 cases of diabetes | Cross-sectional; compared PDR^*^ cases with DR cases | NR^†^ | Smoking was associated with PDR in patients with a long duration of diabetes; there was no adjustment for level of control of diabetes
Christiansen 1978 | 180 patients with insulin-dependent juvenile-onset diabetes of different durations | Cross-sectional | Standard exam/clinical observer of DR | Smoking was not associated with DR or PDR
West et al. 1980 | 973 Native Americans with adult-onset diabetes | Cross-sectional | Standard exam/clinical exam for DR | Smoking was not associated with DR or PDR
Gray et al. 1982 | 194 patients with type 1 diabetes with varying levels of DR | Cross-sectional | Standard exam/not stated | Patients with DR were more likely to be smokers, likely explained by level of diabetes control; no dose-response pattern was noted
Klein et al. 1983 | 467 patients with younger-onset (diagnosed before 30 years of age and taking insulin) and 1,039 with adult-onset diabetes | Cross-sectional | Fasting glucose/fundus photographs graded according to the modified Arlie House Classification | There were no associations between smoking, pack-years^‡^, and DR or severity of DR
Telmer et al. 1984 | 688 patients with insulin-dependent diabetes with a duration of 12–40 years | Cross-sectional | Clinic records/clinical exam and fluorescein angiogram for PDR | Smoking, smoking dose, and former smoking were not associated with PDR
Rand et al. 1985 | 111 patients with insulin-dependent diabetes with PDR and 81 patients with diabetes with no or minimal DR | Case-control, matched for duration of diabetes | Standard exam/PDR on stereo fundus photographs graded according to the modified Arlie House Classification | Smoking was not associated with PDR
Sjolie 1985 | 577 insulin-treated patients with diabetes aged 10–70 years | Cross-sectional | Clinic reports/clinical exam for DR | There was an increased risk of any DR with smoking, OR^§^ = 1.9; not adjusted for control of diabetes
Walker et al. 1985 | 193 diabetic patients | Cross-sectional | Clinic records/clinical exam for DR | Smoking was related to DR in men, not in women; not adjusted for level of control of diabetes
Ballard et al. 1986 | Population-based group of 1,031 patients with adult-onset diabetes | Prospective, up to 20 years | Standard exam/DR by clinical exam | Smoking was not associated with incidence of DR or PDR
Mühlhauser et al. 1986 | 192 smokers and 192 nonsmokers with type 1 diabetes | Matched case-control | Clinic records/DR assessed by ophthalmologist | Smokers had more PDR compared with nonsmokers (12.5 vs. 6.8%); no increased risk of all DR; not adjusted for level of control of diabetes
Borch-Johnsen et al. 1987 | 184 survivors of long-term insulin-dependent diabetes participating in a prospective study | Cross-sectional | Clinic records/clinical exam, DR graded in nonstandard fashion | Smoking was not associated with DR or PDR
Kingsley et al. 1988 | 754 patients with insulin-dependent diabetes | Cross-sectional | Standard exam/58 patients had angiography, otherwise self-reported | There were no differences in percentages for smokers with and without severe retinopathy; there were no adjustments for other factors
Moss et al. 1991 | 668 patients with early-onset and 1,379 with adult-onset diabetes | 4-year prospective for incidence and progression of DR | Fasting glucose/fundus photographs graded according to modified Arlie system | Smoking was not associated with incidence or progression in either group with diabetes
Marshall et al. 1993 | 277 patients with type 1 diabetes with durations of ≥5 years | Prospective for ≥1 years (mean follow-up = 2.7 years) | Not stated/DR by fundus photographs graded according to modified Arlie classification | Smoking was not associated with a transition to DR in a consistent manner
Klein et al. 1995 | 765 patients with younger-onset (diagnosed under 30 years of age and taking insulin) and 533 with older-onset diabetes with a 10-year follow-up | 10-year prospective | Fasting glucose/fundus photographs graded according to modified Arlie system | 10-year incidence of diabetic macular edema was not related to smoking history
Moss et al. 1996 | 708 persons with early-onset and 987 with adult-onset diabetes | 10-year prospective for progression of DR | Fasting glucose/fundus photographs graded according to modified Arlie system | Pack-years, pack-years while diabetic, and smoking status were not associated with incidence and progression of DR or progression to PDR^*^
Mühlhauser et al. 1996 | 636 patients with type 1 diabetes | 6-year prospective for progression of DR | Standard exam for diabetes/DR by clinical exam and photographs; grading system not described | Pack-years smoked while diabetic were associated with any progression; not adjusted for baseline status: OR = 1.44/10 pack-years (95% confidence interval, 1.10–1.88); there were no associations of smoking variables with incidence of or progression to PDR in the group with no DR at baseline; adjusted for level of control and duration of diabetes
Sinha et al. 1997 | 100 patients with insulin-dependent diabetes (53 smokers) | Prospective for up to 6 years | NR | Smokers had more DR at baseline and follow-up; no adjustment for level of control of diabetes

* PDR = Proliferative diabetic retinopathy.

† NR = Data were not reported.

‡ Pack-years = The number of years of smoking multiplied by the number of packs of cigarettes smoked per day.

§ OR = Odds ratio.

#### Evidence Synthesis

Although smoking might plausibly worsen diabetic retinopathy, the evidence is inconsistent. The strongest studies, the prospective cohort studies, do not show an association. The level of diabetes control is a potential major confounder that has not been considered in a number of the studies.

#### Conclusion

1. The evidence is suggestive of no causal relationship between smoking and the onset or progression of retinopathy in persons with diabetes.

#### Implication

As research on diabetes continues, possible effects of smoking should be reassessed.

### Glaucoma

Glaucoma is the third leading cause of blindness worldwide (Thylefors et al. 1995). In the United States, African Americans and Hispanics are more affected than other groups. Glaucoma is a disease characterized by loss of retinal ganglion cells, probably through a variety of mechanisms. The two main types of primary glaucoma are primary open-angle glaucoma and angle closure glaucoma. The angle refers to the angle between the iris and trabecular meshwork in the anterior chamber, which if shallow or closed impedes outflow of aqueous fluid and causes a rise in pressure. There are distinct differences between the two types of glaucoma, and their distribution differs in populations. In the United States, primary open-angle glaucoma is the more common type.

#### Biologic Basis

There is no evident basis for proposing that smoking might predispose a person to either developing glaucoma or having more severe glaucoma. Investigators have proposed that factors that diminish perfusion of the optic nerve head with blood may be associated with glaucoma. Because smoking affects the retinal circulation (although any direct effect of smoking on the optic nerve head is unknown), several investigators have examined the association of glaucoma with smoking. However, the effects of smoking on blood flow in ocular circulation are difficult to measure, in part because studies often do not consider separating acute effects in smokers and nonsmokers from the chronic effects that result from repeated exposures. The role of smoking in altering intraocular pressure also is variable. In one study (Shephard et al. 1978), smoking (including cumulative consumption) was not associated with intraocular pressure differences.

#### Evidence Synthesis

The few epidemiologic studies conducted (Table 6.30) do not indicate any relationship between smoking and glaucoma. Three cross-sectional studies found no association between smoking and glaucoma (Klein et al. 1993a; Ponte et al. 1994; Leske et al. 1995), and one prospective cohort study found no increased risk of glaucomatous field loss among persons with ocular hypertension who smoked compared with those who did not smoke (Quigley et al. 1994). The association has not been evaluated in angle closure glaucoma, but there is little biologic basis for proposing such a relationship.

Table 6.30 Studies on the association between smoking and glaucoma

Study | Population | Design | Glaucoma assessment | Results
Morgan and Drance 1975 | Cases of glaucoma diagnosed by multiple ophthalmologists; neighborhood controls | Case-control | Data were not reported | Smoking was not related to glaucoma
Wilson et al. 1987 | 83 cases, 237 controls matched for age and gender | Case-control | Visual fields, cup and optic disc, and intra- ocular pressure on chart; controls without glaucoma | Smoking was related to glaucoma, odds ratio = 2.9 (95% confidence interval, 1.3–6.6)
Klein et al. 1993a | Population-based survey of 4,926 whites aged ≥43 years (104 cases of glaucoma) | Cross-sectional | Visual fields, intraocular pressure, and cup-to- disc ratio on photographs | Smoking was not related to glaucoma
Ponte et al. 1994 | 44 cases of glaucoma or elevated intra- ocular pressure (≥24 mm Hg); 220 controls with intraocular pressure <21 mm Hg | Cross-sectional | Visual fields and elevated intraocular pressure | Smoking was not related to glaucoma
Quigley et al. 1994 | 647 persons with ocular hypertension, followed for 1–12 years | Prospective | Intraocular pressure >21 mm Hg (ocular hypertension); visual field loss at follow-up | Smoking was not related to incident visual field loss
Leske et al. 1995 | Population-based study of 4,314 Barbadian blacks (302 glaucoma cases) | Cross-sectional | Visual fields and optic disc | Smoking was not related to glaucoma

#### Conclusion

1. The evidence is inadequate to infer the presence or absence of a causal relationship between smoking and glaucoma.

#### Implication

As further studies of glaucoma are undertaken, the role of smoking should remain under investigation.

### Other Eye Diseases: Graves’ Ophthalmopathy

Several other eye diseases have been investigated for an association with smoking. Most were not reviewed for this report, however, because the data are insufficient to reach any conclusions. The one exception is an uncommon condition—Graves’ ophthalmopathy, an ocular complication of Graves’ disease.

Graves’ disease is thought to be an autoimmune disease of the thyroid. It is likely that both genetic and environmental factors are related to the risk of the disease. Among its clinical manifestations, the ophthalmologic complications appear to be related to smoking. Graves’ ophthalmopathy is characterized by proptosis (protrusion of the eyeball), diplopia (double vision), optic neuropathy, and conjunctival and peri-orbital inflammation. The pathogenesis of Graves’ ophthalmopathy is not completely understood, but it appears to involve the orbital fibroblasts that are stimulated to release glycosaminoglycans, which in turn are related to the orbital edema seen with the ocular complications. Recent data suggest an autoimmune basis for Graves’ ophthalmopathy as well (Bahn 2000).

#### Biologic Basis

The mechanism by which smoking may cause or aggravate Graves’ ophthalmopathy is unknown. Orbital hypoxia and effects of thiocyanate have been postulated, and other research has investigated the effect of smoke constituents on orbital fibroblast activity. Researchers investigating the role of hypoxia in muscular inflammation have found stimulation of protein synthesis and proliferation of extra-ocular, muscle-derived fibroblasts under hypoxic conditions (Metcalfe and Weetman 1994). Smoking does not appear to affect serum concentrations of proinflammatory cytokines in Graves’ disease, even among persons with ocular complications (Salvi et al. 2000).

#### Epidemiologic Evidence

Seven studies (Table 6.31) found an increased risk associated with smoking of developing the ophthalmologic complications of Graves’ disease (Hägg and Asplund 1987; Shine et al. 1990; Tellez et al. 1992; Prummel and Wiersinga 1993; Winsa et al. 1993; Pfeilschifter and Ziegler 1996; Bartalena et al. 1998); three found a dose-response relationship with the number of cigarettes smoked (Shine et al. 1990; Tellez et al. 1992; Pfeilschifter and Ziegler 1996). The studies, while consistent, are limited in number and the sample sizes of some are small. The severity of the ophthalmopathy was associated with smoking in two studies (Prummel and Wiersinga 1993; Winsa et al. 1993). Estimates of the OR varied between 2 and 10, depending on the control population selected. The effect of quitting smoking on Graves’ ophthalmopa-thy has not been well studied and would provide convincing evidence of a causal relationship. On the basis of the findings of the epidemiologic studies, several investigators are studying the effect of smoking on the thyroid gland and the extra-ocular, muscle-derived fibroblasts.

Table 6.31 Studies on the association between smoking and Graves’ ophthalmopathy

Study | Population | Design | Diagnosis of ophthalmopathy | Results
Hägg and Asplund 1987 | 12 persons with Graves’ ophthalmopathy, 24 controls with Graves’ disease and no ophthalmopathy, 48 population controls | Case-control | Clinical exam | Smoking increased the OR^*^ of ophthalmopathy compared with no ophthalmopathy among persons with Graves’ disease, OR = 10.0 (95% CI^†^, 1.4–74.3), and with population controls, OR = 20.2 (95% CI, 2.8–144.8)
Shine et al. 1990 | 85 patients with ophthalmopathy, 62 with Graves’ disease, 81 controls without Graves’ disease | Case-control | Clinical exam | Cases of ophthalmopathy were more likely to be smokers than healthy controls or controls without ophthalmopathy; dose-response pattern was reported
Tellez et al. 1992 | 155 patients with newly diagnosed Graves’ disease | Cross-sectional | Clinical exam, using American Thyroid Association Classification system | Ophthalmopathy prevalence was higher in smokers and in former smokers, OR = 2.4 (95% CI, 1.1–5.2); there was a dose-response pattern with cigarette-years^‡^
Prummel and Wiersinga 1993 | 100 cases of Graves’ ophthalmopathy, 100 cases of Graves’ disease without ophthalmopathy, 175 cases of goiter, 75 cases of hyperthyroidism, 400 controls | Case-control | Clinical exam | Graves’ ophthalmopathy cases and severe cases (classified by total eye score) were adjusted for gender, age, and education, and were more likely to be smokers, OR = 6.5 (95% CI, 3.8–11.2), compared with controls; there was no dose- response pattern with an increasing severity of eye disease; smoking was not associated with other thyroid diseases
Winsa et al. 1993 | 208 patients with newly diagnosed Graves’ disease and 72 cases of Graves’ with ophthalmopathy | Cross-sectional | Clinical exam | Patients with ophthalmopathy were more likely to be current and former smokers compared with patients without ophthalmopathy, 63 vs. 45%; there was an increased prevalence of smoking with an increase in the severity of ophthalmopathy
Pfeilschifter and Ziegler 1996 | 253 patients with recent onset of Graves’ disease | ≥1 year prospective | Clinical exam/ patient report of double vision (diplopia) and exophthalmometer readings >20 mm (proptosis) | Current smoking was associated with incidence of symptomatic ophthalmopathy, OR = 1.3 (95% CI, 1.1–1.6), proptosis, OR = 2.6 (95% CI, 1.8–3.9), and diplopia, OR = 3.1 (95% CI, 1.7–6.0); there was a dose-response relationship; former smokers had no increased risk
Bartalena et al. 1998 | 300 patients with mild ophthalmopathy receiving 1 of 2 treatments, 150 patients with severe ophthalmopathy | Prospective, for risk of progression | Degree of ophthalmopathy assessed by clinical exam, masked to smoking status | Mild ophthalmopathy was more likely to progress among smokers and less likely to improve with treatment; severe ophthalmopathy was less likely to respond to treatment among smokers

* OR = Odds ratio.

† CI = Confidence interval.

‡ Cigarette-years = The number of years of smoking multiplied by the number of cigarettes smoked per day.

#### Evidence Synthesis

Although there are suggestive epidemiologic findings, the biologic basis for a role of smoking in Graves’ ophthalmopathy is unclear. The epidemiologic data are still limited, although consistent in indicating an increased risk in smokers. Dose-response is not well documented.

#### Conclusion

1. The evidence is suggestive but not sufficient to infer a causal relationship between ophthalmopa-thy associated with Graves’ disease and smoking.

#### Implication

Data on the role of smoking cessation in preventing or lessening the severity of the ophthalmopathy would be important to understanding the relationship between Graves’ disease and smoking.

## Peptic Ulcer Disease

In the early 1990s, the central role played by the bacterium Helicobacter pylori (H. pylori) in both the incidence and recurrence of peptic ulcer disease was recognized (Kuipers et al. 1995). This section reviews the evidence of an association between smoking and peptic ulcer disease in light of this new understanding of the pathogenesis of ulcer disease. Relevant articles were identified through a MEDLINE search from 1985 through June 2000 using the following terms: “ulcer and smoking and pylori” and “smoking and pylori and eradication.” A further search was performed for the years 1998 through June 2000, using the terms “ulcer and smoking” to identify any major studies that were not included in the previous Surgeon General’s report (USDHHS 2001), even though the studies had not evaluated H. pylori.

### Conclusions of Previous Surgeon General’s Reports

Numerous studies have demonstrated an association between smoking and the occurrence of peptic ulcer disease. This evidence was reviewed in the 1964, 1971, and 1972 Surgeon General’s reports on smoking and health (USDHEW 1964, 1971, 1972). The 1979 report concluded that cigarette smoking was significantly associated with both the incidence and an increased risk of dying from peptic ulcer disease: “the association between smoking and peptic ulcer disease is significant enough to suggest a causal relationship” (USDHEW 1979, p. 1–23). In addition, that report concluded that there was highly suggestive evidence that smoking also retards ulcer healing. The 1990 report concluded that smokers had an increased risk of developing both duodenal and gastric ulcers, and smoking cessation reduced that risk (USDHHS 1990). That report also found that among smokers ulcer disease was more severe, duodenal ulcers were less likely to heal, and both duodenal and gastric ulcers were more likely to recur. Ulcer patients who stopped smoking, however, were found to have an improved clinical course compared with continuing smokers. Although much of this previous evidence was based largely on studies of men, the more recent Surgeon General’s report on women and smoking (USDHHS 2001) concluded that women who smoked also had an increased risk of peptic ulcer disease.

### Biologic Basis

In the decades since the 1964 Surgeon General’s report, explanations of the pathogenesis of peptic ulcer disease have changed dramatically with the identification of the gastric bacterium H. pylori in a high proportion of patients with peptic ulcers (Marshall and Warren 1984). Up to 100 percent of duodenal ulcers and 70 to 90 percent of gastric ulcers are now associated with H. pylori infection (Kuipers et al. 1995). Most ulcers in persons without H. pylori infection were linked to the use of nonsteroidal anti-inflammatory drugs (NSAIDs) (Borody et al. 1991, 1992a). Other causes of peptic ulcers, although rarer, include Crohn’s disease and Zollinger-Ellison syndrome.

Normally, the gastrointestinal mucosa is protected from injury by, among other factors, a layer of mucus and the secretion of bicarbonate by gastric and duodenal epithelial cells to neutralize gastric acid. If these protective mechanisms are impaired, or if there is an increase in levels of damaging factors, then ulceration may occur.

#### Effects of Smoking on Gastrointestinal Physiology

The 1990 Surgeon General’s report (USDHHS 1990) reviewed the effects of cigarette smoking on aspects of human gastrointestinal physiology relevant to peptic ulcer disease. Likely mechanisms whereby smoking could promote the development of peptic ulcer disease included the potential for tobacco smoke and/or nicotine to increase maximal gastric acid output and duodenogastric reflux and to decrease alkaline pancreatic secretion and prostaglandin synthesis.

Two subsequent reviews (Endoh and Leung 1994; Eastwood 1997) evaluating the potential effects of cigarette smoke and nicotine as injurious and protective factors that could play a role in peptic ulcer formation came to similar conclusions. Data on the effects of smoking on gastric acid secretion in humans have been highly inconsistent; multiple reports found that smoking and/or nicotine variously stimulated, inhibited, or had no effect on gastric acid secretion. However, there was more consistent evidence that smoking promotes reflux of duodenal contents into the stomach, and increases production of free radicals and the release of vasopressin, a potent vasoconstrictor. Protective mechanisms consistently affected by smoking were the chronic inhibition of gastric mucus secretion, cytoprotective prostaglandin production, pancreatic and duodenal mucosal bicarbonate secretion, and a decrease in mucosal blood flow.

The mucosal protection mechanism most clearly affected by smoking is the pancreatic secretion of bicarbonate. A transient reduction in secretion is seen immediately after smoking, leading to a drop in pH in the duodenal bulb (Eastwood 1997). Acidity in the duodenal bulb appears to be the most important determinant for the development of gastric metaplasia in the duodenum, thus paving the way for duodenal colonization by H. pylori (Tytgat et al. 1993).

Results from studies evaluating mucosal blood flow among smokers and nonsmokers have been more varied, possibly because of a variation in the measurement methods. Taha and colleagues (1993) demonstrated that both gastric and duodenal mucosal blood flow were reduced in chronic NSAID users. However, after allowing for NSAID use, significantly reduced duodenal blood flow was seen only in H. pylori-positive smokers. There was no additional effect of either H. pylori infection or smoking on gastric mucosal blood flow.

Finally, some strains of H. pylori produce a vacuolating toxin that may be important in determining the virulence of the organism. This toxin induces vacuolation of HeLa cells in vitro, as does nicotine alone, but the addition of nicotine to H. pylori potentiates the vacuolating effect of the toxin (Cover et al. 1992).

In summary, studies document that smoking appears to have a multitude of effects on gastroduodenal physiology, and through a number of mechanisms it could promote peptic ulceration. These effects are, however, largely transient, and the affected physiologic measures return to normal within minutes or hours after smoking cessation (Eastwood 1997). These same studies also indicate that smoking could particularly increase the likelihood of ulceration in H. pylori-positive persons.

#### Smoking and Helicobacter pylori Infection

Both H. pylori infection (Malaty et al. 1992; EUROGAST Study Group 1993) and smoking (Bergen and Caporaso 1999) are more common among groups of lower SES. Cross-sectional studies that have evaluated the association between H. pylori infection and smoking in healthy volunteers consistently have reported higher infection rates in smokers (current or former) than in nonsmokers. In a study of 485 volunteers in the United States, current and former smokers were more likely to be seropositive for H. pylori than nonsmokers (among blacks, rates were 73 percent among current smokers, 85 percent among former smokers, and 61 percent among nonsmokers; and among whites, rates were 40 percent, 48 percent, and 25 percent, respectively) (Graham et al. 1991). Infection also was slightly more common among 3,496 adult smokers in Northern Ireland (65 percent among former smokers, 57 percent among smokers of fewer than 20 cigarettes, and 64 percent among smokers of 20 or more cigarettes per day compared with 53 percent among people who had never smoked) (Murray et al. 1997). Similar findings were seen in a group of 273 adults from Melbourne, Australia, among current and former smokers (45 percent and 44 percent, respectively, compared with 31 percent in people who had never smoked) (Lin et al. 1998) and among 1,064 adult heavy smokers in New Zealand (38 percent in smokers of more than 20 cigarettes per day compared with 23 percent in smokers of less than 20 cigarettes per day and nonsmokers) (Collett et al. 1999). Similar patterns have been reported in adults visiting general practitioners in Germany (Brenner et al. 1997) and in patients receiving an endoscopic examination in the United Kingdom (Bateson 1993) and Malaysia (Goh 1997).

In some of these studies, the association between H. pylori and smoking was attenuated after adjusting for other factors, including age and SES. In both developed and developing countries, H. pylori infection is believed to occur during childhood (Xia and Talley 1997), and thus it is unlikely that smoking influences the risk of initial H. pylori infection to any great extent. It is unclear whether smoking could be a risk factor for the acquisition or persistence of H. pylori infection in adulthood or if low SES is a common, more distal risk factor for both H. pylori and smoking. These variables do not, however, alter the fact that smokers are more likely than nonsmokers to be infected with H. pylori. The link between H. pylori and peptic ulcer disease is well established; thus, it is important to consider whether smoking also is a risk factor or if some or all of the observed associations between smoking and peptic ulcer disease could be due to confounding by H. pylori infection status.

### Trends in Peptic Ulcer Disease

During the past several decades, rates of hospitalization for and mortality from peptic ulcer disease in the United States have declined dramatically. Using hospitalization rates from the computerized database of the U.S. Department of Veterans Affairs, El-Serag and Sonnenberg (1998) showed that although gastric ulcers accounted for 67.6 and duodenal ulcers for 168.8 out of every 10,000 hospitalizations of veterans from 1970–1974, comparable figures for 1990–1995 were 49.6 per 10,000 and 52.5 per 10,000, respectively. Similarly, using vital statistics data from CDC’s National Center for Health Statistics, these two authors showed that mortality from gastric ulcer disease had fallen from 17.4 per million per year in 1968–1972 to 7.7 per million per year in 1988–1992, with a comparable drop in mortality for duodenal ulcer disease from 19.6 to 8.4 per million per year (El-Serag and Sonnenberg 1998). However, peptic ulcer disease still is a leading cause of morbidity. In 1989, the National Health Interview Survey included a special questionnaire on digestive diseases. Among approximately 42,000 adult respondents, 10 percent reported that they had ever had a physician-diagnosed peptic ulcer, one-third of whom also reported having a new or recurring ulcer in the past 12 months (Sonnenberg and Everhart 1996). Among the 50 percent who reported the site of their ulcer, gastric and duodenal ulcers were equally common overall, although nonwhites reported gastric ulcers more frequently and duodenal ulcers less frequently than whites. When recurrent ulcers (defined as a relapse in the past 12 months of a previously diagnosed ulcer) were excluded, the incidence of new peptic ulcers in 1989 was an estimated 52.7 per 10,000 (Everhart et al. 1998). Among those respondents who specified the site of the ulcer, the incidence of gastric ulcers (17.0 per 10,000) was about three times that of duodenal ulcers (6.1 per 10,000). This finding suggests that the incidence of new duodenal ulcers may have fallen more rapidly over time than that of gastric ulcers.

A large part of the decrease in peptic ulcer rates over the last few decades in the United States has been attributed to lower smoking rates (Kurata et al. 1986), although the same pattern was not seen in the United Kingdom (Sonnenberg 1986). However, the prevalence of H. pylori infection in developed countries also is believed to have declined over a similar time period (Banatvala et al. 1993; Kosunen et al. 1997), and it is this decline, rather than falling smoking rates, that may explain some or all of the reductions in ulcer rates.

### Epidemiologic Evidence

#### Smoking and Development of Peptic Ulcer

Studies that evaluated the relationship between tobacco smoking and the development of peptic ulcer disease repeatedly have shown an increased risk of both duodenal and gastric ulcers among smokers (USDHEW 1979; USDHHS 1990). In some studies, this risk also has been observed to increase with increasing levels of smoking. During a 149,291 person-years follow-up of a cohort of 7,624 Japanese men in Hawaii, the age-adjusted incidence of gastric and duodenal ulcers increased with increasing levels of smoking at baseline (RR among nonsmokers and smokers of less than 24, 24 through 40, and greater than 40 pack-years: 1.0, 1.5, 3.1, and 3.8 [P_trend_ <0.01], respectively, for gastric ulcers and 1.0, 1.8, 2.4, and 3.3 [P_trend_ <0.01], respectively, for duodenal ulcers [Kato et al. 1992]). In contrast, an analysis of self-reported ulcer history, using data from the 1989 National Health Interview Survey in the United States, suggested that smoking may be a stronger risk factor for chronic ulceration than for the development of new ulcers (Everhart et al. 1998). Although these data show a strong relation between smoking and age-standardized prevalence of chronic active ulcers (1.8 percent, 3.0 percent, 3.9 percent, and 5.3 percent among nonsmokers and smokers of <20, 20, and >20 cigarettes per day, respectively), there was no association between smoking and the incidence of new ulcers.

##### Helicobacter pylori, Smoking, and Peptic Ulcer

Only a few studies have considered both smoking and H. pylori infection in relation to the incidence of peptic ulcer disease (Table 6.32). These studies largely have been cross-sectional surveys of patients referred for upper gastrointestinal endoscopy using variable definitions of smoking, and rarely presenting results that distinguished between smokers with and without H. pylori infection. No studies have separately evaluated the risk of peptic ulcers in former smokers after allowing for H. pylori infection.

Table 6.32 Studies on the association between smoking and peptic ulcer disease, allowing for Helicobacter pylori (H. pylori) infection

Study/location | Population | Definition of smoking | Results
Martin et al. 1989 United States | 107 patients referred for endoscopy, including 14 with duodenal ulcers, 14 with gastric ulcers, and 19 healthy volunteers | >10 cigarettes/day | Prevalence of peptic ulcers among H. pylori-positive patients:
Martin et al. 1989 United States | 107 patients referred for endoscopy, including 14 with duodenal ulcers, 14 with gastric ulcers, and 19 healthy volunteers | >10 cigarettes/day | Smokers | 73%
Martin et al. 1989 United States | 107 patients referred for endoscopy, including 14 with duodenal ulcers, 14 with gastric ulcers, and 19 healthy volunteers | >10 cigarettes/day | Nonsmokers | 27% (p <0.01)
Schubert et al. 1993 United States | 1,088 patients referred for endoscopy, including 107 with duodenal ulcer, 97 with gastric ulcer, and 5 with both duodenal and gastric ulcers | At least 1 cigarette 4 weeks before endoscopy | No significant association was found between smoking and peptic ulcer: prevalence of smoking was 36.7% among ulcer-free group, 42.9% among duodenal ulcer group, and 34.0% among gastric ulcer group (no adjusted estimates provided)
Schlemper et al. 1996 Japan and the Netherlands | 215 Japanese and 493 Dutch employees in companies with periodic health screening, including 57 with past peptic ulcers (median 6 years since diagnosis) and 4 with current peptic ulcers | Daily smoking at time of interview | OR (95% CI) adjusted for age, H. pylori infection, family history of peptic ulcers, and occupation, smokers vs. nonsmokers:
Schlemper et al. 1996 Japan and the Netherlands | 215 Japanese and 493 Dutch employees in companies with periodic health screening, including 57 with past peptic ulcers (median 6 years since diagnosis) and 4 with current peptic ulcers | Daily smoking at time of interview | Netherlands (men only) | 1.6 (0.5–4.9)
Schlemper et al. 1996 Japan and the Netherlands | 215 Japanese and 493 Dutch employees in companies with periodic health screening, including 57 with past peptic ulcers (median 6 years since diagnosis) and 4 with current peptic ulcers | Daily smoking at time of interview | Japan (men and women) | 0.8 (0.3–1.8)
Schlemper et al. 1996 Japan and the Netherlands | 215 Japanese and 493 Dutch employees in companies with periodic health screening, including 57 with past peptic ulcers (median 6 years since diagnosis) and 4 with current peptic ulcers | Daily smoking at time of interview | | 0.2 (0.1–0.9), duodenal ulcer only
Wang et al. 1996 China | Factory employees: 500 (422 men) with any peptic ulcer within previous 2 years and 500 (396 men) ulcer-free employees | Current (≤15 and >15 cigarettes/day); former smokers excluded | OR^*^ (95% CI^†^) adjusted for age, H. pylori infection, and family history of peptic ulcer among smokers vs. never smokers, by occupation group (men only):
Wang et al. 1996 China | Factory employees: 500 (422 men) with any peptic ulcer within previous 2 years and 500 (396 men) ulcer-free employees | Current (≤15 and >15 cigarettes/day); former smokers excluded | | [underlined: Workers/drivers] | [underlined: Staff]
Wang et al. 1996 China | Factory employees: 500 (422 men) with any peptic ulcer within previous 2 years and 500 (396 men) ulcer-free employees | Current (≤15 and >15 cigarettes/day); former smokers excluded | Any peptic ulcer
Wang et al. 1996 China | Factory employees: 500 (422 men) with any peptic ulcer within previous 2 years and 500 (396 men) ulcer-free employees | Current (≤15 and >15 cigarettes/day); former smokers excluded | ≤15 cigarettes/day | 3.85 (2.29–6.48) | 1.24 (0.65–2.39)
Wang et al. 1996 China | Factory employees: 500 (422 men) with any peptic ulcer within previous 2 years and 500 (396 men) ulcer-free employees | Current (≤15 and >15 cigarettes/day); former smokers excluded | >15 cigarettes/day | 5.30 (3.10–9.05) | 1.47 (0.66–3.27)
Wang et al. 1996 China | Factory employees: 500 (422 men) with any peptic ulcer within previous 2 years and 500 (396 men) ulcer-free employees | Current (≤15 and >15 cigarettes/day); former smokers excluded | Duodenal ulcer
Wang et al. 1996 China | Factory employees: 500 (422 men) with any peptic ulcer within previous 2 years and 500 (396 men) ulcer-free employees | Current (≤15 and >15 cigarettes/day); former smokers excluded | ≤15 cigarettes/day | 3.38 (1.97–5.79) | 1.36 (0.68–2.72)
Wang et al. 1996 China | Factory employees: 500 (422 men) with any peptic ulcer within previous 2 years and 500 (396 men) ulcer-free employees | Current (≤15 and >15 cigarettes/day); former smokers excluded | >15 cigarettes/day | 4.34 (2.49–7.57) | 1.36 (0.57–3.22)
Talamini et al. 1997 Italy | 495 patients referred for endoscopy, including 69 with duodenal ulcers and 23 with gastric ulcers | 1–10 or >10 cigarettes/day | Percentage of those with duodenal ulcer: nonsmokers, 10.8%; smokers 1–10 cigarettes/day, 15.4%; and >10 cigarettes/day, 25.6%; p <0.001
Talamini et al. 1997 Italy | 495 patients referred for endoscopy, including 69 with duodenal ulcers and 23 with gastric ulcers | 1–10 or >10 cigarettes/day | OR (95% CI) adjusted for gender and H. pylori infection, smokers vs. nonsmokers:
Talamini et al. 1997 Italy | 495 patients referred for endoscopy, including 69 with duodenal ulcers and 23 with gastric ulcers | 1–10 or >10 cigarettes/day | Duodenal ulcer vs. rest (including gastric ulcer)
Talamini et al. 1997 Italy | 495 patients referred for endoscopy, including 69 with duodenal ulcers and 23 with gastric ulcers | 1–10 or >10 cigarettes/day | 1–10 cigarettes/day | 1.35 (0.57–1.38)
Talamini et al. 1997 Italy | 495 patients referred for endoscopy, including 69 with duodenal ulcers and 23 with gastric ulcers | 1–10 or >10 cigarettes/day | >10 cigarettes/day | 2.53 (1.35–4.74)
Halter and Brignoli 1998 Switzerland | 282 patients referred for endoscopy, including 24 with duodenal ulcers and 5 with gastric ulcers | Data were not reported | Crude OR (95% CI) vs. for each group vs. other 3 groups combined:
Halter and Brignoli 1998 Switzerland | 282 patients referred for endoscopy, including 24 with duodenal ulcers and 5 with gastric ulcers | Data were not reported | Duodenal ulcer vs. rest (including gastric ulcer)
Halter and Brignoli 1998 Switzerland | 282 patients referred for endoscopy, including 24 with duodenal ulcers and 5 with gastric ulcers | Data were not reported | H. pylori-negative nonsmokers | 0.13 (0.02–0.93)
Halter and Brignoli 1998 Switzerland | 282 patients referred for endoscopy, including 24 with duodenal ulcers and 5 with gastric ulcers | Data were not reported | H. pylori-negative smokers | 0.37 (not reported)
Halter and Brignoli 1998 Switzerland | 282 patients referred for endoscopy, including 24 with duodenal ulcers and 5 with gastric ulcers | Data were not reported | H. pylori-positive nonsmokers | 0.94 (not reported)
Halter and Brignoli 1998 Switzerland | 282 patients referred for endoscopy, including 24 with duodenal ulcers and 5 with gastric ulcers | Data were not reported | H. pylori-positive smokers | 5.53 (1.97–15.53)

* OR = Odds ratio.

† CI = Confidence interval.

Four of these studies were conducted with groups receiving endoscopic examinations. Martin and colleagues (1989) found no duodenal ulcers in 47 H. pylori-negative persons although 4 of them, all of whom were taking NSAIDs, had a gastric ulcer. Among the 60 H. pylori-positive persons, peptic ulcers were significantly more common in smokers than in non-smokers. Similarly, Talamini and colleagues (1997) reported a significant association between duodenal ulcers and smoking after adjusting for H. pylori infection. In a Swiss study, smoking also appeared to be associated with an increased risk of duodenal ulcers, particularly among H. pylori-positive persons (Halter and Brignoli 1998). The lack of a single reference group in this study, however, makes comparisons with other studies difficult. In contrast, Schubert and colleagues (1993) reported no significant differences between the proportion of smokers in patients with and without ulcers and, as a consequence, did not include smoking status in their multivariable models adjusting for H. pylori. It is possible, however, that the very broad definition of smoking used in this last study may have led to very light or occasional smokers being inappropriately classified as smokers, thus masking differences between patients with and without ulcers.

Two other studies used groups of company employees. Wang and colleagues (1996) conducted a case-control study in a factory in Shanghai, China. To prevent confounding by SES and gender, data were analyzed separately for men and women, drivers and workers (lower SES), and staff (higher SES). Among male workers and drivers (304 cases and 263 controls), current smoking was associated with a significantly elevated risk of peptic ulcer disease that increased with the amount of cigarettes smoked. A similar pattern was seen for duodenal ulcer disease alone. There was only one female employee smoker, and too few former smokers to evaluate risks in those groups. Although smoking status was assessed after the development of ulcers, smoking rates were high and few workers reported having stopped smoking. It is therefore unlikely that many employees changed their smoking behavior following ulcer diagnosis.

Schlemper and colleagues (1996) conducted parallel studies in companies in Japan and the Netherlands. Men and women with verifiable ulcer disease who had not been treated with H. pylori eradication therapy were compared with those without ulcers or prior gastric surgery. After adjusting for potential confounders, researchers found that daily smoking was associated with a nonsignificant increased risk of peptic ulcer disease only in the Dutch population. In this study, the majority of ulcers had been diagnosed a median of six years before smoking data were collected, and it is possible that employees with peptic ulcer disease may have changed their smoking behaviors over time.

There is a potential for bias in any of these studies if participants altered their smoking behaviors because of ulcer symptoms or if they misreported their smoking patterns. If ulcer patients tend to stop or reduce their smoking because of symptoms, or if they systematically underreport the amount they smoke, then the true associations between smoking and ulcers could be greater than those reported. Conversely, if ulcer patients actually increase their smoking in response to ulcer symptoms or if they systematically overreport the amount they smoke, then the observed associations could exaggerate the true effect. This latter situation would seem less likely than the former.

##### Nonsteroidal Anti-Inflammatory Drugs, Smoking, and Peptic Ulcer

The main cause of ulcers in persons negative for H. pylori infection, at least in developed countries, is the use of NSAIDs (Borody et al. 1991, 1992a). In the 1990 Surgeon General’s report (USDHHS 1990), smoking was associated with peptic ulcer disease and acute gastric erosions in three studies of NSAID users. Since then, three more studies have evaluated the relationship between smoking and peptic ulcers in NSAID users, with conflicting results.

Hansen and colleagues (1996) compared 94 NSAID users admitted to a hospital with complications of peptic ulcers (predominantly bleeding or perforated ulcers) with 324 controls selected at random from all assumed NSAID users. Overall, cases were no more likely than controls to be smokers (44 percent and 41 percent, respectively), but after adjusting for age, gender, ulcer history, and duration of NSAID use, current smoking was associated with an almost twofold increased risk of ulcer complications (OR = 1.9 [95 percent CI, 1.0–3.6]).

In contrast, Aalykke and colleagues (1999) compared 132 current NSAID users diagnosed with bleeding peptic ulcers with 136 ulcer-free NSAID users selected from a rheumatology clinic and geriatrics department. Smokers were not at an increased risk of developing bleeding ulcers compared with controls (OR, adjusted for age, gender, ulcer history, H. pylori infection status, and NSAID dose = 0.91 [95 percent CI, 0.48–1.71]). Similarly, in a large case-control study in the United Kingdom, Weil and colleagues (2000) compared 1,121 patients diagnosed with bleeding peptic ulcers with 989 community controls. Information on H. pylori infection status was not available, but among NSAID users the risk for bleeding peptic ulcers (compared with nonsmokers who did not use NSAIDs) did not differ appreciably between current smokers (OR = 4.0 [95 percent CI, 2.9–5.5]) and non-smokers (OR = 3.6 [95 percent CI, 2.9–4.5]).

#### Mortality from Peptic Ulcer

Large-scale cohort studies consistently have shown that smokers are at a greater risk of dying from peptic ulcer disease than nonsmokers (USDHHS 1990). Follow-up of the U.S. Veterans Study now has been extended to 26 years, with a total of 5.4 million person-years. Smoking information was collected only at baseline. To allow for the fact that many current smokers at baseline subsequently would have stopped smoking, the analysis was restricted to people who never smoked (who were unlikely to have started smoking) and to former smokers at baseline. Former smokers had elevated risks for mortality from both duodenal ulcer disease (OR = 1.8 [95 percent CI, 1.3–2.4]) and gastric ulcer disease (1.6 [1.1–2.2]) (NIH 1997). During follow-up of the British doctors cohort, information about smoking behaviors was collected at baseline in 1951 and again in 1957, 1966, 1972, 1978, and 1990. After 40 years, mortality from peptic ulcer disease was 8 per 100,000 per year among men who had never smoked cigarettes; 12 per 100,000 per year among former smokers; and 11, 33, and 34 per 100,000 per year among current smokers of 1 to 14, 15 to 24, and 25 or more cigarettes per day, respectively (p <0.001) (Doll et al. 1994). None of these studies, however, could explore possible confounding of this association by H. pylori infection.

#### Effect of Smoking on Ulcer Severity

Ulcers may be more severe and complications may occur more frequently among continuing smokers (USDHHS 1990). Hasebe and colleagues (1998) compared 35 patients with deep gastric ulcers (ulceration beyond the muscularis propria) and 33 patients with shallow and intermediate depth ulcers (ulceration in submucosa and muscularis propria) in Japan. They found that patients with deep ulcers were more likely to be heavy smokers, defined as smoking 20 or more cigarettes per day, than patients with shallower ulcers (81 percent versus 55 percent, p <0.05). However, patients with deep ulcers also were significantly more likely to drink alcohol on a daily basis (40 percent versus 27 percent, p <0.05) and to have H. pylori infections (97 percent versus 79 percent, p <0.01), so it is possible that these differences could explain some or all of the associations with smoking.

##### Smoking and Peptic Ulcer Complications

Svanes and colleagues (1997) compared patients diagnosed with perforated peptic ulcers with population controls (90 percent response rate) in Norway. Analyses of smoking were restricted to cases (36 gastric perforation and 73 duodenal perforation) and controls (n = 4,270) aged 15 through 74 years because smoking was rare in older patients. After adjusting for age and gender, the risk of perforated ulcers in current smokers increased significantly with the number of cigarettes smoked per day. The ORs were 7.3 (95 percent CI, 4.0–18.1) for smokers of 1 to 9 cigarettes per day, 8.7 (95 percent CI, 5.5–14.4) for smokers of 10 to 19 cigarettes per day, and 11.2 (95 percent CI, 6.3–27.5) for smokers of 20 or more cigarettes per day (p <0.001) compared with people who had never smoked. The risk among former smokers was no greater than that among those who had never smoked (OR = 0.8 [95 percent CI, 0.2–2.2]). Smokers were less likely than nonsmokers to have used NSAIDs or other ulcerogenic drugs. Thus, variation in NSAID use could not explain the relationship with smoking. The high alcohol consumption, however, which was significantly more common among current smokers (25 percent versus 4 percent among nonsmokers), could possibly explain some of the strong associations between smoking and perforated ulcers. H. pylori infection was not assessed, but among the cases, 87 percent of smokers and 96 percent of nonsmokers reported previous “ulcer dyspepsia,” suggesting that infection rates probably were high in both groups.

Lanas and colleagues (1997) conducted a similar study in Spain, comparing 76 patients with gastrointestinal perforation (including 31 with duodenal ulcers and 28 with gastric ulcers) with matched hospital and community controls. After adjusting for the use of NSAIDs and alcohol and histories of ulcers and arthritis, smoking was again associated with a significantly increased risk of perforated ulcers (p = 0.003). In Italy, Labenz and colleagues (1999) compared 72 patients admitted with bleeding peptic ulcers with matched hospital controls. After adjusting for H. pylori infection status, NSAID use, and alcohol intake, smoking was associated with a nonsignificant 40 percent increased risk of bleeding ulcers (OR = 1.4 [95 percent CI, 0.5–3.6]).

In the large case-control study conducted by Weil and colleagues (2000) in the United Kingdom, overall current smoking was associated with a 60 percent increased risk of bleeding peptic ulcers (OR = 1.6 [95 percent CI, 1.2–2.0]). This risk appeared to differ, however, between users and nonusers of NSAIDs. Among NSAID nonusers, smoking was associated with an almost twofold increased risk of bleeding ulcers (OR = 1.9 [95 percent CI, 1.4–2.4]). In contrast, the risk for peptic ulcers in NSAID users did not differ appreciably between current and nonsmokers as described above.

#### Effect of Smoking on Ulcer Healing and Recurrence

##### Ulcer Healing

Many studies have shown that smoking adversely affects healing of duodenal ulcers by acid-reducing agents (Lam 1990; USDHHS 1990). It does not appear, however, to have the same adverse effect on healing by other agents, including sucralfate (Lam 1991) or colloidal bismuth subcitrate (Lam 1991; Lambert 1991). In a meta-analysis, data from six studies of sucralfate were combined, giving overall healing rates of 78 percent among 301 smokers and 78 percent among 272 nonsmokers (Lam 1991). In the same analysis, data also were pooled from three studies of colloidal bismuth subcitrate, giving healing rates of 82 percent among 55 smokers and 76 percent among 38 nonsmokers. Less consistent results were reported for the effects of smoking on gastric ulcer healing, although studies evaluating the benefits of smoking cessation have suggested that ulcer patients who stop smoking do better than patients who continue to smoke (USDHHS 1990).

Rates of ulcer healing are significantly higher (Hentschel et al. 1993; Labenz and Börsch 1994) and recurrence rates significantly lower (Rauws and Tytgat 1995) among patients with ulcers (gastric or duodenal) who received H. pylori eradication therapy, which now is the recommended treatment for patients with H. pylori infection (NIH 1997). The combined effects of smoking and H. pylori eradication on ulcer healing in the short term have not been directly evaluated; however, in three studies of ulcer patients treated with H. pylori eradication therapy, there were no significant differences in ulcer healing rates between smokers and nonsmokers (O’Connor et al. 1995; Bardhan et al. 1997; Kadayifçi and Simsek 1997). O’Connor and colleagues (1995) reported healing rates for gastric and duodenal ulcers of 83 percent for smokers compared with 92 percent for nonsmokers (p = 0.3); the H. pylori eradication rate also was slightly lower among smokers (83 percent versus 94 percent, p = 0.2), possibly explaining the slightly different healing rates. Bardhan and colleagues (1997) reported duodenal ulcer healing in 96 percent of smokers compared with 94 percent of nonsmokers (p = 0.6), whereas rates of H. pylori eradication were slightly higher for nonsmokers (77 percent versus 71 percent, p = 0.5). Kadayifçi and Simsek (1997) reported duodenal ulcer healing in 82 percent and 83 percent of heavy (more than 20 cigarettes per day) and mild (1 to 20 cigarettes per day) smokers, respectively, compared with 85 percent of nonsmokers (p = 0.9). In this study, H. pylori eradication rates were slightly higher for nonsmokers (68 percent versus 66 percent among mild and 59 percent among heavy smokers). These reports suggest that ulcer healing rates are high in patients treated with H. pylori eradication therapy, regardless of their smoking status.

##### Duodenal Ulcer Recurrence

In studies comparing duodenal ulcer recurrence rates for smokers and nonsmokers before the introduction of H. pylori eradication therapy, higher relapse rates consistently were reported for smokers (USDHHS 1990). However, ulcers rarely, if ever, recur in patients who remain free of H. pylori, regardless of their smoking status. George and colleagues (1990) observed no recurrence of duodenal ulcers among 71 patients (31 current and 12 former smokers, and 28 lifetime non-smokers) whose ulcers had healed, whose H. pylori had been eradicated, and who remained free of H. pylori during the four years they were followed. In an Australian study, 197 patients successfully treated for H. pylori-positive duodenal ulcers had their infections eradicated and their ulcers cured. They then were followed for 12 to 73 months (Borody et al. 1992b). There was no recurrence of H. pylori or duodenal ulcers among the groups of 80 current smokers (smoking 5 to 40 cigarettes per day), 38 former smokers (who gave up smoking during follow-up or up to 20 years earlier), and 79 patients who had never smoked. In the Netherlands, Van Der Hulst and colleagues (1997) also found no recurrences in 141 duodenal ulcer patients whose ulcers had been cured and who had been treated successfully for H. pylori infection; they remained free of infection during nine years of follow-up. In Greece, there was no recurrence of duodenal ulcers during 12 to 72 months of follow-up in 141 patients who remained H. pylori negative, regardless of their smoking status; there were seven recurrences (six in smokers) among 24 patients (unknown number of smokers) who became reinfected with H. pylori (Archimandritis et al. 1999).

Although other authors have documented low ulcer recurrence rates in patients whose H. pylori infection was eradicated, ulcer recurrence commonly is associated with either reinfection with H. pylori (Bayerdörffer et al. 1993) or NSAID use (Chen et al. 1999). Furthermore, recurrence rates have not varied between smokers and nonsmokers. A study in Hong Kong followed patients for 10 to 18 months who had been successfully treated for H. pylori infection and whose duodenal ulcers had healed (Chan et al. 1997). The authors documented two recurrences (2.9 percent, both H. pylori negative) among 68 smokers (≥10 cigarettes per day) and four recurrences (2.1 percent, three H. pylori negative) among 188 persons who had never smoked or were former smokers. The study concluded that smoking did not influence ulcer recurrence after H. pylori eradication.

Patients treated for H. pylori-positive duodenal ulcers in a multicenter study (Canada, Ireland, United Kingdom, and United States) were followed for six months (Bardhan et al. 1997). All patients had healed ulcers, but H. pylori was eradicated in only 77 percent of nonsmokers and 71 percent of smokers. Ulcers recurred in 22 percent of 118 smokers and 16 percent of 117 nonsmokers (p = 0.32). The slightly higher rate seen in smokers could be a result of the slightly lower H. pylori eradication rate for this group. Recurrence rates in this study among patients who apparently remained free of H. pylori during follow-up were an unusually high 12 percent (<6 percent in three of the centers) for both smokers and nonsmokers.

In summary, smoking does not appear to affect duodenal ulcer recurrence rates in patients whose H. pylori infection has been eradicated. Among those who remain H. pylori positive, smoking may increase the risk of relapse, although no good data support or refute this possible association.

##### Gastric Ulcer Recurrence

A similar pattern is seen for H. pylori-positive gastric ulcers, which also rarely recur after successful H. pylori eradication therapy in the absence of NSAID use (Labenz and Börsch 1994). There were no relapses of gastric ulcers in 45 patients who remained H. pylori negative during 10 years of follow-up (Van Der Hulst et al. 1997). Chan and colleagues (1997) observed one recurrence of gastric ulcer accompanied by the reappearance of H. pylori in 15 smokers and no recurrences in 16 nonsmokers followed for up to 18 months after H. pylori eradication and successful ulcer healing.

These data suggest that for both gastric and duodenal ulcers, the main predictor of successful ulcer healing with no recurrence is H. pylori infection status. If smoking has any effect on the healing or recurrence of ulcers, it is therefore likely to be through an effect on the process of H. pylori eradication.

##### Smoking and Helicobacter pylori Eradication

A number of studies have evaluated the effects of smoking on H. pylori eradication. Results of studies that included more than 50 participants and presented separate eradication rates for smokers and nonsmokers are shown in Table 6.33. (Because three other studies [Fraser et al. 1996; Harris et al. 1996; Georgopoulos et al. 2000] simply reported that smoking was not significantly associated with eradication without presenting eradication rates, it is not possible to tell if there were nonsignificant differences between smokers and nonsmokers.) Although the definition of smoking in these studies often is unclear, and a range of different drug combinations was used to treat the infections, a fairly consistent pattern of lower eradication rates is seen in groups defined as smokers.

Table 6.33 Studies on Helicobacter pylori (H. pylori) eradication rates among smokers and nonsmokers

Study/location | Population | Therapy | Definition of smoking | Eradication rate (%) | | Absolute percent difference (%)
Study/location | Population | Therapy | Definition of smoking | Smokers | Nonsmokers | Absolute percent difference (%)
Cutler and Schubert 1993 United States | 96 patients with gastric ulcers, duodenal ulcers, or nonulcer dyspepsia | Bismuth, tetracycline, and metronidazole | NR^*^ | 73.7 | 89.7 | 16.0 (p = 0.040)
Labenz et al. 1994 Germany | 405 patients with H. pylori-related diseases of the gastroduodenum (231 with duodenal ulcer disease, 138 with gastric ulcer disease, 14 with gastroduodenal double ulcers, and 22 with H. pylori gastritis-associated dyspepsia) | Omeprazole and amoxicillin | NR | 65 | 83 | 18 (p <0.001)
O’Connor et al. 1995 Ireland | 85 patients with gastric or duodenal ulcers and confirmed H. pylori infection | Bismuth, metronidazole, tetracycline | NR | 82.6 | 94.4 | 11.8 (NS^†^)
Goddard and Spiller 1996 United Kingdom | 200 patients with endoscopically proven H. pylori | Bismuth, tetracycline, and metronidazole (BTT); | NR | BTT: 76.3 | 84.2 | 7.9 (NS)
Goddard and Spiller 1996 United Kingdom | 200 patients with endoscopically proven H. pylori | omeprazole, clarithromycin, and metronidazole (OCM); | NR | OCM: 85.7 | 88.8 | 3.1 (NS)
Goddard and Spiller 1996 United Kingdom | 200 patients with endoscopically proven H. pylori | omeprazole, clarithromycin, and tinidazole (OCT); | NR | OCT: 68.7 | 87.5 | 18.8 (NS)
Goddard and Spiller 1996 United Kingdom | 200 patients with endoscopically proven H. pylori | omeprazole, clarithromycin, metronidazole, and tinidazole (OCN) | NR | OCN: 79.5 | 88.2 | 8.7 (p <0.05)
Bardhan et al. 1997 Canada, Ireland, United Kingdom, United States | 284 duodenal ulcer patients with H. pylori infection | Clarithromycin, omeprazole | NR | 71 | 77 | 6 (NS)
Breuer et al. 1997a Korea | 72 patients with H. pylori infection and endoscopically confirmed gastric or duodenal ulcers | Amoxicillin, clarithromycin, and nizatidine | NR | 93.7 | 100 | 6.3 (p = 0.55)
Breuer et al. 1997b Korea | 79 patients with H. pylori infection and endoscopically confirmed gastric or duodenal ulcers | Metronidazole, amoxicillin, omeprazole | ≥5 cigarettes/day | 65 | 88 | 23 (p = 0.035)
Kadayifçi and Simsek 1997 Turkey | 232 patients with endoscopically verified H. pylori-positive active duodenal ulcer disease | Amoxicillin, clarithromycin, metranidazole, roxitromycin, and nitrimidazine (alone or in different combinations) | Eradication rates were stratified by cigarettes/day categories, but it is unclear how the analysis defined “nonsmokers” | 5–20 cigarettes/day: 66 | 68 | 2 (NS)
Kadayifçi and Simsek 1997 Turkey | 232 patients with endoscopically verified H. pylori-positive active duodenal ulcer disease | Amoxicillin, clarithromycin, metranidazole, roxitromycin, and nitrimidazine (alone or in different combinations) | Eradication rates were stratified by cigarettes/day categories, but it is unclear how the analysis defined “nonsmokers” | >20 cigarettes/day: 59 | | 9 (NS)
Moayyedi et al. 1997 United Kingdom | 273 H. pylori-positive patients, diagnosed by ^13^C-UBT (127 with normal endoscopy, 68 with duodenitis, 28 with duodenal ulcers, 8 with gastric ulcers, 18 with esophagitis, and 24 miscellaneous) | Omeprazole, clarithromycin, and tinidazole | NR | 87 | 95 | 8
Kamada et al. 1999 Japan | 137 H. pylori-positive patients (60 with duodenal ulcers, 19 with gastric ulcers, and 58 with nonulcer dyspepsia) | Omeprazole, amoxicillin, clarithromycin | NR | 57.7 | 80.0 | 22.3 (p <0.01)

* NR = Data were not reported.

† NS = Not significant.

Other factors known to be strongly predictive of H. pylori eradication are compliance with therapy (Graham et al. 1992; Cutler and Schubert 1993; Labenz et al. 1994) and the prevalence of metronidazole resistance (O’Riordan et al. 1990). Although some studies have reported poorer compliance among smokers (Unge et al. 1993), others have found similarly high compliance rates between smokers and nonsmokers (O’Connor et al. 1995; Bardhan et al. 1997; Kamada et al. 1999). In a logistic regression model also adjusting for therapy duration and omeprazole pretreatment, Labenz and colleagues (1994) found both lack of compliance (OR = 74.72 [95% CI, 24.17–205.51]) and smoking (OR = 2.75 [95% CI, 1.56–4.86]) to be independent risk factors for treatment failure. Witteman and colleagues (1993) found that metronidazole resistance developed more readily in smokers following therapy with bismuth and metronidazole after allowing for variations in compliance (p = 0.01). However, poorer eradication rates in smokers also are seen with regimens that do not contain this class of drug. Therefore, it seems unlikely that the lower eradication rates for smokers can be attributed to either poorer compliance or an increase in metronidazole resistance. It has been suggested that smoking may adversely affect eradication by increasing acid output or by decreasing gastric blood flow, thereby reducing drug delivery to the gastric mucosa, but little evidence supports either of these hypotheses.

### Evidence Synthesis

#### Incidence of Peptic Ulcer

Many studies have reported strong and significant associations between smoking and peptic ulcer disease. Only six studies, however, have allowed for the effects of H. pylori infection when evaluating this association. Three of those studies reported significantly increased risks of ulcer disease in smokers after adjusting for H. pylori infection; in each study, the majority (80 to 90 percent) of ulcer patients were H. pylori positive (Wang et al. 1996; Talamini et al. 1997; Halter and Brignoli 1998). A fourth study reported a significant association between smoking and ulcers only among H. pylori-positive persons (Martin et al. 1989). The remaining two studies (Schubert et al. 1993; Schlemper et al. 1996) reported little or no association, but the classification of smoking status in these studies is potentially unreliable.

Cigarette smoking has a number of effects on gastroduodenal physiology that could lead to the development of peptic ulceration, and evidence suggests that some of these effects may be potentiated in H. pylori-positive persons. Taken together, these data strongly suggest a causal relationship between smoking and the development of peptic ulcers, at least in H. pylori-positive persons. There is insufficient evidence to evaluate the relation between smoking and peptic ulcers in those who are H. pylori negative. Conflicting and inadequate data link smoking to ulcer occurrence in NSAID users and it is not possible to evaluate an independent effect for smoking in the development of NSAID-induced peptic ulcers.

There is evidence to suggest that after adjusting for NSAID use, smoking may be associated with an increased risk of peptic ulcer complications, including perforation and bleeding. Data from the most recent study (Weil et al. 2000), however, suggest that this effect may be restricted to nonusers of NSAIDs.

The effects of smoking cessation on ulcer risk have not been evaluated in the context of H. pylori infection. However, the transient nature of many of the physiologic effects of smoking suggests that an excess risk may be restricted to current smokers.

#### Ulcer Healing and Recurrence

Healing and recurring H. pylori-positive ulcers are closely associated with eradication and recurrence of the infection. The evidence strongly suggests that if H. pylori is eradicated, smoking has no effect on either the healing or recurrence of ulcers. There is, however, evidence to suggest that H. pylori eradication therapy is somewhat less successful for current smokers. There are no good data to evaluate the effects of smoking on the recurrence of ulcers associated with H. pylori infection when long-term H. pylori eradication fails, or on the treatment and recurrence of ulcers in persons negative for H. pylori infection.

### Conclusions

1. The evidence is sufficient to infer a causal relationship between smoking and peptic ulcer disease in persons who are Helicobacter pylori positive.
2. The evidence is inadequate to infer the presence or absence of a causal relationship between smoking and peptic ulcer disease in nonsteroidal anti-inflammatory drug users or in those who are Helicobacter pylori negative.
3. The evidence is suggestive but not sufficient to infer a causal relationship between smoking and risk of peptic ulcer complications, although this effect might be restricted to nonusers of non-steroidal anti-inflammatory drugs.
4. The evidence is inadequate to infer the presence or absence of a causal relationship between smoking and the treatment and recurrence of Helicobacter pylori-negative ulcers.

### Implications

The prevalence of H. pylori has declined in developed countries (Banatvala et al. 1993; Kosunen et al. 1997) and, as a result, the proportion of patients with H. pylori-negative ulcers will increase, making them an important group to study. Also, an increasing number of H. pylori-negative ulcers may not be attributable to NSAID use or other established causes of ulcers (Jyotheeswaran et al. 1998). The rarity of ulcer recurrence when H. pylori is eradicated, regardless of smoking status, suggests that smoking is not an important factor in the initial development or recurrence of ulcers among persons who are H. pylori negative. However, this topic has not been well investigated, largely because of the paucity of such ulcers, and is likely to be an important area for future research.

Because the main effects of smoking on gastrointestinal physiology appear to be short-lived, it is likely that smoking cessation will both reduce ulcer occurrence in those persons who are H. pylori positive and improve the chances of eradication in patients (with or without ulcers) treated for H. pylori infection. Even if eradication is successful, it seems unlikely that a continuation of smoking will influence the course of peptic ulcer disease.

## Conclusions

Diminished Health Status

1. The evidence is sufficient to infer a causal relationship between smoking and diminished health status that may manifest as increased absenteeism from work and increased use of medical care services.

2. The evidence is sufficient to infer a causal relationship between smoking and increased risks for adverse surgical outcomes related to wound healing and respiratory complications.

Loss of Bone Mass and the Risk of Fractures

3. The evidence is inadequate to infer the presence or absence of a causal relationship between smoking and reduced bone density before menopause in women and in younger men.

4. In postmenopausal women, the evidence is sufficient to infer a causal relationship between smoking and low bone density.

5. In older men, the evidence is suggestive but not sufficient to infer a causal relationship between smoking and low bone density.

6. The evidence is sufficient to infer a causal relationship between smoking and hip fractures.

7. The evidence is inadequate to infer the presence or absence of a causal relationship between smoking and fractures at sites other than the hip.

Dental Diseases

8. The evidence is sufficient to infer a causal relationship between smoking and periodontitis.

9. The evidence is inadequate to infer the presence or absence of a causal relationship between smoking and coronal dental caries.

10. The evidence is suggestive but not sufficient to infer a causal relationship between smoking and root-surface caries.

Erectile Dysfunction

11. The evidence is suggestive but not sufficient to infer a causal relationship between smoking and erectile dysfunction.

Eye Diseases

12. The evidence is sufficient to infer a causal relationship between smoking and nuclear cataract.

13. The evidence is suggestive but not sufficient to infer that smoking cessation reduces the risk of nuclear opacity.

14. The evidence is suggestive but not sufficient to infer a causal relationship between current and past smoking, especially heavy smoking, with risk of exudative (neovascular) age-related macular degeneration.

15. The evidence is suggestive but not sufficient to infer a causal relationship between smoking and atrophic age-related macular degeneration.

16. The evidence is suggestive of no causal relationship between smoking and the onset or progression of retinopathy in persons with diabetes.

17. The evidence is inadequate to infer the presence or absence of a causal relationship between smoking and glaucoma.

18. The evidence is suggestive but not sufficient to infer a causal relationship between ophthalmopathy associated with Graves’ disease and smoking.

Peptic Ulcer Disease

19. The evidence is sufficient to infer a causal relationship between smoking and peptic ulcer disease in persons who are Helicobacter pylori positive.

20. The evidence is inadequate to infer the presence or absence of a causal relationship between smoking and peptic ulcer disease in nonsteroidal anti-inflammatory drug users or in those who are Helicobacter pylori negative.

21. The evidence is suggestive but not sufficient to infer a causal relationship between smoking and risk of peptic ulcer complications, although this effect might be restricted to nonusers of non-steroidal anti-inflammatory drugs.

22. The evidence is inadequate to infer the presence or absence of a causal relationship between smoking and the treatment and recurrence of Helicobacter pylori-negative ulcers.

## References

Aalykke C, Lauritsen JM, Hallas J, Reinholdt S, Krogfelt K, Lauritsen K. Helicobacter pylori and risk of ulcer bleeding among users of nonsteroidal anti-inflammatory drugs: a case-control study. Gastroenterology. 1999;116(6):1305-9. [pmid: 10348813].
Abber JC, Lue TF, Orvis BR, McClure RD, Williams RD. Diagnostic tests for impotence: a comparison of papaverine injection with the penile-brachial index and nocturnal penile tumescence monitoring. Journal of Urology. 1986;135(5):923-5. [pmid: 3959242].
Abidi NA, Dhawan S, Gruen GS, Vogt MT, Conti SF. Wound-healing risk factors after open reduction and internal fixation of calcaneal fractures. Foot and Ankle International. 1998;19(12):856-61. [pmid: 9872474].
Adaikan PG, Ratnam SS. Pharmacology of penile erection in humans. Cardiovascular and Interventional Radiology. 1988;11(4):191-4. [pmid: 2852054].
Age-Related Eye Disease Study Research Group. A randomized, placebo-controlled, clinical trial of high-dose supplementation with vitamins C and E, beta carotene, and zinc for age-related macular degeneration and vision loss: AREDS report no. 8. Archives of Ophthalmology. 2001;119(10):1417-36. [pmid: 11594942].
Ah MKB, Johnson GK, Kaldahl WB, Patil KD, Kalkwarf KL. The effect of smoking on the response to periodontal therapy. Journal of Clinical Periodontology. 1994;21(2):91-7. [pmid: 8144739].
Ahlberg J, Tuominen R, Murtomaa H. Periodontal status among male industrial workers in southern Finland with or without access to subsidized dental care. Acta Odontologica Scandinavica. 1996;54(3):166-70. [pmid: 8811138].
Ainamo J. The seeming effect of tobacco consumption on the occurrence of periodontal disease and dental caries. Suomen Hammaslaakariseuran Toimituksia. 1971;67(2):87-94. [pmid: 4397932].
Ainamo J, Barmes D, Beagrie G, Cutress T, Martin J, Sardo-Infirri J. Development of the World Health Organization (WHO) community periodontal index of treatment needs (CPITN). International Dental Journal. 1982;32(3):281-91. [pmid: 6958657].
Alberg AJ, Chen JC, Zhao H, Hoffman SC, Comstock GW, Helzlsouer KJ. Household exposure to passive cigarette smoking and serum micronutrient concentrations. American Journal of Clinical Nutrition. 2000;72(6):1576-82. [pmid: 11101488].
Alexander AG. The relationship between tobacco smoking calculus and plaque accumulation and gingivitis. Dental Health (London). 1970;9(1):6-9.
Allen RA, Kluft C, Brommer EJP. Effect of chronic smoking on fibrinolysis. Arteriosclerosis. 1985;5(5):443-50. [pmid: 3876092].
Allen RP, Brendler CB. Nocturnal penile tumescence with polysomnography (NPT-PSG) remains the only objectively validated procedure for differential diagnosis of organic versus psychogenic erectile impotence. Lue TF, editor. World Book of Impotence. London. Smith-Gordon. 1992:75-80.
Aloia JF, Cohn SH, Vaswani A, Yeh JK, Yuen K, Ellis K. Risk factors for postmenopausal osteoporosis. American Journal of Medicine. 1985;78(1):95-100. [pmid: 3966495].
Alpagot T, Wolff LF, Smith QT, Tran SD. Risk indicators for periodontal disease in a racially diverse urban population. Journal of Clinical Periodontology. 1996;23(11):982-8. [pmid: 8951624].
American Academy of Periodontology. Position paper: epidemiology of periodontal diseases. Journal of Periodontology. 1996;67(9):935-45. [See also comments in Journal of Periodontology 1997;68(8):804; Journal of Periodontology 1997;68(10):1022–3]. [pmid: 8884652].
American Academy of Periodontology. The pathogenesis of periodontal diseases. Journal of Periodontology. 1999;70(4):457-70. [pmid: 10328661].
Ames BN, Gold LS, Willett WC. The causes and prevention of cancer. Proceedings of the National Academy of Sciences of the United States of America. 1995;92(12):5258-65. [pmid: 7777494].
Amin S, LaValley MP, Zhang Y, Evans SR, Sawin C, Wilson PWF, Hannan MT, Kiel DP, Felson DT. Is the effect of smoking on bone mineral density (BMD) in elderly men mediated through estradiol (E2)? The Framingham Osteoporosis Study. Journal of Bone and Mineral Research. 1999;14(Suppl 1):S147.
Andersson G, Malmgren S. Risk factors and reported sick leave among employees of Saab-Scania, Linköping, Sweden, between the ages of 50 and 59. Scandinavian Journal of Social Medicine. 1986;14(1):25-30. [pmid: 3704577].
Andrews JA, Severson HH, Lichtenstein E, Gordon JS. Relationship between tobacco use and self-reported oral hygiene habits. Journal of the American Dental Association. 1998;129(3):313-20. [pmid: 9529806].
Aoki K, Ito Y, Sasaki R, Ohtani M, Hamajima N, Asano A. Smoking, alcohol drinking and serum carotenoids levels. Japanese Journal of Cancer Research. 1987;78(10):1049-56. [pmid: 3119536].
Apple DF Jr, Hayes WC, editors. Prevention of Falls and Hip Fractures in the Elderly. Rosemont (IL). American Academy of Orthopaedic Surgeons. 1994.
Archimandritis A, Balatsos V, Delis V, Manika Z, Skandalis N. “Reappearance” of Helicobacter pylori after eradication: implications on duodenal ulcer recurrence. A prospective 6 year study”. Journal of Clinical Gastroenterology. 1999;28(4):345-7. [pmid: 10372933].
Arend SM, Mallat MJ, Westendorp RJ, van der Woude FJ, van Es LA. Patient survival after renal transplantation; more than 25 years follow-up. Nephrology, Dialysis, Transplantation. 1997;12(8):1672-9.
Armitage GC. Development of a classification system for periodontal diseases and conditions. Annals of Periodontology. 1999;4(1):1-6. [pmid: 10863370].
Arno A, Schei O, Lovdal A, Wæehaug J. Alveolar bone loss as a function of tobacco consumption. Acta Odontologica Scandinavica. 1959;17:3-10.
Asami S, Manabe H, Miyake J, Tsurdome Y, Hirano T, Yamaguchi R, Itoh H, Kasai H. Cigarette smoking induces an increase in oxidative DNA damage, 8-hydroxydeoxyguanosine, in a central site of the human lung. Carcinogenesis. 1997;18(9):1763-6. [pmid: 9328173].
Ascherio A, Rimm EB, Giovannucci EL, Spiegelman D, Stampfer M, Willett WC. Dietary fat and risk of coronary heart disease in men: cohort follow up study in the United States. British Medical Journal. 1996;13(7049):84-90. [pmid: 8688759].
Ashford JR. Smoking and the use of the health services. British Journal of Preventive and Social Medicine. 1973;27(1):8-17. [pmid: 4717827].
Ashraf SS, Shaukat N, Kamaly ID, Durrani A, Doran B, Grotte GJ, Keenan DJ. Determinants of early and late mortality in patients with end-stage renal disease undergoing cardiac surgery. Scandinavian Journal of Thoracic and Cardiovascular Surgery. 1995;29(4):187-93. [pmid: 8789472].
Athanasou JA. Smoking and absenteeism. The Medical Journal of Australia. 1979;1(6):234-6. [pmid: 460015].
Athanasou JA, Reid CC, Ferguson DA. Sickness absence and smoking. The Medical Journal of Australia. 1981;1(5):211-2. [pmid: 7231307].
Ault RW, Ekelund RB Jr, Jackson JD, Saba RS, Saurman DS. Smoking and absenteeism. Applied Economics. 1991;23(4B):743-54.
Axelsson P, Paulander J, Lindhe J. Relationship between smoking and dental status in 35-, 50-, 65-, and 75-year-old individuals. Journal of Clinical Periodontology. 1998;25(4):297-305. [pmid: 9565280].
Baab DA, Öberg PÅ. The effect of cigarette smoking on gingival blood flow in humans. Journal of Clinical Periodontology. 1987;14(7):418-24. [pmid: 2957396].
Bacon C, Mittleman M, Glasser D, Rimm E. Can lifestyle factors help prevent erectile dysfunction?. European Urology. 2001;39(Suppl 5):17.
Bahn RS. Understanding the immunology of Graves’ ophthalmopathy: is it an autoimmune disease?. Endocrinology and Metabolism Clinics of North America. 2000;29(2):287-96. [pmid: 10874530].
Bähren W, Gall H, Scherb W, Stief C, Thon W. Arterial anatomy and arteriographic diagnosis of arteriogenic impotence. Cardiovascular and Interventional Radiology. 1988;11(4):195-210. [pmid: 3147134].
Balarajan R, Yuen P, Bewley BR. Smoking and state of health. British Medical Journal (Clinical Research Edition). 1985;291(6510):1682.
Ballard DJ, Melton LJ III, Dwyer MS, Trautmann JC, Chu C-P, O’Fallon WM, Palumbo PJ. Risk factors for diabetic retinopathy: a population-based study in Rochester, Minnesota. Diabetes Care. 1986;9(4):334-42. [pmid: 3743309].
Banatvala N, Mayo K, Megraud F, Jennings R, Deeks JJ, Feldman RA. The cohort effect and Helicobacter pylori. Journal of Infectious Diseases. 1993;168(1):219-21. [pmid: 8515114].
Barbour SE, Nakashima K, Zhang J-B, Tandaga S, Hahn C-L, Schenkein HA, Tew JG. Tobacco and smoking: environmental factors that modify the host response (immune system) and have an impact on periodontal health. Critical Reviews in Oral Biology and Medicine. 1997;8(4):437-60. [pmid: 9391754].
Bardhan KD, Graham DY, Hunt RH, O’Morain CA. Effects of smoking on cure of Helicobacter pylori infection and duodenal ulcer recurrence in patients treated with clarithromycin and omeprazole. Helicobacter. 1997;2(1):27-31. [pmid: 9432318].
Barker GJ, Williams KB. Tobacco use cessation activities in U.S. dental and dental hygiene student clinics. Journal of Dental Education. 1999;63(11):828-33. [pmid: 10608929].
Baron JA, Comi RJ, Cryns V, Brinck-Johnsen T, Mercer NG. The effect of cigarette smoking on adrenal cortical hormones. Journal of Pharmacology and Experimental Therapeutics. 1995;272(1):151-5. [pmid: 7815328].
Baron JA, Farahmand BY, Weiderpass E, Michaëlsson K, Alberts A, Persson I, Ljunghall S. Cigarette smoking, alcohol consumption, and risk of hip fracture in women. Archives of Internal Medicine. 2001;161(7):983-8. [pmid: 11295961].
Baron JA, Karagas M, Barrett J, Kniffin W, Malenka D, Mayor M, Keller RB. Basic epidemiology of fractures of the upper and lower limb among Americans over 65 years of age. Epidemiology. 1996;7(6):612-8. [pmid: 8899387].
Bartalena L, Marcocci C, Tanda ML, Manetti L, Dell’Unto E, Bartolomei MP, Nardi M, Martino E, Pinchera A. Cigarette smoking and treatment outcomes in Graves ophthalmopathy. Annals of Internal Medicine. 1998;129(8):632-5. [pmid: 9786811].
Bastiaan RJ, Waite IM. Effects of tobacco smoking on plaque development and gingivitis. Journal of Periodontology. 1978;49(8):480-2. [pmid: 281495].
Batenburg M, Reinken JA. The relationship between sickness absence from work and pattern of cigarette smoking. New Zealand Medical Journal. 1990;103(882):11-3. [pmid: 2360925].
Bateson MC. Cigarette smoking and Helicobacter pylori infection. Postgraduate Medical Journal. 1993;69(807):41-4. [pmid: 8446549].
Bauer DC, Browner WS, Cauley JA, Orwoll ES, Scott JC, Black DM, Tao JL, Cummings SR. Factors associated with appendicular bone mass in older women. The Study of Osteoporotic Fractures Research Group. Annals of Internal Medicine. 1993;118(9):657-65. [pmid: 8460853].
Bayerdörffer E, Mannes GA, Sommer A, Höchter W, Weingart J, Hatz R, Lehn N, Ruckdeschel G, Dirschedl P, Stolte M. Long-term follow-up after eradication of Helicobacter pylori with a combination of omeprazole and amoxycillin. Scandinavian Journal of Gastroenterology Supplement. 1993;28:19-25.
Beaulieu M-D, Beland F, Roy D, Falardeau M, Hebert G. Factors determining compliance with screening mammography. Canadian Medical Association Journal. 1996;154(9):1335-43. [pmid: 8616736].
Beck JD, Cusmano L, Green-Helms W, Koch GG, Offenbacher S. A 5-year study of attachment loss in community-dwelling older adults: incidence density. Journal of Periodontal Research. 1997;32(6):506-15. [pmid: 9379318].
Beck JD, Koch GG, Rozier RG, Tudor GE. Prevalence and risk indicators for periodontal attachment loss in a population of older community-dwelling blacks and whites. Journal of Periodontology. 1990;61(8):521-8. [pmid: 2391631].
Belloc NB, Breslow L. Relationship of physical health status and health practices. Preventive Medicine. 1972;1(3):409-21. [pmid: 5085007].
Benedetto MC, Kerns RD, Rosenberg R, Burg MM, Westgate K. Health risk behaviors and their relationships to health care utilization among veterans receiving primary medical care. Journal of Clinical Psychology in Medical Settings. 1998;5(4):441-7.
Bergen AW, Caporaso N. Cigarette smoking. Journal of the National Cancer Institute. 1999;91(16):1365-75. [pmid: 10451441].
Bergström J. Short-term investigation on the influence of cigarette smoking upon plaque accumulation. Scandinavian Journal of Dental Research. 1981;89(3):235-8. [pmid: 6947382].
Bergström J. Oral hygiene compliance and gingivitis expression in cigarette smokers. Scandinavian Journal of Dental Research. 1990;98(6):497-503. [pmid: 2091245].
Bergström J, Eliasson S. Cigarette smoking and alveolar bone height in subjects with a high standard of oral hygiene. Journal of Clinical Periodontology. 1987a;14(8):466-9. [pmid: 3477575].
Bergström J, Eliasson S. Noxious effect of cigarette smoking on periodontal health. Journal of Periodontal Research. 1987b;22(6):513-7. [pmid: 2963112].
Bergström J, Eliasson S, Preber H. Cigarette smoking and periodontal bone loss. Journal of Periodontology. 1991;62(4):242-6. [See also erratum in Journal of Periodontology 1991;62(12):809.]. [pmid: 2037954].
Bergström J, Floderus-Myrhed B. Co-twin control study of the relationship between smoking and some periodontal disease factors. Community Dentistry and Oral Epidemiology. 1983;11(2):113-6. [pmid: 6573237].
Bergström J, Preber H. The influence of cigarette smoking on the development of experimental gingivitis. Journal of Periodontal Research. 1986;21(6):668-76. [pmid: 2948000].
Berkman LF, Seeman TE, Albert M, Blazer D, Kahn R, Mohs R, Finch C, Schneider E, Cotman C, McClearn G. High, usual and impaired functioning in community-dwelling older men and women: findings from the MacArthur Foundation Research Network on Successful Aging. Journal of Clinical Epidemiology. 1993;46(10):1129-40. [pmid: 8410098].
Berr C, Coudray C, Bonithon-Kopp C, Roussci AN, Mainard F, Alperovitch A. Eva Study Group. Demographic and cardiovascular rise factors in relation to antioxidant status: the EVA Study. International Journal of Vitamin and Nutrition Research. 1998;68(1):26-35.
Bertera RL. The effects of behavioral risks on absenteeism and health-care costs in the workplace. Journal of Occupational Medicine. 1991;33(11):1119-24. [pmid: 1765851].
Best D, Rawaf S, Rowley J, Floyd K, Manning V, Strang J. Drinking and smoking as concurrent predictors of illicit drug use and positive drug attitudes in adolescents. Drug and Alcohol Dependence. 2000;60(3):319-21. [pmid: 11053768].
Bettman JW, Fellows V, Chao P. The effect of cigarette smoking on the intraocular circulation. Archives of Ophthalmology. 1958;59:481-8. [pmid: 13519966].
Bhattacharyya MH, Whelton BD, Stern PH, Peterson DP. Cadmium accelerates bone loss in ovariectomized mice and fetal rat limb bones in culture. Proceedings of the National Academy of Sciences of the United States of America. 1988;85(22):8761-5. [pmid: 3186759].
Billimoria JD, Pozner H, Metselaar B, Best FW, Janus DC. Effect of cigarette smoking on lipids, lipoproteins, blood coagulation, fibrinolysis and cellular components of human blood. Atherosclerosis. 1975;21(1):61-76. [pmid: 1131301].
Bjarnason NH, Christiansen C. The influence of thinness and smoking on bone loss and response to hormone replacement therapy in early postmenopausal women. Journal of Clinical Endocrinology and Metabolism. 2000;85(2):590-6. [pmid: 10690860].
Blair A, Blair SN, Howe HG, Pate RR, Rosenberg M, Parker GM, Pickle LW. Physical, psychological, and sociodemographic differences among smokers, exsmokers, and nonsmokers in a working population. Preventive Medicine. 1980;9(6):747-59. [pmid: 7454699].
Blake GH, Abell TD, Stanley WG. Cigarette smoking and upper respiratory infection among recruits in basic combat training. Annals of Internal Medicine. 1988;109(3):198-202. [pmid: 3389603].
Blanker MH, Bohnen AM, Groeneveld FPMJ, Bernsen RMD, Prins A, Thomas S, Bosch JLHR. Correlates for erectile and ejaculatory dysfunction in older Dutch men: a community-based study. Journal of the American Geriatrics Society. 2001;49(4):436-42. [pmid: 11347788].
Bluman LG, Mosca L, Newman N, Simon D. Preoperative smoking habits and postoperative pulmonary complications. Chest. 1998;113(4):883-9. [pmid: 9554620].
Blumenkranz MS, Russell SR, Robey MG, Kott-Blumenkranz R, Penneys N. Risk factors in age-related maculopathy complicated by choroidal neovascularization. Ophthalmology. 1986;93(5):552-8. [pmid: 2425325].
Bobak M, Pikhart H, Hertzman C, Rose R, Marmot M. Socioeconomic factors, perceived control and self-reported health in Russia: a cross-sectional survey. Social Science Medicine. 1998;47(2):269-79. [pmid: 9720645].
Bochow TW, West SK, Azar A, Munoz B, Sommer A, Taylor HR. Ultraviolet light exposure and risk of posterior subcapsular cataracts. Archives of Ophthalmology. 1989;107(3):369-72. [pmid: 2923558].
Bolin A, Eklund G, Frithiof L, Lavstedt S. The effect of changed smoking habits on marginal alveolar bone loss: a longitudinal study. Swedish Dental Journal. 1993;17(5):211-6. [pmid: 8291030].
Bolin A, Lavstedt S, Frithiof L, Henrikson CO. Proximal alveolar bone loss in a longitudinal radiographic investigation. IV: smoking and some other factors influencing the progress in individuals with at least 20 remaining teeth. Acta Odontologica Scandinavica. 1986;44(5):263-9. [pmid: 3468736].
Bolton-Smith C, Casey CE, Gey KF, Smith WCS, Tunstall-Pedoe H. Antioxidant vitamin intakes assessed using a food-frequency questionnaire: correlation with biochemical status in smokers and non-smokers. British Journal of Nutrition. 1991;65(3):337-46. [pmid: 1878353].
Bonithon-Kopp C, Coudray C, Berr C, Touboul P-J, Fève JM, Favier A, Ducimetière P. Combined effects of lipid peroxidation and antioxidant status on carotid atherosclerosis in a population aged 59–71 y: the EVA Study. American Journal of Clinical Nutrition. 1997;65(1):121-7. [pmid: 8988923].
Boot AM, de Ridder MAJ, Pols HAP, Krenning EP, de Muinck Keizer-Schrama SMPF. Bone mineral density in children and adolescents: relation to puberty, calcium intake, and physical activity. Journal of Clinical Endocrinology and Metabolism. 1997;82(1):57-62. [pmid: 8989233].
Borch-Johnsen K, Nissen H, Henriksen E, Kreiner S, Salling N, Deckert T, Nerup J. The natural history of insulin-dependent diabetes mellitus in Denmark: 1. Long-term survival with and without late diabetic complications. Diabetic Medicine. 1987;4(3):201-10. [pmid: 2956020].
Bornman MS, Du Plessis DJ. Smoking and vascular impotence: a reason for concern. South African Medical Journal. 1986;70(6):329-30. [pmid: 3750136].
Borody TJ, Brandl S, Andrews P, Jankiewicz E, Ostapowicz N. Helicobacter pylori-negative gastric ulcer. American Journal of Gastroenterology. 1992a;87(10):1403-6. [pmid: 1415095].
Borody TJ, George LL, Brandl S, Andrews P, Jankiewicz E, Ostapowicz N. Smoking does not contribute to duodenal ulcer relapse after Helicobacter pylori eradication. American Journal of Gastroenterology. 1992b;87(10):1390-3. [pmid: 1415092].
Borody TJ, George LL, Brandl S, Andrews P, Ostapowicz N, Hyland L, Devine M. Helicobacter pylori-negative duodenal ulcer. American Journal of Gastroenterology. 1991;86(9):1154-7. [pmid: 1882793].
Boström L, Linder LE, Bergström J. Clinical expression of TNF-α in smoking-associated periodontal disease. Journal of Clinical Periodontology. 1998a;25(10):767-73. [pmid: 9797047].
Boström L, Linder LE, Bergström J. Influence of smoking on the outcome of periodontal surgery: a 5-year follow-up. Journal of Clinical Periodontology. 1998b;25(3):194-201. [pmid: 9543189].
Boucher JM, Dupras A, Jutras N, Page V, LeLorier J, Gagnon RM. Long-term survival and functional status in the elderly after cardiac surgery. Canadian Journal of Cardiology. 1997;13(7):646-52. [pmid: 9251577].
Bovill EG, Bild DE, Heiss G, Kuller LH, Lee MH, Rock R, Wahl PW. White blood cell counts in persons aged 65 years or more from the Cardiovascular Health Study: correlations with baseline clinical and demographic characteristics. American Journal of Epidemiology. 1996;143(11):1107-15. [pmid: 8633599].
Brady WE, Mares-Perlman JA, Bowen P, Stacewicz-Sapuntzakis M. Human serum carotenoid concentrations are related to physiologic and lifestyle factors. Journal of Nutrition. 1996;126(1):129-37. [pmid: 8558292].
Brain K, Parker H, Carnwath T. Drinking with design: young drinkers as psychoactive consumers. Drugs: Education, Prevention and Policy. 2000;7(1):5-20.
Brandtzaeg P, Jamison HC. A study of periodontal health and oral hygiene in Norwegian army recruits. Journal of Periodontology. 1964;35:22-7.
Brenner H, Rothenbacher D, Bode G, Adler G. Relation of smoking and alcohol and coffee consumption to active Helicobacter pylori infection: cross sectional study. British Medical Journal. 1997;315(7121):1489-92. [pmid: 9420488].
Bressler NM, Munoz B, Maguire MG, Vitale SE, Schein OD, Taylor HR, West SK. Five-year incidence and disappearance of drusen and retinal pigment epithelial abnormalities: waterman study. Archives of Ophthalmology. 1995;113(3):301-8. [pmid: 7534060].
Breuer T, Kim JG, el-Zimaity HM, Nakajima S, Ota H, Osato M, Graham DY. Clarithromycin, amoxycillin, and H_2_-receptor antagonist therapy for Helicobacter pylori peptic ulcer disease in Korea. Alimentary Pharmacology and Therapeutics. 1997a;11(5):939-42. [pmid: 9354204].
Breuer T, Kim JG, Gurer IE, Graham DP, Osato M, Genta RM, Graham DY. Successful low-dose amoxycillin, metronidazole and omeprazole combination therapy in a population with a high frequency of metronidazole-resistant Helicobacter pylori. Alimentary Pharmacology and Therapeutics. 1997b;11(3):523-7. [pmid: 9218076].
Bridges RB, Anderson JW, Saxe SR, Gregory K, Bridges SR. Periodontal status of diabetic and non-diabetic men: effects of smoking, glycemic control, and socioeconomic factors. Journal of Periodontology. 1996;67(11):1185-92. [pmid: 8959568].
Brook M, Grimshaw JJ. Vitamin C concentration of plasma and leukocytes as related to smoking habit, age, and sex of humans. American Journal of Clinical Nutrition. 1968;21(11):1254-8. [pmid: 5699720].
Brooks-Brunn JA. Predictors of postoperative pulmonary complications following abdominal surgery. Chest. 1997;111(3):564-71. [pmid: 9118688].
Brot C, Jensen LB, Sørensen OH. Bone mass and risk factors for bone loss in perimenopausal Danish women. Journal of Internal Medicine. 1997;242(6):505-11. [pmid: 9437412].
Brot C, Jørgensen NR, Sørensen OH. The influence of smoking on vitamin D status and calcium metabolism. European Journal of Clinical Nutrition. 1999;53(12):920-6. [pmid: 10602348].
Brown AJ. Acute effects of smoking cessation on antioxidant status. Journal of Nutritional Biochemistry. 1996;7(1):29-39.
Brown CW, Orme TJ, Richardson HD. The rate of pseudarthrosis (surgical nonunion) in patients who are smokers and patients who are non-smokers: a comparison study. Spine. 1986;11(9):942-3. [pmid: 3824072].
Brown LF, Beck JD, Rozier RG. Incidence of attachment loss in community-dwelling older adults. Journal of Periodontology. 1994;65(4):316-23. [pmid: 8195975].
Buiatti E, Muñoz N, Kato I, Vivas J, Muggli R, Plummer M, Benz M, Franceschi S, Oliver W. Determinants of plasma antioxidant vitamin levels in a population at high risk for stomach cancer. International Journal of Cancer. 1996;65(3):317-22.
Burger H, de Laet CEDH, van Daele PLA, Weel AEAM, Witteman JCM, Hofman A, Pols HAP. Risk factors for increased bone loss in an elderly population: the Rotterdam Study. American Journal of Epidemiology. 1998;147(9):871-9. [pmid: 9583718].
Burger H, de Laet CEDH, Weel AEAM, Hofman A, Pols HAP. Added value of bone mineral density in hip fracture risk scores. Bone. 1999;25(3):369-74. [pmid: 10495142].
Burnett AL. Nitric oxide in the penis: physiology and pathology. Journal of Urology. 1997;157(1):320-4. [pmid: 8976289].
Burt BA, Eklund SA. Dentistry, Dental Practice, and the Community. 5th ed. Philadelphia. WB Saunders Company. 1999.
Burt BA, Ismail AI, Eklund SA. Root caries in an optimally fluoridated and a high-fluoride community. Journal of Dental Research. 1986;65(9):1154-8. [pmid: 3461032].
Bush R, Wooden M. Smoking and absence from work: Australian evidence. Social Science and Medicine. 1995;41(3):437-46. [pmid: 7481938].
Cabana MD, Rand CS, Powe NR, Wu AW, Wilson MH, Abboud PA, Rubin HR. Why don’t physicians follow clinical practice guidelines? A framework for improvement. Journal of the American Medical Association. 1999;282(15):1458-65. [pmid: 10535437].
Callahan CM, Stump TE, Stroupe KT, Tierney WM. Cost of health care for a community of older adults in an urban academic healthcare system. Journal of the American Geriatric Society. 1998;46(11):1371-7.
Calori G, D’Angelo A, Della Valle P, Ruotolo G, Ferini-Strambi L, Giusti C, Errera A, Gallus G. The effect of cigarette-smoking on cardiovascular risk factors: a study of monozygotic twins discordant for smoking. Thrombosis and Hemostatis. 1996;75(1):14-8.
Camilleri IG, Malata CM, Stavrianos S, Mclean NR. A review of 120 Becker permanent tissue expanders in reconstruction of the breast. British Journal of Plastic Surgery. 1996;49(6):346-51. [pmid: 8881779].
Carel RS, Eviatar J. Factors affecting leukocyte count in healthy adults. Preventive Medicine. 1985;14(5):607-19. [pmid: 4070192].
Casasnovas JA, Lapetra A, Puzo J, Pelegrin J, Hermosilla T, De Vicente J, Garza F, Del Rio A, Giner A, Ferreira IJ. Tobacco, physical exercise and lipid profile. European Heart Journal. 1992;13(4):440-5. [pmid: 1600979].
Cekic O. Effect of cigarette smoking on copper, lead, and cadmium accumulation in human lens. British Journal of Ophthalmology. 1998;82(2):186-8. [pmid: 9613387].
Centers for Disease Control and Prevention. Incidence and costs to Medicare of fractures among Medicare beneficiaries aged ≥65 years—United States, July 1991–June 1992. Morbidity and Mortality Weekly Report. 1996;45(41):877-83. [pmid: 8927007].
Chan FK, Sung JJ, Lee YT, Leung WK, Chan LY, Yung MY, Chung SC. Does smoking predispose to peptic ulcer relapse after eradication of Helicobacter pylori?. American Journal of Gastroenterology. 1997;92(3):442-5. [pmid: 9068465].
Chan WH, Wong WK, Chan HS, Soo KC. Results of surgical resection of oesophageal carcinoma in Singapore. Annals of Academic Medicine in Singapore. 2000;29(1):57-61.
Chan-Yeung M, Abboud R, Buncio AD, Vedal S. Peripheral leukocyte count and longitudinal decline in lung function. Thorax. 1988;43(6):462-6. [pmid: 3420557].
Chan-Yeung M, Vedal S, Kus J, MacLean L, Enarson D, Tse KS. Symptoms, pulmonary function, and bronchial hyperreactivity in western red cedar workers compared with those in office workers. American Review of Respiratory Diseases. 1984;130(6):1038-41. [pmid: 6508001].
Chen T-S, Chang F-Y, Lee S-D, Lee S-C. Recurrence of H. pylori infection and dyspeptic symptoms after successful eradication in patients cured of duodenal ulcer disease. Hepato-Gastroenterology. 1999;46(25):252-6. [pmid: 10228802].
Cheng S, Fan B, Wang L, Fuerst T, Lian M, Njeh C, He Y, Kern M, Lappin M, Tylavsky F, Casal D, Harris S, Genant HK. Factors affecting broadband ultrasound attenuation results of the calcaneus using a gel-coupled quantitative ultrasound scanning system. Osteoporosis International. 1999;10(6):495-504. [pmid: 10663351].
Cheng S, Suominen H, Heikkinen E. Bone mineral density in relation to anthropometric properties, physical activity and smoking in 75-year-old men and women. Aging: Clinical and Experimental Research. 1993;5(1):55-62.
Cheng S, Suominen H, Rantanen T, Parkatti T, Heikkinen E. Bone mineral density and physical activity in 50–60-year-old women. Bone and Mineral. 1991;12(2):123-32. [pmid: 2015413].
Chetwynd J, Rayner T. Impact of smoking on health care resource use. New Zealand Medical Journal. 1986;99(799):230-2. [pmid: 3458067].
Chimbira W, Sweeney BP. The effect of smoking on postoperative nausea and vomiting. Anaesthesia. 2000;55(6):540-4. [pmid: 10866716].
Christen AG, McDonald JL Jr, Christen JA. The Impact of Tobacco Use and Cessation on Nonmalignant and Pre-cancerous Oral and Dental Diseases and Conditions. Indianapolis (IN). Indiana University, School of Dentistry. 1991.
Christen WG, Glynn RJ, Ajani UA, Schaumberg DA, Buring JE, Hennekens CH, Manson JE. Smoking cessation and risk of age-related cataract in men. Journal of the American Medical Association. 2000;284(6):713-6. [pmid: 10927779].
Christen WG, Glynn RJ, Manson JE, Ajani UA, Buring JE. A prospective study of cigarette smoking and risk of age-related macular degeneration in men. Journal of the American Medical Association. 1996;276(14):1147-51. [pmid: 8827967].
Christen WG, Manson JE, Seddon JM, Glynn RJ, Buring JE, Rosner B, Hennekens CH. A prospective study of cigarette smoking and risk of cataract in men. Journal of the American Medical Association. 1992;268(8):989-93. [pmid: 1501324].
Christiansen JS. Cigarette smoking and prevalence of microangiopathy in juvenile-onset insulin-dependent diabetes mellitus. Diabetes Care. 1978;1(3):146-9. [pmid: 729438].
Clark P, de la Peña F, Gomez Garcia F, Orozco JA, Tugwell P. Risk factors for osteoporotic hip fractures in Mexicans. Archives of Medical Research. 1998;29(3):253-7. [pmid: 9775460].
Clarke NG, Shephard BC. The effects of epinephrine and nicotine on gingival blood flow in the rabbit. Archives of Oral Biology. 1984;29(10):789-93. [pmid: 6594091].
Clarke NG, Shephard BC, Hirsch RS. The effects of intra-arterial epinephrine and nicotine on gingival circulation. Oral Surgery, Oral Medicine, Oral Pathology. 1981;52(6):577-82.
Clayton RM, Cuthbert J, Duffy J, Seth J, Phillips CI, Bartholomew RS, Reid JM. Some risk factors associated with cataract in S.E. Scotland: a pilot study. Transactions of the Ophthalmological Societies of the United Kingdom. 1982;102(Pt 3):331-6. [pmid: 6964276].
Collett JA, Burt MJ, Frampton CMA, Yeo KHJ, Chapman TM, Buttimore RC, Cook HB, Chapman BA. Seroprevalence of Helicobacter pylori in the adult population of Christchurch: risk factors and relationship to dyspeptic symptoms and iron studies. New Zealand Medical Journal. 1999;112(1093):292-5. [pmid: 10493426].
Colsher PL, Wallace RB, Pomrehn PR, La Croix AZ, Cornoni-Huntley J, Blazer D, Scherr PA, Berkman L, Hennekens CH. Demographic and health characteristics of elderly smokers: results from established populations for epidemiologic studies of the elderly. American Journal of Preventive Medicine. 1990;6(2):61-70. [pmid: 2363951].
Comstock GW, Menkes MS, Schober SE, Vuilleumier J-P, Helsing KJ. Serum levels of retinol, beta-carotene, and alpha-tocopherol in older adults. American Journal of Epidemiology. 1988;127(1):114-23. [pmid: 3276153].
Condra M, Morales A, Owen JA, Surridge DH, Fenemore J. Prevalence and significance of tobacco smoking in impotence. Urology. 1986;27(6):495-8. [pmid: 3716047].
Cooper C, Barker DJP, Wickham C. Physical activity, muscle strength, and calcium intake in fracture of the proximal femur in Britain. British Medical Journal. 1988;297(6661):1443-6. [pmid: 3147008].
Cooper C, Shah S, Hand DJ, Adams J, Compston J, Davie M, Woolf A. Screening for vertebral osteoporosis using individual risk factors: the Multicentre Vertebral Fracture Study Group. Osteoporosis International. 1991;2(1):48-53. [pmid: 1790421].
Cornuz J, Feskanich D, Willett WC, Colditz GA. Smoking, smoking cessation, and risk of hip fracture in women. American Journal of Medicine. 1999;106(3):311-4. [pmid: 10190380].
Coronary Drug Project Research Group. Aspirin in coronary heart disease. Journal of Chronic Diseases. 1976;29(10):625-42. [pmid: 789390].
Corre F, Lellouch J, Schwartz D. Smoking and leucocyte-counts: results of an epidemiological survey. Lancet. 1971;2(7725):632-4. [pmid: 4105947].
Cover TL, Vaughan SG, Cao P, Blaser MJ. Potentiation of Helicobacter pylori vacuolating toxin activity by nicotine and other weak bases. Journal of Infectious Diseases. 1992;166(5):1073-8. [pmid: 1402018].
Cross CE, Traber M, Eiserich J, van der Vliet A. Micro-nutrient antioxidants and smoking. British Medical Bulletin. 1999;55(3):691-704. [pmid: 10746357].
Cumming RG, Klineberg RJ. Case-control study of risk factors for hip fractures in the elderly. American Journal of Epidemiology. 1994;139(5):493-503. [pmid: 8154473].
Cumming RG, Mitchell P. Alcohol, smoking, and cataracts: the Blue Mountains Eye Study. Archives of Ophthalmology. 1997;115(10):1296-303. [pmid: 9338677].
Cummings SR, Black DM, Nevitt MC, Browner W, Cauley J, Ensrud K, Genant HK, Palermo L, Scott J, Vogt TM. Bone density at various sites for prediction of hip fractures. Lancet. 1993;341(8837):72-5. [pmid: 8093403].
Cummings SR, Nevitt MC, Browner WS, Stone K, Fox KM, Ensrud KE, Cauley J, Black D, Vogt TM. Risk factors for hip fracture in white women: the Study of Osteoporotic Fractures Research Group. New England Journal of Medicine. 1995;332(12):767-73. [pmid: 7862179].
Cutler AF, Schubert TT. Patient factors affecting Helicobacter pylori eradication with triple therapy. American Journal of Gastroenterology. 1993;88(4):505-9. [pmid: 8470629].
D’Agostino RS, Svensson LG, Neumann DJ, Balkhy H, Williamson WA, Shahian D. Screening carotid ultrasonography and risk factors for stroke in coronary artery surgery patients. Annals of Thoracic Surgery. 1996;62(6):1714-23. [pmid: 8957376].
Danesh J, Muir J, Wong Y-k, Ward M, Gallimore JR, Pepys MB. Risk factors for coronary heart disease and acute-phase proteins. European Heart Journal. 1999;20(13):954-9. [pmid: 10361047].
Daniel M, Martin AD, Drinkwater DT. Cigarette smoking, steroid hormones, and bone mineral density in young women. Calcified Tissue International. 1992;50(4):300-5. [pmid: 1571840].
Danielsen B, Manji F, Nagelkerke N, Fejerskov O, Baelum V. Effect of cigarette smoking on the transition dynamics in experimental gingivitis. Journal of Clinical Periodontology. 1990;17(3):159-64. [pmid: 2319002].
Das I. Raised C-reactive protein levels in serum from smokers. Clinica Chemica Acta. 1985;153(1):9-13.
Dawson DA. Drinking as a risk factor for sustained smoking. Drug and Alcohol Dependence. 2000;59(3):235-49. [pmid: 10812284].
de Maat MPM, Pietersma A, Kofflard M, Sluiter W, Kluft C. Association of plasma fibrinogen levels with coronary artery disease, smoking and inflammatory markers. Atherosclerosis. 1996;121(2):185-91. [pmid: 9125293].
Degan P, Bonassi S, De Caterina M, Korkina LG, Pinto L, Scopacasa F, Zatterale A, Calzone R, Pagano G. In vivo accumulation of 8-hydroxy-2′-deoxyguanosine in DNA correlates with release of reactive oxygen species in Fanconi’s anaemia families. Carcinogenesis. 1995;16(4):735-41. [pmid: 7728950].
Delcourt C, Diaz J-L, Ponton-Sanchez A, Papoz L. Smoking and age-related macular degeneration: the POLA study. Archives of Ophthalmology. 1998;116(8):1031-5. [pmid: 9715683].
Dennerstein L, Smith AMA, Morse C. Psychological well-being, mid-life and the menopause. Maturitas. 1994;20(1):1-11. [pmid: 7877515].
DePalma RG, Emsellem HA, Edwards CM, Druy EM, Shultz SW, Miller HC, Bergsrud D. A screening sequence for vasculogenic impotence. Journal of Vascular Surgery. 1987;5(2):228-36. [pmid: 3820400].
Derby CA, Araujo AB, Johannes CB, Feldman HA, McKinlay JB. Measurement of erectile dysfunction in population-based studies: the use of a single question self-assessment in the Massachusetts Male Aging Study. International Journal of Impotence Research. 2000a;12(4):197-204. [pmid: 11079360].
Derby CA, Mohr BA, Goldstein I, Feldman HA, Johannes CB, McKinlay JB. Modifiable risk factors and erectile dysfunction: can life-style changes modify risk?. Urology. 2000b;56(2):302-6. [pmid: 10925098].
Dimberg L, Olafsson A, Stefansson E, Aagaard H, Odén A, Andersson GBJ, Hagert C-G, Hansson T. Sickness absenteeism in an engineering industry—an analysis with special reference to absence for neck and upper extremity symptoms. Scandinavian Journal of Social Medicine. 1989;17(1):77-84. [pmid: 2711149].
Dodsworth H, Dean A, Boom G. Effects of smoking and the pill on blood count. British Journal of Haematology. 1981;49(3):484-8. [pmid: 7295592].
Dolan TA, Gilbert GH, Ringelberg ML, Legler DW, Antonson DE, Foerster U, Heft MW. Behavioral risk indicators of attachment loss in adult Floridians. Journal of Clinical Periodontology. 1997a;24(4):223-32. [pmid: 9144044].
Dolan TA, McGorray SP, Grinstead-Skigen CL, Mecklenburg R. Tobacco control activities in U.S. dental practices. Journal of the American Dental Association. 1997b;128(12):1669-79. [pmid: 9415764].
Doll R, Peto R, Wheatley K, Gray R, Sutherland I. Mortality in relation to smoking: 40 years’ observations on male British doctors. British Medical Journal. 1994;309(6959):901-11. [pmid: 7755693].
Donaldson SI, Sussman S, Dent CW, Severson HH, Stoddard JL. Health behavior, quality of work life, and organizational effectiveness in the lumber industry. Health Education and Behavior. 1999;26(4):579-91. [pmid: 10435239].
Drake CW, Beck JD, Lawrence HP, Koch GG. Three-year coronal caries incidence and risk factors in North Carolina elderly. Caries Research. 1997;31(1):1-7. [pmid: 8955986].
Durak I, Yalein S, Burak Cimen MY, Buyukkocak S, Kacmaz M, Ozturk HS. Effects of smoking on plasma and erythrocyte antioxidant defense systems. Journal of Toxicology and Environmental Health Part A. 1999;56(6):373-8. [pmid: 10096360].
Duthie GG, Arthur JR, Beattie JA, Brown KM, Morrice PC, Robertson JD, Shortt CT, Walker KA, James WP. Cigarette smoking antioxidants, lipid peroxidation, and coronary heart disease. Annals of the New York Academy of Sciences. 1993;686:120-9. [pmid: 8512243].
Eastwood GL. Is smoking still important in the pathogenesis of peptic ulcer disease?. Journal of Clinical Gastroenterology. 1997;25(Suppl 1):S1-S7. [pmid: 9479620].
Edgar W, Higham SM. Saliva and the control of plaque pH. Edgar WM, O’Mullane DM, editors. Saliva and Oral Health. 2nd ed. London. British Dental Association. 1996:81-94.
Edwards N, Boulet J. Implementing breast cancer screening guidelines: results of the Ontario Health Status Survey. American Journal of Preventive Medicine. 1997;13(2):143-9. [pmid: 9088452].
Egger P, Duggleby S, Hobbs R, Fall C, Cooper C. Cigarette smoking and bone mineral density in the elderly. Journal of Epidemiology and Community Health. 1996;50(1):47-50. [pmid: 8762353].
Eichel B, Shahrik HA. Tobacco smoke toxicity: loss of human oral leukocyte function and fluid-cell metabolism. Science. 1969;166(911):1424-8. [pmid: 5350347].
Eickholz P, Hausmann E. Accuracy of radiographic assessment of interproximal bone loss in intrabony defects using linear measurements. European Journal of Oral Sciences. 2000;108(1):70-3. [pmid: 10706480].
Eiserich JP, van der Vliet A, Handelman GJ, Halliwell B, Cross CE. Dietary antioxidants and cigarette smoke–induced bimolecular damage: a complex interaction. American Journal of Clinical Nutrition. 1995;62(6 Suppl):1490S-1500S. [pmid: 7495250].
Eisman JA. Genetics of osteoporosis. Endocrine Reviews. 1999;20(6):788-804. [pmid: 10605626].
Elist J, Jarman WD, Edson M. Evaluating medical treatment of impotence. Urology. 1984;23(4):374-5. [pmid: 6710711].
El-Serag HB, Sonnenberg A. Opposing time trends of peptic ulcer and reflux disease. Gut. 1998;43(3):327-33. [pmid: 9863476].
Elter JR, Beck JD, Slade GD, Offenbacher S. Etiologic models for incident periodontal attachment loss in older adults. Journal of Clinical Periodontology. 1999;26(2):113-23. [pmid: 10048646].
Endoh K, Leung FW. Effect of smoking and nicotine on the gastric mucosa: a review of clinical and experimental evidence. Gastroenterology. 1994;107(3):864-78. [pmid: 7915701].
Ensrud KE, Palermo L, Black DM, Cauley J, Jergas M, Orwoll ES, Nevitt MC, Fox KM, Cummings SR. Hip and calcaneal bone loss increase with advancing age: longitudinal results from the study of osteoporotic fractures. Journal of Bone and Mineral Research. 1995;10(11):1778-87. [pmid: 8592956].
Erdmann MW, Court-Brown CM, Quaba AA. A five year review of islanded distally based fasciocutaneous flaps on the lower limb. British Journal of Plastic Surgery. 1997;50(6):421-7. [pmid: 9326145].
Erickson P. Evaluation of a population-based measure of quality of life: the Health and Activity Limitation Index (HALex). Quality of Life Research. 1998;7(2):101-14. [pmid: 9523491].
Espehaug B, Havelin LI, Engesaeter LB, Langeland N, Vollset SE. Patient-related risk factors for early revision of total hip replacements: a population register-based case-control study of 674 revised hips. Acta Orthopaedica Scandinavica. 1997;68(3):207-15. [pmid: 9246978].
EUROGAST Study Group. Epidemiology of, and risk factors for, Helicobacter pylori infection among 3194 asymptomatic subjects in 17 populations. Gut. 1993;34(12):1672-6. [pmid: 8282253].
Everhart JE, Byrd-Holt D, Sonnenberg A. Incidence and risk factors for self-reported peptic ulcer disease in the United States. American Journal of Epidemiology. 1998;147(6):529-36. [pmid: 9521179].
Eye Disease Case-Control Study Group. Risk factors for neovascular age-related macular degeneration. Archives of Ophthalmology. 1992;110(12):1701-8. [pmid: 1281403].
Faddy MJ, Cullinan MP, Palmer JE, Westerman B, Seymour GJ. Ante-dependence modeling in a longitudinal study of periodontal disease: the effect of age, gender, and smoking status. Journal of Periodontology. 2000;71(3):454-9. [pmid: 10776934].
Fang MA, Frost PJ, Iida-Klein A, Hahn TJ. Effects of nicotine on cellular function in UMR 106-01 osteoblast-like cells. Bone. 1991;12(4):283-6. [pmid: 1793680].
Featherstone JDB. Prevention and reversal of dental caries: role of low level fluoride. Community Dentistry and Oral Epidemiology. 1999;27(1):31-40. [pmid: 10086924].
Fehily AM, Coles RJ, Evans WD, Elwood PC. Factors affecting bone density in young adults. American Journal of Clinical Nutrition. 1992;56(3):579-86. [pmid: 1503072].
Feldman HA, Goldstein I, Hatzichristou DG, Krane RJ, McKinlay JB. Impotence and its medical and psychosocial correlates: results of the Massachusetts Male Aging Study. Journal of Urology. 1994;151(1):54-61. [pmid: 8254833].
Feldman HA, Johannes CB, Derby CA, Kleinman KP, Mohr BA, Araujo AB, McKinlay JB. Erectile dysfunction and coronary risk factors: prospective results from the Massachusetts Male Aging Study. Preventive Medicine. 2000;30(4):328-38. [pmid: 10731462].
Feldman RS, Alman JE, Chauncey HH. Periodontal disease indexes and tobacco smoking in healthy aging men. Gerodontics. 1987;3(1):43-6. [pmid: 3471618].
Feldman RS, Bravacos JS, Rose CL. Association between smoking different tobacco products and periodontal disease indexes. Journal of Periodontology. 1983;54(8):481-7. [pmid: 6578319].
Ferguson D. Sickness absence: an analysis of the problem. The Medical Journal of Australia. 1973;1(7):334-40. [pmid: 4699027].
Fisch IR, Freedman SH. Smoking, oral contraceptives, and obesity: effects on white blood cell count. Journal of the American Medical Association. 1975;234(5):500-6. [pmid: 1242167].
Flaye DE, Sullivan KN, Cullinan TR, Silver JH, Whitlocke RAF. Cataracts and cigarette smoking: the City Eye Study. Eye. 1989;3(Pt 4):379-84. [pmid: 2606211].
Flemmig TF. Periodontitis. Annals of Periodontology. 1999;4(1):32-8. [pmid: 10863373].
Forrester BG, Weaver MT, Brown KC, Phillips JA, Hilyer JC. Personal health-risk predictors of occupational injury among 3415 municipal employees. Journal of Occupational and Environmental Medicine. 1996;38(5):515-21. [pmid: 8733643].
Forsberg L, Gustavii B, Höjerback T, Olsson AM. Impotence, smoking and β-blocking drugs. Fertility and Sterility. 1979;31(5):589-91. [pmid: 446783].
Forsberg L, Hederström E, Olsson AM. Severe arterial insufficiency in impotence confirmed with an improved angiographic technique: the impact of smoking and some other etiologic factors. European Urology. 1989;16(5):357-60. [pmid: 2776807].
Forsén L, Bjartveit K, Bjørndal A, Edna T-H, Meyer HE, Schei B. Ex-smokers and risk of hip fracture. American Journal of Public Health. 1998;88(10):1481-3. [pmid: 9772848].
Forsén L, Bjørndal A, Bjartveit K, Edna T-H, Holmen J, Jessen V, Westberg G. Interaction between current smoking, leanness, and physical inactivity in the prediction of hip fracture. Journal of Bone and Mineral Research. 1994;9(11):1671-8. [pmid: 7863817].
Fraser AG, Moore L, Ali MR, Chua LE, Hollis B, Little SV. An audit of low dose triple therapy for eradication of Helicobacter pylori. New Zealand Medical Journal. 1996;109(1027):290-2. [pmid: 8773671].
Freeborn DK, Mullooly JP, Pope CR, McFarland BH. Smoking and consistently high use of medical care among older HMO members. American Journal of Public Health. 1990;80(5):603-5. [pmid: 2327540].
Fried LP, Moore RD, Pearson TA. Long-term effects of cigarette smoking and moderate alcohol consumption on coronary artery diameter: mechanisms of coronary artery disease independent of atherosclerosis or thrombosis. American Journal of Medicine. 1986;80(1):37-44. [pmid: 3942153].
Friedman GD, Siegelaub AB. Changes after quitting cigarette smoking. Circulation. 1980;61(4):716-23. [pmid: 7357713].
Friedman GD, Siegelaub AB, Seltzer CC, Feldman R, Collen MF. Smoking habits and the leukocyte count. Archives of Environmental Health. 1973;26(3):137-43. [pmid: 4688852].
Fujisawa T, Iizasa T, Saitoh Y, Sekine Y, Motohashi S, Yasukawa T, Shibuya K, Hiroshima K, Ohwada H. Smoking before surgery predicts poor long-term survival in patients with stage I non-small-cell lung carcinomas. Journal of Clinical Oncology. 1999;17(7):2086-91. [pmid: 10561262].
Fujiwara S, Kasagi F, Yamada M, Kodama K. Risk factors for hip fracture in a Japanese cohort. Journal of Bone and Mineral Research. 1997;12(7):998-1004. [pmid: 9199997].
Fylkesnes K, Førde O. The Tromsø study: predictors of self-evaluated health—has society adopted the expanded health concept?. Social Science and Medicine. 1991;32(2):141-6. [pmid: 2014409].
Gallop B. Sickness absenteeism and smoking. New Zealand Medical Journal. 1989;102(863):112. [pmid: 2927799].
Ganley JP. Epidemiologic characteristics of presumed ocular histoplasmosis. Acta Ophthalmologica Supplement. 1973;119:1-63.
Gärdsell P, Johnell O, Nilsson BE. Predicting fractures in women by using forearm bone densitometry. Calcified Tissue International. 1989;44(4):235-42. [pmid: 2501005].
Gelskey SC, Young TK, Singer DL. Factors associated with adult periodontitis in a dental teaching clinic population. Community Dentistry and Oral Epidemiology. 1998;26(4):226-32. [pmid: 9758422].
Genco RJ. Classification and clinical and radiographic features of periodontal disease. Genco RJ, Goldman HM, Cohen DW, editors. Contemporary Periodontics. St. Louis. CV Mosby Company. 1990a:63-81.
Genco RJ. Periodontal diagnosis, prognosis, and treatment planning. Genco RJ, Goldman HM, Cohen DW, editors. Contemporary Periodontics. St. Louis. CV Mosby Company. 1990b:348-59.
Genco RJ. Current view of risk factors for periodontal diseases. Journal of Periodontology. 1996;67(10 Suppl):1041-9. [pmid: 8910821].
Genco RJ. Risk factors for periodontal disease. Rose LF, Genco RJ, Cohen DW, Mealey BL, editors. Periodontal Medicine. St. Louis. BC Decker. 2000:11-33.
Gentile AT, Mills JL, Gooden MA, Westerband A, Cui H, Berman SS, Hunter GC, Hughes JD. Identification of predictors for lower extremity vein graft stenosis. American Journal of Surgery. 1997;174(2):218-21. [pmid: 9293849].
George LL, Borody TJ, Andrews P, Devine M, Moore-Jones D, Walton M, Brandl S. Cure of duodenal ulcer after eradication of Helicobacter pylori. Medical Journal of Australia. 1990;153(3):145-9. [pmid: 1974027].
Georgopoulos SD, Ladas SD, Karatapanis S, Mentis A, Spiliadi C, Artikis V, Raptis SA. Factors that may affect treatment outcome of triple Helicobacter pylori eradication therapy with omeprazole, amoxicillin, and clarithromycin. Digestive Diseases and Sciences. 2000;45(1):63-7. [pmid: 10695615].
Gilbert DG, Hagen RL, D’Agostino JA. The effects of cigarette smoking on human sexual potency. Addictive Behaviors. 1986;11(4):431-4. [pmid: 3812052].
Giovino GA, Henningfield JE, Tomar SL, Escobedo LG, Slade J. Epidemiology of tobacco use and dependence. Epidemiologic Reviews. 1995;17(1):48-65. [pmid: 8521946].
Glina S, Reichelt AC, Leão PP, dos Reis JMSM. Impact of cigarette smoking on papaverine-induced erection. Journal of Urology. 1988;140(3):523-4. [pmid: 3411666].
Goddard AF, Spiller RC. Helicobacter pylori eradication in clinical practice: one-week low-dose triple therapy is preferable to classical bismuth based triple therapy. Alimentary Pharmacology and Therapeutics. 1996;10(6):1009-13. [pmid: 8971303].
Goh KL. Prevalence of and risk factors for Helicobacter pylori infection in a multi-racial dyspeptic Malaysian population undergoing endoscopy. Journal of Gastroenterology and Hepatology. 1997;12(Suppl):S29-S35. [pmid: 9195409].
Goldberg MS, Scott SC, Mayo NE. A review of the association between cigarette smoking and the development of nonspecific back pain and related outcomes. Spine. 2000;25(8):995-1014. [pmid: 10767814].
Golding J. Unnatural constituents of breast milk— medication, lifestyle, pollutants, viruses. Early Human Development. 1997;49(Suppl):S29-S43. [pmid: 9363416].
Goldstein I, Feldman MI, Deckers PJ, Babayan RK, Krane RJ. Radiation-associated impotence: a clinical study of its mechanism. Journal of the American Medical Association. 1984;251(7):903-10. [pmid: 6694291].
Goldstein I, Hatzichristou D. Epidemiology of impotence. Bennett AH, editor. Impotence: Diagnosis and Management of Erectile Dysfunction. Philadelphia. W.B. Saunders Company. 1994:1-17.
Golosow LM, Wagner JD, Feeley M, Sharp T, Havlik R, Sood R, Coleman JJ. Risk factors for predicting surgical salvage of sternal wound-healing complications. Annals of Plastic Surgery. 1999;43(1):30-5. [pmid: 10402984].
González YM, De Nardin A, Grossi SG, Machtei EE, Genco RJ, De Nardin E. Serum cotinine levels, smoking, and periodontal attachment loss. Journal of Dental Research. 1996;75(2):796-802. [pmid: 8655777].
Goodman CM, Cohen V, Armenta A, Thornby J, Netscher DT. Evaluation of results and treatment variables for pressure ulcers in 48 veteran spinal cord-injured patients. Annals of Plastic Surgery. 1999;42(6):665-72. [pmid: 10382806].
Goodson JM. Selection of suitable indicators of periodontitis. Bader JD, editor. Risk Assessment in Dentistry: Proceedings of a Conference. June 2–3, 1989. Chapel Hill (NC). University of North Carolina. Dental Ecology. 1990:69-74.
Goultschin J, Cohen HDS, Donchin M, Brayer L, Soskolne WA. Association of smoking with periodontal treatment needs. Journal of Periodontology. 1990;61(6):364-7. [pmid: 2366143].
Graham DY, Lew GM, Malaty HM, Evans DG, Evans DJ Jr, Klein PD, Alpert LC, Genta RM. Factors influencing the eradication of Helicobacter pylori with triple therapy. Gastroenterology. 1992;102(2):493-6. [pmid: 1732120].
Graham DY, Malaty HM, Evans DG, Evans DJ Jr, Klein PD, Adam E. Epidemiology of Helicobacter pylori in an asymptomatic population in the United States: effect of age, race, and socioeconomic status. Gastroenterology. 1991;100(6):1495-501. [pmid: 2019355].
Grainge MJ, Coupland CAC, Cliffe SJ, Chilvers CED, Hosking DJ. Cigarette smoking, alcohol and caffeine consumption, and bone mineral density in post-menopausal women: the Nottingham EPIC Study Group. Osteoporosis International. 1998;8(4):355-63. [pmid: 10024906].
Gray RS, Starkey IR, Rainbow S, Kurtz AB, Abdel-Khalik A, Urbaniak S, Elton RA, Duncan LJP, Clarke BF. HLA antigens and other risk factors in the development of retinopathy in type 1 diabetes. British Journal of Ophthalmology. 1982;66(5):280-5. [pmid: 7074002].
Green MS, Luz J, Gofer D. Absence from work among smokers and nonsmokers in Israeli industries—the Cordis Study. Israel Journal of Medical Sciences. 1992;28(8–9):645-9. [pmid: 1428824].
Gregg EW, Cauley JA, Seeley DG, Ensrud KE, Bauer DC. Physical activity and osteoporotic fracture risk in older women: Study of Osteoporotic Fractures Research Group. Annals of Internal Medicine. 1998;129(2):81-8. [pmid: 9669990].
Gregg EW, Kriska AM, Salamone LM, Wolf RL, Roberts MM, Ferrell RE, Anderson SJ, Kuller LH, Cauley JA. Correlates of quantitative ultrasound in the Women’s Healthy Lifestyle Project. Osteoporosis International. 1999;10(5):416-24. [pmid: 10591840].
Grembowski D, Patrick D, Diehr P, Durham M, Beresford S, Kay E, Hecht J. Self-efficacy and health behavior among older adults. Journal of Health and Social Behavior. 1993;34(2):89-104. [pmid: 8277130].
Grisso JA, Kelsey JL, O’Brien LA, Miles CG, Sidney S, Maislin G, La Pann K, Moritz D, Peters B. Risk factors for hip fracture in men: Hip Fracture Study Group. American Journal of Epidemiology. 1997;145(9):786-93. [pmid: 9143208].
Grisso JA, Kelsey JL, Strom BL, O’Brien LA, Maislin G, LaPann K, Samelson L, Hoffman S. Risk factors for hip fracture in black women: the Northeast Hip Fracture Study Group. New England Journal of Medicine. 1994;330(22):1555-9. [pmid: 8177244].
Grossi SG, Genco RJ, Machtei EE, Ho AW, Koch G, Dunford R, Zambon JJ, Hausmann E. Assessment of risk for periodontal disease. II: risk indicators for alveolar bone loss. Journal of Periodontology. 1995;66(1):23-9. [pmid: 7891246].
Grossi SG, Skrepcinski FB, DeCaro T, Zambon JJ, Cummins D, Genco RJ. Response to periodontal therapy in diabetics and smokers. Journal of Periodontology. 1996;67(10 Suppl):1094-102. [pmid: 8910828].
Grossi SG, Zambon J, Machtei EE, Schifferle R, Andreana S, Genco RJ, Cummins D, Harrap G. Effects of smoking and smoking cessation on healing after mechanical periodontal therapy. Journal of the American Dental Association. 1997;128(5):599-607. [pmid: 9150643].
Grossi SG, Zambon JJ, Ho AW, Koch G, Dunford RG, Machtei EE, Norderyd OM, Genco RJ. Assessment of risk for periodontal disease. I: risk indicators for attachment loss. Journal of Periodontology. 1994;65(3):260-7. [pmid: 8164120].
Guay AT, Perez JB, Heatley GJ. Cessation of smoking rapidly decreases erectile dysfunction. Endocrine Practice. 1998;4(1):23-6. [pmid: 15251760].
Gunsolley JC, Quinn SM, Tew J, Gooss CM, Brooks CN, Schenkein HA. The effect of smoking on individuals with minimal periodontal destruction. Journal of Periodontology. 1998;69(2):165-70. [pmid: 9526915].
Guralnik JM, Kaplan GA. Predictors of healthy aging: prospective evidence from the Alameda County Study. American Journal of Public Health. 1989;79(6):703-8. [pmid: 2729467].
Guthrie JR, Ebeling PR, Hopper JL, Barrett-Connor E, Dennerstein L, Dudley EC, Burger HG, Wark JD. A prospective study of bone loss in menopausal Australian-born women. Osteoporosis International. 1998;8(3):282-90. [pmid: 9797914].
Guthrie JR, Ebeling PR, Hopper JL, Dennerstein L, Wark JD, Burger HG. Bone mineral density and hormone levels in menopausal Australian women. Gynecological Endocrinology. 1996;10(3):199-205. [pmid: 8862496].
Haber J, Kent RL. Cigarette smoking in a periodontal practice. Journal of Periodontology. 1992;63(2):100-6. [pmid: 1552463].
Haber J, Wattles J, Crowley M, Mandell R, Joshipura K, Kent RL. Evidence for cigarette smoking as a major risk factor for periodontitis. Journal of Periodontology. 1993;64(1):16-23. [pmid: 8426285].
Hägg E, Asplund K. Is endocrine ophthalmopathy related to smoking?. British Medical Journal (Clinical Research Edition). 1987;295(6599):634-5.
Hagiwara S, Tsumura K. Smoking as a risk factor for bone mineral density in the heel of Japanese men. Journal of Clinical Densitometry. 1999;2(3):219-22. [pmid: 10548817].
Halpern MT, Warner KE. Differences in former smokers’ beliefs and health status following smoking cessation. American Journal of Preventive Medicine. 1994;10(1):31-7. [pmid: 8172729].
Halter F, Brignoli R. Helicobacter pylori and smoking: two additive risk factors for organic dyspepsia. Yale Journal of Biology and Medicine. 1998;71(2):91-9. [pmid: 10378354].
Hammond EC. Evidence on the effects of giving up cigarette smoking. American Journal of Public Health. 1965;55(5):682-91. [pmid: 14287838].
Hammond BR Jr, Wooten BR, Snodderly DM. Cigarette smoking and retinal carotenoids: implications for age-related macular degeneration. Vision Research. 1996;36(18):3003-9. [pmid: 8917800].
Handelman GJ, van Kuijk FJGM, Chatterjee A, Krinsky NI. Characterization of products formed during the autoxidation of β-carotene. Free Radical Biology and Medicine. 1991;10(6):427-37. [pmid: 1894165].
Hanes PJ, Schuster GS, Lubas S. Binding, uptake, and release of nicotine by human gingival fibroblasts. Journal of Periodontology. 1991;62(2):147-52. [pmid: 2027063].
Hankinson SE, Willett WC, Colditz GA, Seddon JM, Rosner B, Speizer FE, Stampfer MJ. A prospective study of cigarette smoking and risk of cataract surgery in women. Journal of the American Medical Association. 1992;268(8):994-8. [pmid: 1501325].
Hannan MT, Felson DT, Dawson-Hughes B, Tucker KL, Cupples LA, Wilson PWF, Kiel DP. Risk factors for longitudinal bone loss in elderly men and women: the Framingham Osteoporosis Study. Journal of Bone and Mineral Research. 2000;15(4):710-20. [pmid: 10780863].
Hansen BF, Bjertness E, Gjermo P. Changes in periodontal disease indicators in 35-year-old Oslo citizens from 1973 to 1984. Journal of Clinical Periodontology. 1990a;17(4):249-54. [pmid: 2347950].
Hansen JM, Hallas J, Lauritsen JM, Bytzer P. Non-steroidal anti-inflammatory drugs and ulcer complications: a risk factor analysis for clinical decision-making. Scandinavian Journal of Gastroenterology. 1996;31(2):126-30. [pmid: 8658033].
Hansen LK, Grimm RH Jr, Neaton JD. The relationship of white blood cell count to other cardiovascular risk factors. International Journal of Epidemiology. 1990b;19(4):881-8. [pmid: 2084016].
Hansen MA, Overgaard K, Riis BJ, Christiansen C. Potential risk factors for development of postmenopausal osteoporosis—examined over a 12-year period. Osteoporosis International. 1991;1(2):95-102. [pmid: 1790399].
Harats D, Ben-Naim M, Dabach Y, Hollander G, Havivi E, Stein O, Stein Y. Effect of Vitamin C and E supplementation on susceptibility of plasma lipoproteins to peroxidation induced by acute smoking. Atherosclerosis. 1990;85(1):47-54. [pmid: 2282108].
Harats D, Ben-Naim M, Dabach Y, Hollander G, Stein O, Stein Y. Cigarette smoking renders LDL susceptible to peroxidative modification and enhanced metabolism by macrophages. Atherosclerosis. 1989;79(2–3):245-52. [pmid: 2597232].
Harding J. Cataract: Biochemistry, Epidemiology, and Pharmacology. London. Chapman and Hall. 1991.
Harding JJ. Cigarettes and cataract: cadmium or a lack of vitamin C?. British Journal of Ophthalmology. 1995;79(3):199-200. [pmid: 7703192].
Harding JJ, Van Heyningen R. Drugs, including alcohol, that act as risk factors for cataract, and possible protection against cataract by aspirin-like analgesics and cyclopenthiazide. British Journal of Ophthalmology. 1988;72(11):809-14. [pmid: 3207655].
Harris AW, Pryce DI, Gabe SM, Karim QN, Walker MM, Langworthy H, Baron JH, Misiewicz JJ. Lansoprazole, clarithromycin and metronidazole for seven days in Helicobacter pylori infection. Alimentary Pharmacology and Therapeutics. 1996;10(6):1005-8. [pmid: 8971302].
Hart GT, Brown DM, Mincer HH. Tobacco use and dental disease. Journal of the Tennessee Dental Association. 1995;75(2):25-7. [pmid: 9520770].
Hasebe T, Harasawa S, Miwa T. Factors affecting depth of gastric ulcers. Tokai Journal of Experimental Clinical Medicine. 1998;23(4):177-82.
Haverstock BD, Mandracchia VJ. Cigarette smoking and bone healing: implications in foot and ankle surgery. Journal of Foot and Ankle Surgery. 1998;37(1):69-74. [pmid: 9470121].
Hawker R, Holtby I. Smoking and absence from work in a population of student nurses. Public Health. 1988;102(2):161-7. [pmid: 3375415].
Hecht SS. Tobacco smoke carcinogens and lung cancer. Journal of the National Cancer Institute. 1999;91(14):1194-210. [pmid: 10413421].
Heinemann G, Schievelbein H, Eber S. Effect of cigarette smoking on white blood cells and erythrocyte enzymes. Archives of Environmental Health. 1982;37(5):261-5. [pmid: 7138074].
Heintze U. Secretion rate, buffer effect and number of lactobacilli and Streptococcus mutans of whole saliva of cigarette smokers and nonsmokers. Scandinavian Journal of Dental Research. 1984;92(4):294-301. [pmid: 6591365].
Helman N, Rubenstein LS. The effects of age, sex, and smoking on erythrocytes and leukocytes. American Journal of Clinical Pathology. 1975;63(1):35-44. [pmid: 1111274].
Hemenway D, Colditz GA, Willett WC, Stampfer MJ, Speizer FE. Fractures and lifestyle: effect of cigarette smoking, alcohol intake, and relative weight on the risk of hip and forearm fractures in middle-aged women. American Journal of Public Health. 1988;78(12):1554-8. [pmid: 3189632].
Hendrix WH, Taylor GS. A multivariate analysis of the relationship between cigarette smoking and absence from work. American Journal of Health Promotion. 1987;2(2):5-11. [pmid: 22208508].
Hentschel E, Brandstätter G, Dragosics B, Hirschl AM, Nemec H, Schütze K, Taufer M, Wurzer H. Effect of ranitidine and amoxicillin plus metronidazole on the eradication of Helicobacter pylori and the recurrence of duodenal ulcer. New England Journal of Medicine. 1993;328(5):308-12. [pmid: 8419816].
Hermann AP, Brot C, Gram J, Kolthoff N, Mosekilde L. Premenopausal smoking and bone density in 2015 perimenopausal women. Journal of Bone and Mineral Reseach. 2000;15(4):780-7.
Hildebolt CF, Pilgram TK, Dotson M, Yokoyama-Crothers N, Muckerman J, Hauser J, Cohen S, Kardaris E, Vannier MW, Hanes P, Shrout MK, Civitelli R. Attachment loss with postmenopausal age and smoking. Journal of Periodontal Research. 1997;32(7):619-25. [pmid: 9401935].
Hiller R, Sperduto RD, Podgor MJ, Wilson PWF, Ferris FL III, Colton T, D’Agostino RB, Roseman MJ, Stockman ME, Milton RC. Cigarette smoking and the risk of development of lens opacities: the Framingham studies. Archives of Ophthalmology. 1997;115(9):1113-8. [pmid: 9298050].
Hirsch JM, Livian G, Edward S, Noren JG. Tobacco habits among teenagers in the city of Göteborg, Sweden, and possible association with dental caries. Swedish Dental Journal. 1991;15(3):117-23. [pmid: 1876978].
Hirshkowitz M, Karacan I, Howell JW, Arcasoy MO, Williams RL. Nocturnal penile tumescence in cigarette smokers with erectile dysfunction. Urology. 1992;39(2):101-7. [pmid: 1736499].
Hodgson TA. Cigarette smoking and lifetime medical expenditures. Milbank Quarterly. 1992;70(1):81-125. [pmid: 1588892].
Hogarty V, May H, Khaw KT. White blood cell count, blood pressure, and cigarette smoking in older adults. Journal of American Geriatric Society. 1995;43(7):837-8.
Høidrup S, Grønbæk M, Pedersen AT, Lauritzen JB, Gottschau A, Schroll M. Hormone replacement therapy and hip fracture risk: effect modification by tobacco smoking, alcohol intake, physical activity, and body mass index. American Journal of Epidemiology. 1999;150(10):1085-93. [pmid: 10568624].
Høidrup S, Prescott E, Sørensen TIA, Gottschau A, Lauritzen JB, Schroll M, Grønbaek M. Tobacco smoking and risk of hip fracture in men and women. International Journal of Epidemiology. 2000;29(2):253-9. [pmid: 10817121].
Holbrook TL, Barrett-Connor E, Wingard DL. Dietary calcium and risk of hip fracture: 14-year prospective population study. Lancet. 1988;2(8619):1046-9. [pmid: 2903278].
Holcomb HS III, Meigs JW. Medical absenteeism among cigarette, and cigar and pipe smokers. Archives of Environmental Health. 1972;25(4):295-300. [pmid: 5055681].
Hollenbach KA, Barrett-Connor E, Edelstein SL, Holbrook T. Cigarette smoking and bone mineral density in older men and women. American Journal of Public Health. 1993;83(9):1265-70. [pmid: 8363002].
Hollinger JO, Schmitt JM, Hwang K, Soleymani P, Buck D. Impact of nicotine on bone healing. Journal of Biomedical Materials Research. 1999;45(4):294-301. [pmid: 10321701].
Holló I, Gergely I, Boross M. Influence of heavy smoking upon the bone mineral content of the radius of the aged and effect of tobacco smoke on the sensitivity to calcitonin of rats. Aktuelle Gerontologie. 1979;9(8):365-8. [pmid: 39459].
Honkanen R, Tuppurainen M, Kröger H, Alhava E, Saarikoski S. Relationships between risk factors and fractures differ by type of fracture: a population-based study of 12,192 perimenopausal women. Osteoporosis International. 1998;8(1):25-31. [pmid: 9692074].
Hopper JL, Seeman E. The bone density of female twins discordant for tobacco use. New England Journal of Medicine. 1994;330(6):387-92. [pmid: 8284003].
Horning GM, Hatch CL, Cohen ME. Risk indicators for periodontitis in a military treatment population. Journal of Periodontology. 1992;63(4):297-302. [pmid: 1573543].
Hovell MF, Slymen DJ, Jones JA, Hofstetter CR, Burkham-Kreitner S, Conway TL, Rubin B, Noel D. An adolescent tobacco-use prevention trial in orthodontic offices. American Journal of Public Health. 1996;86(12):1760-6. [pmid: 9003134].
Howell RW. Smoking habits and laboratory tests. Lancet. 1970;2(7664):152. [pmid: 4194535].
Hui SL, Slemenda CW, Johnston CC Jr. Baseline measurement of bone mass predicts fracture in white women. Annals of Internal Medicine. 1989;111(5):355-61. [pmid: 2764403].
Huopio J, Kröger H, Honkanen R, Saarikoski S, Alhava E. Risk factors for perimenopausal fractures: a prospective study. Osteoporosis International. 2000;11(3):219-27. [pmid: 10824237].
Husgafvel-Pursiainen K. Sister-chromatid exchange and cell proliferation in cultured lymphocytes of passively and actively smoking restaurant personnel. Mutation Research. 1987;190(3):211-5. [pmid: 3821782].
Huuskonen J, Väisänen SB, Kröger H, Jurvelin C, Bouchard C, Alhava E, Rauramaa R. Determinants of bone mineral density in middle-aged men: a population-based study. Osteoporosis International. 2000;11(8):702-8. [pmid: 11095174].
Hyman LG, Lilienfeld AM, Ferris FL III, Fine SL. Senile macular degeneration: a case-control study. American Journal of Epidemiology. 1983;118(2):213-27. [pmid: 6881127].
Imaki M, Yoshida Y, Tanada S. Relation between smoking and periodontal disease by oral hygiene status in Japanese factory workers. Applied Human Science. 1997;16(2):77-81. [pmid: 9164011].
Ismail AI, Burt BA, Eklund SA. Epidemiologic patterns of smoking and periodontal disease in the United States. Journal of the American Dental Association. 1983;106(5):617-21. [pmid: 6575080].
Ismail AI, Morrison EC, Burt BA, Caffesse RG, Kavanagh MT. Natural history of periodontal disease in adults: findings from the Tecumseh Periodontal Disease Study, 1959–87. Journal of Dental Research. 1990;69(2):430-5. [pmid: 2407756].
Italian-American Cataract Study Group. Risk factors for age-related cortical, nuclear, and posterior sub-capsular cataracts. American Journal of Epidemiology. 1991;133(6):541-53. [pmid: 1672483].
Jackson SE, Chenoweth D, Glover ED, Holbert D, White D. Study indicates smoking cessation improves workplace absenteeism rate. Occupational Health and Safety. 15. 1989;58(13):13-6. 18. [pmid: 2601927].
Jacqmin-Gadda H, Fourrier A, Commenges D, Dartigues J-F. Risk factors for fractures in the elderly. Epidemiology. 1998;9(4):417-23. [pmid: 9647906].
Jaglal SB, Kreiger N, Darlington G. Past and recent physical activity and risk of hip fracture. American Journal of Epidemiology. 1993;138(2):107-18. [pmid: 8342529].
James JA, Sayers NM, Drucker DB, Hull PS. Effects of tobacco products on the attachment and growth of periodontal ligament fibroblasts. Journal of Periodontology. 1999;70(5):518-25. [pmid: 10368056].
Janzon L, Lindell SE, Trell E, Larme P. Smoking habits and carboxyhaemoglobin: a cross-sectional study of an urban population of middle-aged men. Journal of Epidemiology and Community Health. 1981;35(4):271-3. [pmid: 7200119].
Jeffrey RW, Forster JL, Baxter JE, French SA, Kelder SH. An empirical evaluation of the effectiveness of tangible incentives in increasing participation and behavior change in a worksite health promotion program. American Journal of Health Promotion. 1993;8(2):98-100. [pmid: 10146823].
Jensen GF. Osteoporosis of the slender smoker revisited by epidemiologic approach. European Journal of Clinical Investigation. 1986;16(3):239-42. [pmid: 3089821].
Jensen JS. Determining factors for the mortality following hip fractures. Injury. 1984;15(6):411-4. [pmid: 6724688].
Jensen EJ, Pedersen B, Fredericksen R, Dahl R. Prospective study on the effect of smoking and nicotine substitution on leucocyte blood counts and relation between blood leucocytes and lung function. Thorax. 1998;53(9):784-9. [pmid: 10319062].
Jensen J, Christiansen C. Effects of smoking on serum lipoproteins and bone mineral content during post-menopausal hormone replacement therapy. American Journal of Obstetrics and Gynecology. 1988;159(4):820-5. [pmid: 2972209].
Jensen J, Christiansen C, Rødbro P. Cigarette smoking, serum estrogens, and bone loss during hormone-replacement therapy early after menopause. New England Journal of Medicine. 1985;313(16):973-5. [pmid: 4047104].
Jensen JS, Tondevold E. Mortality after hip fractures. Acta Orthopaedica Scandinavica. 1979;50(2):161-7. [pmid: 433578].
Jette AM, Feldman HA, Tennstedt SL. Tobacco use: a modifiable risk factor for dental disease among the elderly. American Journal of Public Health. 1993;83(9):1271-6. [pmid: 8363003].
Johannes CB, Araujo AB, Feldman HA, Derby CA, Kleinman KP, McKinlay JB. Incidence of erectile dysfunction in men 40 to 69 years old: longitudinal results from the Massachusetts Male Aging Study. Journal of Urology. 2000;163(2):460-3. [pmid: 10647654].
Johansson C, Mellström D, Lerner U, Österberg T. Coffee drinking: a minor risk factor for bone loss and fractures. Age and Ageing. 1992;21(1):20-6. [pmid: 1553855].
Johnell O, Nilsson BE. Life-style and bone mineral mass in perimenopausal women. Calcified Tissue International. 1984;36(4):354-6. [pmid: 6435833].
Johnson GK, Fung YK, Squier CA. Effects of systemic administration of nicotine on capillaries in rat oral mucosa. Journal of Oral Pathology and Medicine. 1989;18(4):230-2. [pmid: 2769595].
Johnson GK, Todd GL, Johnson WT, Fung YK, Dubois LM. Effects of topical and systemic nicotine on gingival blood flow in dogs. Journal of Dental Research. 1991;70(5):906-9. [pmid: 2022772].
Jones G, Nguyen T, Sambrook P, Kelly PJ, Eisman JA. Progressive loss of bone in the femoral neck in elderly people: longitudinal findings from the Dubbo osteoporosis epidemiology study. British Medical Journal. 1994;309(6956):691-5. [pmid: 7950520].
Jones G, Scott FS. A cross-sectional study of smoking and bone mineral density in premenopausal parous women: effect of body mass index, breastfeeding, and sports participation. Journal of Bone and Mineral Research. 1999;14(9):1628-33. [pmid: 10469293].
Jones RC, Bly JL, Richardson JE. A study of a work site health promotion program and absenteeism. Journal of Occupational Medicine. 1990;32(2):95-9. [pmid: 2303925].
Jorgensen LN, Kallehave F, Christensen E, Siana JE, Gottrup F. Less collagen production in smokers. Surgery. 1998;123(4):450-5. [pmid: 9551072].
Joung IMA, Stronks K, van de Mheen H, Mackenbach JP. Health behaviors explain part of the differences in self-reported health associated with partner/marital status in The Netherlands. Journal of Epidemiology and Community Health. 1995;49(5):482-8. [pmid: 7499990].
Juenemann K-P, Lue TF, Luo J-A, Benowitz NL, Abozeid M, Tanagho EA. The effect of cigarette smoking on penile erection. Journal of Urology. 1987;138(2):438-41. [pmid: 3599273].
Jyotheeswaran S, Shah AN, Jin HO, Potter GD, Ona FV, Chey WY. Prevalence of Helicobacter pylori in peptic ulcer patients in Greater Rochester, NY: is empirical triple therapy justified?. American Journal of Gastroenterology. 1998;93(4):574-8. [pmid: 9576450].
Kadayifçi A, Simsek H. Does smoking influence the eradication of Helicobacter pylori and duodenal ulcer healing with different regimens?. International Journal of Clinical Practice. 1997;51(8):516-7. [pmid: 9536607].
Kadioĝlu A, Erdoĝru T, Karşida K, Dinççaĝ N, Satman I, Yilmaz M, Tellaloĝlu S. Evaluation of penile arterial system with color Doppler ultrasonography in nondiabetic and diabetic males. European Urology. 1995;27(4):311-4. [pmid: 7656908].
Kaldahl WB, Johnson GK, Patil KD, Kalkwarf KL. Levels of cigarette consumption and response to periodontal therapy. Journal of Periodontology. 1996;67(7):675-81. [pmid: 8832478].
Källestål C. Dental caries in 16- and 18-year-old adolescents in northern Sweden. Scandinavian Journal of Dental Research. 1991;99(2):100-5. [pmid: 2052890].
Kallner AB, Hartmann D, Hornig DH. On the requirements of ascorbic acid in man: steady-state turnover and body pool in smokers. American Journal of Clinical Nutrition. 1981;34(7):1347-55. [pmid: 7258125].
Kamada T, Haruma K, Komoto K, Mihara M, Chen X, Yoshihara M, Sumii K, Kajiyama G, Tahara K, Kawamura Y. Effect of smoking and histological gastritis severity on the rate of Helicobacter pylori eradication with omeprazole, amoxicillin, and clarithromycin. Helicobacter. 1999;4(3):204-10. [pmid: 10469195].
Kamma JJ, Nakou M, Baehni PC. Clinical and micro-biological characteristics of smokers with early onset periodontitis. Journal of Periodontal Research. 1999;34(1):25-33. [pmid: 10086883].
Kanis J, Johnell O, Gullberg B, Allander E, Elffors L, Ranstam JP, Dequeker J, Dilsen G, Gennari C, Vaz AL, Lyritis G, Mazzuoli G, Miravet L, Passeri M, Cano RP, Rapado A, Ribot C. Risk factors for hip fracture in men from southern Europe: the MEDOS Study. Mediterranean Osteoporosis Study. Osteoporosis International. 1999;9(1):45-54. [pmid: 10367029].
Kaplan RM, Wingard DL, McPhillips JB, Williams-Jones D, Barrett-Connor E. Cigarette smoking, mortality, institutional and community-based care utilization in an adult community. Journal of Community Health. 1992;17(1):53-60. [pmid: 1564140].
Kaprio J, Koskenvuo M. A prospective study of psychological and socioeconomic characteristics, health behavior and morbidity in cigarette smokers prior to quitting compared to persistent smokers and non-smokers. Journal of Clinical Epidemiology. 1988;41(2):139-50. [pmid: 3335880].
Karacan I, Hirshkowitz M, Howell JW, Arcasoy MO, Acik G, Aydin F, Thornby JI, Williams RL. Smoking more than a pack-per-day has a worsening effect on impotence. Sleep Research. 1988;17:287.
Karacan I, Salis PJ, Williams RL. The role of the sleep laboratory in diagnosis and treatment of impotence. Williams RL, Karacan I, editors. Sleep Disorders: Diagnosis and Treatment. New York. John Wiley and Sons. 1978:353-82.
Kassirer B. Smoking as a risk factor for gingival problems, periodontal problems and caries. University of Toronto Dental Journal. 1994;7(1):6-10. [pmid: 9584769].
Kato I, Nomura AMY, Stemmermann GN, Chyou P-H. A prospective study of gastric and duodenal ulcer and its relation to smoking, alcohol, and diet. American Journal of Epidemiology. 1992;135(5):521-30. [pmid: 1570818].
Kato J, Toniolo P, Zeleniuch-Jacquotte A, Shore RE, Koenig KL, Akhmedkhanov A, Riboli E. Diet, smoking and anthropometric indices and postmenopausal bone fractures: a prospective study. International Journal of Epidemiology. 2000;29(1):85-92. [pmid: 10750608].
Katz RV. Assessing root caries in populations: the evolution of the root caries index. Journal of Public Health Dentistry. 1980;40(1):7-16. [pmid: 6928495].
Kazor C, Taylor GW, Loesche WJ. The prevalence of BANA-hydrolyzing periodontopathic bacteria in smokers. Journal of Clinical Periodontology. 1999;26(12):814-21. [pmid: 10599910].
Kelsey JL, Browner WS, Seeley DG, Nevitt MC, Cummings SR. Risk factors for fractures of the distal forearm and proximal humerus. American Journal of Epidemiology. 1992;135(5):477-89. [See also erratum in American Journal of Epidemiology 1992; 135(10):1183.]. [pmid: 1570814].
Kelsey JL, Hoffman S. Risk factors for hip fracture. New England Journal of Medicine. 1987;316(7):404-6. [pmid: 3807977].
Kempczinski RF. Role of the vascular diagnostic laboratory in the evaluation of male impotence. American Journal of Surgery. 1979;138(2):278-82. [pmid: 464231].
Kenney EB, Kraal JH, Saxe SR, Jones J. The effect of cigarette smoke on human oral polymorphonuclear leukocytes. Journal of Periodontal Research. 1977;12(4):227-34. [pmid: 142132].
Kenzora JE, McCarthy RE, Lowell JD, Sledge CB. Hip fracture mortality: relation to age, treatment, pre-operative illness, time of surgery, and complications. Clinical Orthopaedics and Related Research. 1984;186:45-56. [pmid: 6723159].
Kerdvongbundit V, Wikesjö UME. Effect of smoking on periodontal health in molar teeth. Journal of Periodontology. 2000;71(3):433-7. [pmid: 10776931].
Khaw K-T, Tazuke S, Barrett-Connor E. Cigarette smoking and levels of adrenal androgens in postmenopausal women. New England Journal of Medicine. 1988;318(26):1705-9. [pmid: 2967432].
Khosla S, Melton LJ III, Atkinson EJ, O’Fallon WM, Klee GG, Riggs BL. Relationship of serum sex steroid levels and bone turnover markers with bone mineral density in men and women: a key role for bioavailable estrogen. Journal of Clinical Endocrinology and Metabolism. 1998;83(7):2266-74. [pmid: 9661593].
Kiel DP, Baron JA, Anderson JJ, Hannan MT, Felson DT. Smoking eliminates the protective effect of oral estrogens on the risk for hip fracture among women. Annals of Internal Medicine. 1992;116(9):716-21. [pmid: 1558342].
Kiel DP, Felson DT, Anderson JJ, Wilson PWF, Moskowitz MA. Hip fracture and the use of estrogens in postmenopausal women: the Framingham Study. New England Journal of Medicine. 1987;317(19):1169-74. [pmid: 3657888].
Kiel DP, Zhang Y, Hannan MT, Anderson JJ, Baron JA, Felson DT. The effect of smoking at different life stages on bone mineral density in elderly men and women. Osteoporosis International. 1996;6(3):240-8. [pmid: 8783299].
Kim C-H, Kim YI, Choi CS, Park JY, Lee MS, Lee S-I, Kim GS. Prevalence and risk factors of low quantitative ultrasound values of calcaneus in Korean elderly women. Ultrasound in Medicine and Biology. 2000;26(1):35-40. [pmid: 10687790].
Kinane DF, Radvar M. The effect of smoking on mechanical and antimicrobial periodontal therapy. Journal of Periodontology. 1997;68(5):467-72. [pmid: 9182742].
Kingsley LA, Dorman JS, Doft BH, Orchard TJ, LaPorte RE, Kuller LH, Drash AL. An epidemiologic approach to the study of retinopathy: the Pittsburgh diabetic morbidity and retinopathy studies. Diabetes Research and Clinical Practice. 1988;4(2):99-109. [pmid: 3342736].
Kinsella JB, Rassekh CH, Wassmuth ZD, Hokanson JA, Calhoun KH. Smoking increases facial skin flap complications. Annals of Otology, Rhinology and Laryngology. 1999;108(2):139-42.
Kiyosawa H, Suko M, Okudaira H, Murata K, Miyamoto T, Chung M-H, Kasai H, Nishimura S. Cigarette smoking induces formation of 8-hydroxydeoxyguanosine, one of the oxidative DNA damages in human peripheral leukocytes. Free Radical Research Communications. 1990;11(1–3):23-7. [pmid: 2074046].
Kleerekoper M, Peterson E, Nelson D, Tilley B, Phillips E, Schork MA, Kuder J. Identification of women at risk for developing postmenopausal osteoporosis with vertebral fractures: role of history and single photon absorptiometry. Bone and Mineral. 1989;7(2):171-86. [pmid: 2804452].
Klein BE, Klein R, Moss SE. Prevalence of cataracts in a population-based study of persons with diabetes mellitus. Ophthalmology. 1985;92(9):1191-6. [pmid: 4058882].
Klein BE, Klein R, Ritter LL. Relationship of drinking alcohol and smoking to prevalence of open-angle glaucoma: the Beaver Dam Eye Study. Ophthalmology. 1993a;100(11):1609-13. [pmid: 8233383].
Klein BEK, Klein R, Linton KLP, Franke T. Cigarette smoking and lens opacities: the Beaver Dam Eye Study. American Journal of Preventive Medicine. 1993b;9(1):27-30. [pmid: 8439434].
Klein H, Palmer CE, Knutson JW. Studies on dental caries. I: dental status and dental needs of elementary school children. Public Health Reports. 1938;53:751-65.
Klein R, Klein BE, Jensen SC, Meuer SM. The five-year incidence and progression of age-related maculopathy: the Beaver Dam Eye Study. Ophthalmology. 1997;104(1):7-21. [pmid: 9022098].
Klein R, Klein BE, Linton KL. Prevalence of age-related maculopathy: the Beaver Dam Eye Study. Ophthalmology. 1992;99(6):933-43. [pmid: 1630784].
Klein R, Klein BE, Moss SE. Relation of smoking to the incidence of age-related maculopathy: the Beaver Dam Eye Study. American Journal of Epidemiology. 1998;147(2):103-10. [pmid: 9456998].
Klein R, Klein BEK, Davis MD. Is cigarette smoking associated with diabetic retinopathy?. American Journal of Epidemiology. 1983;118(2):228-38. [pmid: 6881128].
Klein R, Klein BEK, Linton KLP, DeMets DL. The Beaver Dam Eye Study: the relation of age-related maculopathy to smoking. American Journal of Epidemiology. 1993c;137(2):190-200. [pmid: 8452123].
Klein R, Klein BEK, Moss SE, Cruickshanks KJ. The Wisconsin Epidemiologic Study of Diabetic Retinopathy XV: the long-term incidence of macular edema. Ophthalmology. 1995;102(1):7-16. [pmid: 7831044].
Kleinman KP, Feldman HA, Johannes CB, Derby CA, McKinlay JB. A new surrogate variable for erectile dysfunction status in the Massachusetts male aging study. Journal of Clinical Epidemiology. 2000;53(1):71-8. [pmid: 10693906].
Knoke JD, Hunninghake DB, Heiss G. Physiological markers of smoking and their relation to coronary heart disease: the Lipid Research Clinics Coronary Primary Prevention Trial. Atherosclerosis. 1987;7(5):477-82.
Komulainen M, Kröger H, Tuppurainen MT, Heik-kinen A-M, Honkanen R, Saarikoski S. Identification of early postmenopausal women with no bone response to HRT: results of a five-year clinical trial. Osteoporosis International. 2000;11(3):211-8. [pmid: 10824236].
Kornman KS, di Giovine FS. Genetic variations in cytokine expression: a risk factor for severity of adult periodontitis. Annals of Periodontology. 1998;3(1):327-38. [pmid: 9722717].
Kosunen TU, Aromaa A, Knekt P, Salomaa A, Rautelin H, Lohi P, Heinonen OP. Helicobacter antibodies in 1973 and 1994 in the adult population of Vammala, Finland. Epidemiology and Infection. 1997;119(1):29-34. [pmid: 9287940].
Kotani N, Hashimoto H, Sessler DI, Yoshida H, Kimura N, Okawa H, Muraoka M, Matsuki A. Smoking decreases alveolar macrophage function during anesthesia and surgery. Anesthesiology. 2000;92(5):1268-77. [pmid: 10781271].
Krall EA, Dawson-Hughes B. Smoking and bone loss among postmenopausal women. Journal of Bone and Mineral Research. 1991;6(4):331-8. [pmid: 1858519].
Krall EA, Dawson-Hughes B. Smoking increases bone loss and decreases intestinal calcium absorption. Journal of Bone and Mineral Research. 1999;14(2):215-20. [pmid: 9933475].
Kreiger N, Gross A, Hunter G. Dietary factors and fracture in postmenopausal women: a case-control study. International Journal of Epidemiology. 1992;21(5):953-8. [pmid: 1468859].
Kreiger N, Kelsey JL, Holford TR, O’Connor T. An epidemiologic study of hip fracture in postmenopausal women. American Journal of Epidemiology. 1982;116(1):141-8. [pmid: 7102649].
Kreutzfeldt J, Haim M, Bach E. Hip fracture among the elderly in a mixed urban and rural population. Age and Ageing. 1984;13(2):111-9. [pmid: 6610293].
Kristein MM. How much can business expect to profit from smoking cessation?. Preventive Medicine. 1983;12(2):358-81. [pmid: 6410369].
Kroger H, Kotaniemi A, Vainio P, Alhava E. Bone den-sitometry of the spine and femur in children by dual-energy x-ray absorptiometry. Bone and Mineral. 1992;17(1):75-85. [See also erratum in Bone and Mineral 1992;17(3):429.]. [pmid: 1581707].
Kroll SS, Schusterman MA, Reece GP, Miller MJ, Evans GR, Robb GL, Baldwin B. Choice of flap and incidence of free flap success. Plastic Reconstruction and Surgery. 1996;98(3):459-63.
Kuipers EJ, Thijs JC, Festen HPM. The prevalence of Helicobacter pylori in peptic ulcer disease. Alimentary Pharmacology and Therapeutics. 1995;9(Suppl 2):59-69. [pmid: 8547530].
Kurata JH, Elashoff JD, Nogawa AN, Haile BM. Sex and smoking differences in duodenal mortality. American Journal of Public Health. 1986;76(6):700-2. [pmid: 3706601].
La Vecchia C, Negri E, Levi F, Baron JA. Cigarette smoking, body mass and other risk factors for fractures of the hip in women. International Journal of Epidemiology. 1991;20(3):671-7. [pmid: 1955251].
Labenz J, Börsch G. Evidence for the essential role of Helicobacter pylori in gastric ulcer disease. Gut. 1994;35(1):19-22. [pmid: 8307443].
Labenz J, Leverkus F, Börsch G. Omeprazole plus amoxicillin for cure of Helicobacter pylori infection: factors influencing the treatment success. Scandinavian Journal of Gastroenterology. 1994;29(12):1070-5. [pmid: 7886394].
Labenz K, Peitz U, Köhl H, Kaiser J, Malfertheiner P, Hackelsberger A, Börsch G. Helicobacter pylori increases the risk of peptic ulcer bleeding: a case-control study. Italian Journal of Gastroenterology and Hepatology. 1999;31(2):110-5. [pmid: 10363194].
Lagorio S, Tagesson C, Forastiere F, Iavarone I, Axelson O, Carere A. Exposure to benzene and urinary concentrations of 8-hydroxydeoxyguanosine, a biological marker of oxidative damage to DNA. Occupational and Environmental Medicine. 1994;51(11):739-43. [pmid: 7849850].
Lam SK. Treatment of duodenal ulcer with sucralfate. Scandinavian Journal of Gastroenterology. 1991;26(Suppl 185):22-8.
Lam SK. Why do ulcers heal with sucralfate?. Scandinavian Journal of Gastroenterology. 1990;25(Suppl 173):6-16.
Lambert JR. Clinical indications and efficacy of colloidal bismuth subcitrate. Scandinavian Journal of Gastroenterology. 1991;26(Suppl 185):13-21.
Lanas A, Serrano P, Bajador E, Esteva F, Benito R, Sáinz R. Evidence of aspirin use in both upper and lower gastrointestinal perforation. Gastroenterology. 1997;112(3):683-9. [pmid: 9041228].
Lau E, Donnan S, Barker DJP, Cooper C. Physical activity and calcium intake in fracture of the proximal femur in Hong Kong. British Medical Journal. 1988;297(6661):1441-3. [pmid: 3147007].
Lau EMC, Chan YH, Chan M, Woo J, Griffith J, Chan HHL, Leung PC. Vertebral deformity in Chinese men: prevalence, risk factors, bone mineral density, and body composition measurements. Calcified Tissue International. 2000;66(1):47-52. [pmid: 10602844].
Laumann EO, Paik A, Rosen RC. Sexual dysfunction in the United States: prevalence and predictors. Journal of the American Medical Association. 1999;281(6):537-44. [pmid: 10022110].
Lavernia CJ, Sierra RJ, Gomez-Marin O. Smoking and joint replacement: resource consumption and short-term outcome. Clinical Orthopaedics. 1999;367:172-80.
Lavstedt S, Modéer T, Welander E. Plaque and gingivitis in a group of Swedish schoolchildren with special reference to toothbrushing habits. Acta Odontologica Scandinavica. 1982;40(5):307-11. [pmid: 6960630].
Law MR, Cheng R, Hackshaw AK, Allaway S, Hale AK. Cigarette smoking, sex hormones and bone density in women. European Journal of Epidemiology. 1997;13(5):553-8. [pmid: 9258568].
Law MR, Hackshaw AK. A meta-analysis of cigarette smoking, bone mineral density and risk of hip fracture: recognition of a major effect. British Medical Journal. 1997;315(7112):841-6. [pmid: 9353503].
Leanderson P, Tagesson C. Cigarette smoke-induced DNA-damage: role of hydroquinone and catechol in the formation of oxidative DNA-adduct, 8-hydroxydeoxyguanosine. Chemico-Biological Interactions. 1990;75(1):71-81. [pmid: 2114224].
Leanderson P, Tagesson C. Cigarette smoke-induced DNA damage in cultured human lung cells: role of hydroxyl radicals and endonuclease activation. Chemico-Biological Interactions. 1992;81(1–2):197-208. [pmid: 1309685].
Lee BM, Lee SK, Kim HS. Inhibition of oxidative DNA damage, 8-OHdG, and carbonyl contents in smokers treated with antioxidants (vitamin E, vitamin C, ß-carotene and red ginseng). Cancer Letters. 1998;132(1–2):219-27. [pmid: 10397477].
Leigh JP. Sex differences in absenteeism. Industrial Relations. 1983;22(3):349-61.
Leigh JP, Fries JF. Health habits, health care use and costs in a sample of retirees. Inquiry. 1992;29(1):44-54. [pmid: 1559723].
Leijon M, Mikaelsson B. Repeated short-term sick-leave as a possible symptom of psycho-social problems. Scandinavian Journal of Social Medicine. 1984;12(4):165-9. [pmid: 6523087].
Leske MC, Chylack LT Jr, He Q, Wu S-Y, Schoenfeld E, Friend J, Wolfe J. the LSC Group. Risk factors for nuclear opalescence in a longitudinal study. American Journal of Epidemiology. 1998;147(1):36-41. [pmid: 9440396].
Leske MC, Chylack LT Jr, Wu S-Y. the Lens Opacities Case-Control Study Group. The Lens Opacities Case-Control Study: risk factors for cataract. Archives of Ophthalmology. 1991;109(2):244-51. [pmid: 1993036].
Leske MC, Connell AMS, Wu S-Y, Hyman LG, Schachat AP. the Barbados Eye Study Group. Risk factors for open-angle glaucoma: the Barbados Eye Study. Archives of Ophthalmology. 1995;113(7):918-24. [pmid: 7605285].
Levine L, Gerber G. Acute vasospasm of penile arteries in response to cigarette smoking [letter]. Urology. 1990;36(1):99-100. [pmid: 2368241].
Levy SM, Heckert DA, Beck JD, Kohout FJ. Multivariate correlates of periodontally healthy teeth in an elderly population. Gerodontics. 1987;3(2):85-8. [pmid: 3472986].
Lie MA, van der Weijden GA, Timmerman MF, Loos BG, van Steenbergen TJM, van der Velden U. Oral microbiota in smokers and non-smokers in natural and experimentally-induced gingivitis. Journal of Clinical Periodontology. 1998;25(8):677-86. [pmid: 9722273].
Liede KE, Haukka JK, Hietanen JHP, Mattila MH, Rönka H, Sorsa T. The association between smoking cessation and periodontal status and salivary proteinase levels. Journal of Periodontology. 1999;70(11):1361-8. [pmid: 10588500].
Lilienfeld AM. Emotional and other selected characteristics of cigarette smokers and nonsmokers as related to epidemiological studies of lung cancer and other diseases. Journal of the National Cancer Institute. 1959;22(2):259-82. [pmid: 13631493].
Lin SK, Lambert JR, Nicholson L, Lukito W, Wahlqvist M. Prevalence of Helicobacter pylori in a representative Anglo-Celtic population of urban Melbourne. Journal of Gastroenterology and Hepatology. 1998;13(5):505-10. [pmid: 9641649].
Linden GJ, Mullally BH. Cigarette smoking and periodontal destruction in young adults. Journal of Periodontology. 1994;65(7):718-23. [pmid: 7608851].
Lindenthal JK, Myers JK, Pepper M. Smoking, psychological status and stress. Social Science and Medicine. 1972;6(5):583-91.
Lindquist LW, Carlsson GE, Jemt T. Association between marginal bone loss around osseointegrated mandibular implants and smoking habits: a 10-year follow-up study. Journal of Dental Research. 1997;76(10):1667-74. [pmid: 9326899].
Locker D. Smoking and oral health in older adults. Canadian Journal of Public Health. 1992;83(6):429-32.
Locker D. Incidence of root caries in an older Canadian population. Community Dentistry and Oral Epidemiology. 1996;24(6):403-7. [pmid: 9007358].
Locker D, Leake JL. Risk indicators and risk markers for periodontal disease experience in older adults living independently in Ontario, Canada. Journal of Dental Research. 1993;72(1):9-17. [pmid: 8418114].
Lodovici M, Casalini C, Cariaggi R, Michelucci L, Dolara P. Levels of 8-hydroxydeoxyguanosine as a marker of DNA in human damage in human leu-kocytes. Free Radical Biology and Medicine. 2000;28(1):13-7. [pmid: 10656286].
Loft S, Vistisen K, Ewertz M, Tjønneland A, Overvad K, Poulsen HE. Oxidative DNA damage estimated by 8-hydroxydeoxyguanosine excretion in humans: influence of smoking, gender and body mass index. Carcinogenesis. 1992;13(12):2241-7. [pmid: 1473230].
Lötborn M, Bratteby L-E, Samuelson G, Ljunghall S, Sjöström L. Whole-body bone mineral measurements in 15-year-old Swedish adolescents. Osteoporosis International. 1999;9(2):106-14. [pmid: 10367036].
Low I, Mitchell C. Absence and labour turnover in a foundry attributable to respiratory disease. Journal of Social and Occupational Medicine. 1991;41(4):185-7.
Lowe CR. Smoking habits related to injury and absenteeism in industry. British Journal of Preventive and Social Medicine. 1960;14:57-63. [pmid: 14418527].
Lu PW, Cowell CT, Lloyd-Jones SA, Briody JN, Howman-Giles R. Volumetric bone mineral density in normal subjects, aged 5–27 years. Journal of Clinical Endocrinology and Metabolism. 1996;81(4):1586-90. [pmid: 8636372].
Ludwick W, Massler M. Relation of dental caries experience and gingivitis to cigarette smoking in males 17 to 21 years old (at the Great Lakes Naval Training Center). Journal of Dental Research. 1952;31(3):319-22. [pmid: 14938483].
Lue TF, Tanagho EA. Physiology of erection and pharmacologic management of impotence. Journal of Urology. 1987;137(5):829-36. [pmid: 3553617].
Lykkesfeldt J, Loft S, Nielsen JB, Poulsen HE. Ascorbic acid and dehydroascorbic acid as biomarkers of oxidative stress caused by smoking. American Journal of Clinical Nutrition. 1997;65(4):959-63. [pmid: 9094879].
Lyons RA, Lo SV, Littlepage NC. Perception of health amongst ever-smokers and never-smokers: a comparison using the SF-36 Health Survey Questionnaire. Tobacco Control. 1994;3(3):213-5.
MacFarlane GD, Herzberg MC, Wolff LF, Hardie NA. Refractory periodontitis associated with abnormal polymorphonuclear leukocyte phagocytosis and cigarette smoking. Journal of Periodontology. 1992;63(11):908-13. [pmid: 1333526].
Macgregor IDM. Effects of smoking on oral ecology: a review of the literature. Clinical Preventive Dentistry. 1989;11(1):3-7. [pmid: 2689047].
Macgregor ID, Rugg-Gunn AJ. Toothbrushing sequence in smokers and nonsmokers. Clinical Preventive Dentistry. 1986;8(2):17-20. [pmid: 3486082].
Macgregor IDM, Edgar WM, Greenwood AR. Effects of cigarette smoking on the rate of plaque formation. Journal of Clinical Periodontology. 1985;12(1):35-41. [pmid: 3855869].
Machtei EE, Dunford R, Hausmann E, Grossi SG, Powell J, Cummins D, Zambon JJ, Genco RJ. Longitudinal study of prognostic factors in established periodontitis patients. Journal of Clinical Periodontology. 1997;24(2):102-9. [pmid: 9062856].
Machtei EE, Hausmann E, Dunford R, Grossi S, Ho A, Davis G, Chandler J, Zambon JJ, Genco RJ. Longitudinal study of predictive factors for periodontal disease and tooth loss. Journal of Clinical Periodontology. 1999;26(6):374-80. [pmid: 10382577].
Machtei EE, Hausmann E, Schmidt M, Grossi SG, Dunford R, Schifferle R, Munoz K, Davies G, Chandler J, Genco RJ. Radiographic and clinical responses to periodontal therapy. Journal of Periodontology. 1998;69(5):590-5. [pmid: 9623903].
Machuca G, Rosales I, Lacalle JR, Machuca C, Bullón P. Effect of cigarette smoking on periodontal status of healthy young adults. Journal of Periodontology. 2000;71(1):73-8. [pmid: 10695941].
Macnee CL. Perceived well-being of persons quitting smoking. Nursing Research. 1991;40(4):200-3. [pmid: 1857644].
Macular Photocoagulation Study Group. Recurrent choroidal neovascularization after argon laser photocoagulation for neovascular maculopathy. Archives of Ophthalmology. 1986;104(4):503-12. [pmid: 2420315].
Macular Photocoagulation Study Group. Risk factors for choroidal neovascularization in the second eye of patients with juxtafoveal or subfoveal choroidal neovascularization secondary to age-related macular degeneration. Archives of Ophthalmology. 1997;115(6):741-7. [pmid: 9194725].
Malaty HM, Evans DG, Evans DJ Jr, Graham DY. Helicobacter pylori in Hispanics: comparison with blacks and whites of similar age and socioeconomic class. Gastroenterology. 1992;103(3):813-6. [pmid: 1499931].
Mallmin H, Ljunghall S, Persson I, Bergström R. Risk factors for fractures of the distal forearm: a population-based case-control study. Osteoporosis International. 1994;4(6):298-304. [pmid: 7696821].
Maltzman BA, Mulvihill MN, Greenbaum A. Senile macular degeneration and risk factors: a case-control study. Annals of Ophthalmology. 1979;11(8):1197-201. [pmid: 556147].
Manderbacka K, Lunberg O, Martikainen P. Do risk factors and health behaviours contribute to self-ratings of health. Social Science and Medicine. 1999;48(12):1713-20. [pmid: 10405010].
Manning MR, Osland JS, Osland A. Work-related consequences of smoking cessation. Academy of Management Journal. 1989;32(3):606-21.
Mannino DM, Klevens RM, Flanders WD. Cigarette smoking: an independent risk factor for impotence?. American Journal of Epidemiology. 1994;140(11):1003-8. [pmid: 7985647].
Marangon K, Herbeth B, Lecomte E, Paul-Dauphin A, Grolier P, Chancerelle Y, Artur Y, Siest G. Diet, antioxidant status, and smoking habits in French men. American Journal of Clinical Nutrition. 1998;67(2):231-9. [pmid: 9459370].
Markkanen H, Paunio I, Tuominen R, Rajala M. Smoking and periodontal disease in the Finnish population aged 30 years and over. Journal of Dental Research. 1985;64(6):932-5. [pmid: 3858319].
Marmot MG, North F, Feeney A, Head J. Alcohol consumption and sickness absence: from the Whitehall II study. Addiction. 1993;88(3):369-82. [pmid: 8461854].
Marsden ME, Bray RM, Herbold JR. Substance use and health among U.S. military personnel: findings from the 1985 Worldwide Survey. Preventive Medicine. 1988;17(3):366-76. [pmid: 3405991].
Marshall BJ, Warren JR. Unidentified curved bacilli in the stomach of patients with gastritis and peptic ulceration. Lancet. 1984;1(8390):1311-5. [pmid: 6145023].
Marshall D, Johnell O, Wedel H. Meta-analysis of how well measures of bone mineral density predict occurrence of osteoporotic fractures. British Medical Journal. 1996;312(7041):1254-9. [pmid: 8634613].
Marshall G, Garg SK, Jackson WE, Holmes DL, Chase HP. Factors influencing the onset and progression of diabetic retinopathy in subjects with insulin-dependent diabetes mellitus. Ophthalmology. 1993;100(8):1133-9. [pmid: 8341492].
Martin DF, Montgomery E, Dobek AS, Patrissi GA, Peura DA. Campylobacter pylori, NSAIDS, and smoking: risk factors for peptic ulcer disease. American Journal of Gastroenterology. 1989;84(10):1268-72. [pmid: 2801677].
Martin-Morales A, Sanchez-Cruz JJ, Saenz de Tejada I, Rodriguez-Vela L, Jimenez-Cruz JF, Burgos-Rodriguez R. Prevalence and independent risk factors for erectile dysfunction in Spain: results of the Epidemiologia de la Disfuncion Erectil Masculina Study. Journal of Urology. 2001;166(2):569-75. [pmid: 11458070].
Martinez-Canut P, Lorca A, Magán R. Smoking and periodontal disease severity. Journal of Clinical Periodontology. 1995;22(10):743-9. [pmid: 8682920].
Matarazzo JD, Saslow G. Psychological and related characteristics of smokers and nonsmokers. Psychological Bulletin. 1960;57(6):493-513. [pmid: 13768035].
Mazess RB. On aging bone loss. Clinical Orthopaedics and Related Research. 1982;165:239-52. [pmid: 7075066].
Mazess RB, Barden HS. Bone density in premenopausal women: effects of age, dietary intake, physical activity, smoking, and birth-control pills. American Journal of Clinical Nutrition. 1991;53(1):132-42. [pmid: 1984338].
McClean HE, Dodds PM, Abernethy MH, Stewart AW, Beaven DW. Vitamin C concentration in plasma and leucocytes of men related to age and smoking habit. New Zealand Medical Journal. 1976;83(561):226-9. [pmid: 1066535].
McCulloch RG, Bailey DA, Houston CS, Dodd BL. Effects of physical activity, dietary calcium intake and selected lifestyle factors on bone density in young women. Canadian Medical Association Journal. 1990;142(3):221-7. [pmid: 2302613].
McDermott MT, Witte MC. Bone mineral content in smokers. Southern Medical Journal. 1988;81(4):477-80. [pmid: 3358172].
McGuire MK, Nunn ME. Prognosis versus actual outcome. II: the effectiveness of clinical parameters in developing an accurate prognosis. Journal of Periodontology. 1996;67(7):658-65. [pmid: 8832476].
Medina C, Vergara M, Casellas F, Lara F, Naval J, Malagelada JR. Influence of the smoking habit in the surgery of inflammatory bowel disease. Revista Espanola de Enfermedades Digestivas. 1998;90(11):771-8. [pmid: 9866409].
Melhus H, Michaëlsson K, Holmberg L, Wolk A, Ljunghall S. Smoking, antioxidant vitamins, and the risk of hip fracture. Journal of Bone and Mineral Research. 1999;14(1):129-35. [pmid: 9893075].
Mellstrom D, Rundgren A, Jagenburg R, Steen B, Svanborg A. Tobacco smoking, ageing and health among the elderly: a longitudinal population study of 70-year-old men and an age cohort comparison. Age and Ageing. 1982;11(1):45-58. [pmid: 7072560].
Melman A, Gingell JC. The epidemiology and patho-physiology of erectile dysfunction. Journal of Urology. 1999;161(1):5-11. [pmid: 10037356].
Melton LJ III, O’Fallon WM, Riggs BL. Secular trends in the incidence of hip fractures. Calcified Tissue International. 1987;41(2):57-64. [pmid: 3115545].
Melton LJ III, Riggs BL. Epidemiology of age-related fractures. Avioli LV, editor. The Osteoporotic Syndrome: Detection, Prevention, and Treatment. Orlando (FL). Grune & Stratton. 1987:1-30.
Mercelina-Roumans PE, Ubachs JM, van Wersch JW. Leucocyte count and leucocyte differential in smoking and non-smoking females during pregnancy. European Journal of Obstetrics and Gynecology and Reproductive Biology. 1994;55(3):169-73. [pmid: 7958160].
Merrill JC, Kleber HD, Shwartz M, Liu H, Lewis SR. Cigarettes, alcohol, marijuana, other risk behaviors, and American youth. Drug and Alcohol Dependence. 1999;56(3):205-12. [pmid: 10529022].
Mersdorf A, Goldsmith PC, Diederichs W, Padula CA, Lue TF, Fishman IJ, Tanagho EA. Ultrastructural changes in impotent penile tissue: a comparison of 65 patients. Journal of Urology. 1991;145(4):749-58. [pmid: 2005694].
Metcalfe RA, Weetman AP. Stimulation of extraocular muscle fibroblasts by cytokines and hypoxia: possible role in thyroid-associated ophthalmopathy. Clinical Endocrinology. 1994;40(1):67-72. [pmid: 8306483].
Meyer HE, Tverdal A, Falch JA. Risk factors for hip fracture in middle-aged Norwegian women and men. American Journal of Epidemiology. 1993;137(11):1203-11. [pmid: 8322761].
Michaelsson K, Holmberg L, Mallmin H, Sorensen S, Wolk A, Bergstrom R, Ljunghall S. Diet and hip fracture risk: a case-control study. Study Group of the Multiple Risk Survey on Swedish Women for Eating Assessment. International Journal of Epidemiology. 1995;24(4):771-82. [pmid: 8550275].
Michnovicz JJ, Hershcopf RJ, Naganuma H, Bradlow HL, Fishman J. Increased 2-hydroxylation of estradiol as a possible mechanism for the anti-estrogenic effect of cigarette smoking. New England Journal of Medicine. 1986;315(21):1305-9. [pmid: 3773953].
Miller CW. Survival and ambulation following hip fracture. Journal of Bone and Joint Surgery. 1978;60(7):930-4. [pmid: 701341].
Miller ER 3rd, Apper LJ, Jiang L, Risby TH. Association between cigarette smoking and lipid peroxidation in a controlled feeding study. Circulation. 1997;96(4):1097-101. [pmid: 9286935].
Miller VP, Ernst C, Collin F. Smoking-attributable medical care costs in the USA. Social Science and Medicine. 1999;48(3):375-91. [pmid: 10077285].
Moayyedi P, Chalmers DM, Axon ATR. Patient factors that predict failure of omeprazole, clarithromycin, and tinidazole to eradicate Helicobacter pylori. Journal of Gastroenterology. 1997;32(1):24-7. [pmid: 9058291].
Modéer T, Lavstedt S, Åhlund C. Relation between tobacco consumption and oral health in Swedish schoolchildren. Acta Odontologica Scandinavica. 1980;38(4):223-7. [pmid: 6937088].
Mohan M, Sperduto RD, Angra SK, Milton RC, Mathur RL, Underwood BA, Jaffery N, Pandya CB, Chhabra VK, Vajpayee RB, Kalra VK, Sharma YR. India-US case-control study of age-related cataracts: the India-US Case-Control Study Group. Archives of Ophthalmology. 1989;107(5):670-6. [pmid: 2818712].
Morgado PB, Chen HC, Patel V, Herbert L, Kohner EM. The acute effect of smoking on retinal blood flow in subjects with and without diabetes. Ophthalmology. 1994;101(7):1220-6. [pmid: 8035985].
Morgan RW, Drance SM. Chronic open-angle glaucoma and ocular hypertension: an epidemiological study. British Journal of Ophthalmology. 1975;59(4):211-5. [pmid: 1138846].
Morrow JD, Frei B, Longmire AW, Gaziano JM, Lynch SM, Shyr Y, Strauss WE, Oates JA, Roberts LJ II. Increase in circulating products of lipid peroxidation (F_2_-isoprostanes) in smokers: smoking as a cause of oxidative damage. New England Journal of Medicine. 1995;332(18):1198-203. [pmid: 7700313].
Morrow JD, Roberts LJ II. The isoprostanes: current knowledge and directions for future research. Biochemical Pharmacology. 1996;51(5):1-9. [pmid: 8534261].
Mosca L, Rubenfine M, Tarshis T, Tsai A, Pearson T. Clinical predictors of oxidized low-density lipopro-tein in patients with coronary artery disease. American Journal of Cardiology. 1997;80(1):825-30. [pmid: 9381992].
Moss SE, Klein R, Klein BEK. Association of cigarette smoking with diabetic retinopathy. Diabetes Care. 1991;14(2):119-26. [pmid: 2060413].
Moss SE, Klein R, Klein BEK. Cigarette smoking and ten-year progression of diabetic retinopathy. Ophthalmology. 1996;103(9):1438-42. [pmid: 8841303].
Motoyama T, Kawano H, Kugiyama K, Hirashima O, Ohgushi M, Yoshimora M, Ogawa H, Yasue H. Endothelium-dependent vasodilation in the brachial artery is impaired in smokers: effect of vitamin C. American Journal of Physiology. 1997;273(4 Pt 2):H1644-H1650. [pmid: 9362226].
Mousa SA, Lorelli W, Campochiaro PA. Role of hypoxia and extracellular matrix-integrin binding in the modulation of angiogenic growth factors secretion by retinal pigmented epithelial cells. Journal of Cellular Biochemistry. 1999;74(1):135-43. [pmid: 10381270].
Mühlhauser I, Bender R, Bott U, Jörgens V, Grüsser M, Wagener W, Overmann H, Berger M. Cigarette smoking and progression of retinopathy and ne-phropathy in type 1 diabetes. Diabetic Medicine. 1996;13(6):536-43. [pmid: 8799657].
Mühlhauser I, Sawicki P, Berger M. Cigarette-smoking as a risk factor for macroproteinuria and proliferative retinopathy in type 1 (insulin-dependent) diabetes. Diabetologia. 1986;29(8):500-2. [pmid: 3758532].
Mühlhauser I, Verhasselt R, Sawicki PT, Berger M. Leucocyte count, proteinuina and smoking in type 1 diabetes mellitus. Acta Diabetologica. 1993;30(2):105-7. [pmid: 8219257].
Mullally BH, Breen B, Linden GJ. Smoking and patterns of bone loss in early-onset periodontitis. Journal of Periodontology. 1999;70(4):394-401. [pmid: 10328651].
Mullally BH, Linden GJ. Molar furcation involvement associated with cigarette smoking in periodontal referrals. Journal of Clinical Periodontology. 1996;23(7):658-61. [pmid: 8841898].
Muñoz B, West SK, Rubin GS, Schein OD, Quigley HA, Bressler SB, Bandeen-Roche K. SEE Study Team. Causes of blindness and visual impairment in a population of older Americans: the Salisbury Eye Evaluation Study. Archives of Ophthalmology. 2000;118(6):819-25. [pmid: 10865321].
Murray JF. The Normal Lung: The Basis for Diagnosis and Treatment of Pulmonary Disease. Philadelphia. W.B. Saunders. 1986.
Murray LJ, McCrum EE, Evans AE, Bamford KB. Epidemiology of Helicobacter pylori infection among 4742 randomly selected subjects from Northern Ireland. International Journal of Epidemiology. 1997;26(4):880-7. [pmid: 9279623].
Mussolino ME, Looker AC, Madans JH, Langlois JA, Orwoll ES. Risk factors for hip fracture in white men: the NHANES I Epidemiologic Follow-up Study. Journal of Bone and Mineral Research. 1998;13(6):918-24. [pmid: 9626622].
Nagler R, Lischinsky S, Diamond E, Drigues N, Klein I, Reznick AZ. Effect of cigarette smoke on salivary proteins and enzyme activities. Archives of Biochemistry and Biophysics. 2000;379(2):229-36. [pmid: 10898939].
Nancy NR, Subramanian N, Rai UC. Effect of cigarette smoking on leucocytes in South Indians. Indian Journal of Physiology and Pharmacology. 1982;26(3):196-200. [pmid: 7174065].
National Advisory Eye Council. Vision Research—A National Plan: 1999–2003. Bethesda (MD). U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health, National Eye Institute. 1998. NIH Publication No 98–4120.
National Institutes of Health. Changes in Cigarette-Related Disease Risks and Their Implication for Prevention and Control. Shopland DR, Burns DM, Garfinkel L, Samet JM, editors. Smoking and Tobacco Control Monograph No 8. Bethesda (MD). US Department of Health and Human Services, Public Health Service, National Institutes of Health, National Cancer Institute. 1997. NIH Publication No. 97–4213.
Naus A, Engler V, Hetychova M, Vavreckova O. Work injuries and smoking. Industrial Medicine and Surgery. 1966;35(10):880-1. [pmid: 5225050].
Nelson HD, Nevitt MC, Scott JC, Stone KL, Cummings SR. Smoking, alcohol, and neuromuscular and physical function of older women: Study of Osteoporotic Fractures Research Group. Journal of the American Medical Association. 1994;272(23):1825-31. [pmid: 7990216].
Nettleman MD, Banitt L, Barry W, Awan I, Gordon EE. Predictors of survival and the role of gender in postoperative myocardial infarction. American Journal of Medicine. 1997;103(5):357-62. [pmid: 9375702].
Newbrun E. Indices to measure gingival bleeding. Journal of Periodontology. 1996;67(6):555-61. [pmid: 8794964].
Newcomb MD, Bentler PM. The impact of late adolescent substance use on young adult health status and utilization of health services: a structural-equation model over four years. Social Science and Medicine. 1987;24(1):71-82. [pmid: 3823999].
Newman MG, Kornman KS, Holtzman S. Association of clinical risk factors with treatment outcomes. Journal of Periodontology. 1994;65(5 Suppl):489-97. [pmid: 8046565].
Nguyen TV, Kelly PJ, Sambrook PN, Gilbert C, Pocock NA, Eisman JA. Lifestyle factors and bone density in the elderly: implications for osteoporosis prevention. Journal of Bone and Mineral Research. 1994;9(9):1339-46. [pmid: 7817817].
Niedhammer I, Bugel I, Goldberg M, Leclerc A, Guéguen A. Psychosocial factors at work and sickness absence in the Gazel cohort: a prospective study. Occupational and Environmental Medicine. 1998;55(11):735-41. [pmid: 9924449].
Nielsen H. A quantitative and qualitative study of blood monocytes in smokers. European Journal of Respiratory Diseases. 1985;66(5):327-32. [pmid: 3894043].
Nierenberg DW, Stukel TA, Baron JA, Dain BJ, Greenberg ER. Determinants of plasma levels of beta-carotene and retinol. American Journal of Epidemiology. 1989;130(3):511-21. [pmid: 2669470].
NIH Consensus Development. Panel on Helicobacter pylori in Peptic Ulcer Disease. Helicobacter pylori in peptic ulcer disease. Journal of the American Medical Association. 1994;272(1):65-9. [pmid: 8007082].
NIH Consensus Development Panel on Impotence. Impotence: Consensus Development Panel on Impotence. Journal of the American Medical Association. 1993;270(1):83-90. [pmid: 8510302].
Noble RC, Penny BB. Comparison of leukocyte count and function in smoking and nonsmoking young men. Infection and Immunity. 1975;12(3):550-5. [pmid: 1100522].
Norderyd O, Hugoson A. Risk of severe periodontal disease in a Swedish adult population: a cross-sectional study. Journal of Clinical Periodontology. 1998;25(12):1022-8. [pmid: 9869353].
Norderyd O, Hugoson A, Grusovin G. Risk of severe periodontal disease in a Swedish adult population: a longitudinal study. Journal of Clinical Periodontology. 1999;26(9):608-15. [pmid: 10487312].
North F, Syme SL, Feeney A, Head J, Shipley MJ, Marmot MG. Explaining socioeconomic differences in sickness absence: the Whitehall II Study. British Medical Journal. 1993;306(6874):361-6. [pmid: 8461681].
Oakes TW, Friedman GD, Seltzer CC, Siegelaub AB, Collen MF. Health service utilization by smokers and nonsmokers. Medical Care. 1974;12(11):958-66. [pmid: 4444367].
Obwegeser R, Oguogho A, Ulm M, Berghammer P, Sinzinger H. Maternal cigarette smoking increases F_2_-isoprostanes and reduces prostacyclin and nitric oxide in umbilical vessels. Prostaglandins and Other Lipid Mediators. 1999;57(4):269-79. [pmid: 10402220].
O’Connor HJ, Kanduru C, Bhutta AS, Meehan JM, Feeley KM, Cunnane K. Effect of Helicobacter pylori eradication on peptic ulcer healing. Postgraduate Medical Journal. 1995;71(832):90-3. [pmid: 7724441].
Okuno T. Smoking and blood changes [letter]. Journal of the American Medical Association. 1973;225(11):1387-8. [pmid: 4740667].
Olsen GW, Kusch GD, Stafford BA, Gudmundsen SL, Currier MF. The positive known association design: a quality assurance method for occupational health surveillance data. Journal of Occupational Medicine. 1991;33(9):998-1000. [pmid: 1744750].
O’Riordan T, Mathai E, Tobin E, McKenna D, Keane C, Sweeney E, O’Morain C. Adjuvant antibiotic therapy in duodenal ulcers treated with colloidal bismuth subcitrate. Gut. 1990;31(9):999-1002. [pmid: 2210469].
Orleans CT, Schoenbach VJ, Salmon MA, Strecher VJ, Kalsbeek W, Quade D, Brooks EF, Konrad TR, Blackmon C, Watts CD. A survey of smoking and quitting patterns among black Americans. American Journal of Public Health. 1989;79(2):176-81. [pmid: 2913836].
Ortego-Centeno N, Muñoz-Torres M, Hernández-Quero J, Jurado-Duce A, de la Higuera Torres-Puchol J. Bone mineral density, sex steroids, and mineral metabolism in premenopausal smokers. Calcified Tissue International. 1994;55(6):403-7. [pmid: 7895176].
Ortego-Centeno N, Muñoz-Torres M, Jódar E, Hernández-Quero J, Jurado-Duce A, de la Higuera Torres-Puchol J. Effect of tobacco consumption on bone mineral density in healthy young males. Calcified Tissue International. 1997;60(6):496-500. [pmid: 9164822].
Paetkau ME, Boyd TAS, Grace M, Bach-Mills J, Winship B. Senile disciform macular degeneration and smoking. Canadian Journal of Ophthalmology. 1978;13(2):67-71. [pmid: 647465].
Paetkau ME, Boyd TAS, Winship B, Grace M. Cigarette smoking and diabetic retinopathy. Diabetes. 1977;26(1):46-9. [pmid: 830564].
Paganini-Hill A, Chao A, Ross RK, Henderson BE. Exercise and other factors in the prevention of hip fracture: the Leisure World Study. Epidemiology. 1991;2(1):16-25. [pmid: 2021661].
Paganini-Hill A, Ross RK, Gerkins VR, Henderson BE, Arthur M, Mack TM. Menopausal estrogen therapy and hip fractures. Annals of Internal Medicine. 1981;95(1):28-31. [pmid: 7247123].
Palmer RM, Matthews JP, Wilson RF. Non-surgical periodontal treatment with and without adjunctive metronidazole in smokers and non-smokers. Journal of Clinical Periodontology. 1999;26(3):158-63. [pmid: 10100041].
Palmore E. Health practices and illness among the aged. Gerontologist. 1970;10(4):313-6. [pmid: 5490953].
Pampalon R, Duncan C, Subramanian SV, Jones K. Geographies of health perception in Quebec: a multilevel perspective. Social Science and Medicine. 1999;48(10):1483-90. [pmid: 10369447].
Pamuk ER, Byers T, Coates RJ, Vann JW, Sowell AL, Gunter EW, Glass D. Effect of smoking on serum nutrient concentrations in African-American women. American Journal of Clinical Nutrition. 1994;59(4):891-5. [pmid: 8147335].
Panda K, Chattopadhyay R, Chattopadhyay D, Chatterjee IB. Vitamin C prevents cigarette smoke-induced oxidative damage in vivo. Free Radical Biology and Medicine. 2000;29(2):115-24. [pmid: 10980400].
Panda K, Chattopadhyay R, Ghosh M, Chattopadhyay D, Chatterjee IB. Vitamin C prevents cigarette smoke induced oxidative damage of proteins and increased proteolysis. Free Radical Biology and Medicine. 1999;27(9/10):1064-79. [pmid: 10569639].
Papantonopoulos GH. Smoking influences decision making in periodontal therapy: a retrospective clinical study. Journal of Periodontology. 1999;70(10):1166-73. [pmid: 10534070].
Parazzini F, Fabris FM, Bortolotti A, Calabrò A, Chatenoud L, Colli E, Landoni M, Lavezzari M, Turchi P, Sessa A, Mirone V. Frequency and determinants of erectile dysfunction in Italy. European Urology. 2000;37(1):43-9. [pmid: 10671784].
Parkes KR. Smoking as a moderator of the relationship between affective state and absence from work. Journal of Applied Psychology. 1983;68(4):698-708. [pmid: 6643345].
Parulkar VG, Balsubramaniam P, Barua MJ, Bhatt JV. Smoking and differential leucocyte (w.b.c.) count. Journal of Postgraduate Medicine. 1975;21(2):75-7. [pmid: 1177170].
Parulkar VG, Barua MJ, Bhatt JV. Smoking and leucocyte counts. Journal of Postgraduate Medicine. 1973;19(3):132-5. [pmid: 4793629].
Parvinen T. Stimulated salivary flow rate, pH and lactobacillus and yeast concentrations in non-smokers and smokers. Scandinavian Journal of Dental Research. 1984;92(4):315-8. [pmid: 6591368].
Pearson DC, Grothaus LC, Thompson RS, Wagner EH. Smokers and drinkers in a health maintenance organization population: lifestyles and health status. Preventive Medicine. 1987;16(6):783-95. [pmid: 3432228].
Penner M, Penner S. Excess insured health care costs from tobacco-using employees in a large group plan. Journal of Occupational Medicine. 1990;32(6):521-3. [pmid: 2380801].
Pepelassi EA, Tsiklakis K, Diamanti-Kipioti A. Radiographic detection and assessment of the periodontal endosseous defects. Journal of Clinical Periodontology. 2000;27(4):224-30. [pmid: 10783834].
Pereira ED, Fernandes AL, da Silva Ancao M, de Arauja Pereres C, Atallah AN, Faresin SM. Prospective assessment of the risk of postoperative pulmonary complications in patients submitted to upper abdominal surgery. Sao Paulo Medical Journal. 1999;117(4):151-60. [pmid: 10559850].
Persson RE, Hollender LG, Persson GR. Assessment of alveolar bone levels from intraoral radiographs in subjects between ages 15 and 94 years seeking dental care. Journal of Clinical Periodontology. 1998;25(8):647-54. [See also comments inJournal of Clinical Periodontology 1999;26(4):264–6]. [pmid: 9722269].
Peters JM, Ferris BG Jr. Smoking and morbidity in a college-age group. American Review of Respiratory Disease. 1967;95(5):783-9. [pmid: 6023512].
Petitti DB, Kipp H. The leukocyte count: associations with intensity of smoking and persistence of effect after quitting. American Journal of Epidemiology. 1986;123(1):89-95. [pmid: 3940445].
Pfeilschifter J, Ziegler R. Smoking and endocrine ophthalmopathy: impact of smoking severity and current vs lifetime cigarette consumption. Clinical Endocrinology. 1996;45(4):477-81. [pmid: 8959089].
Pilz H, Oguogho A, Chehne F, Lupattelli G, Palumbo B, Sinzinger H. Quitting cigarette smoking results in a fast improvement of in vivo oxidation injury (determined via plasma, serum, and urinary isoprostane). Thrombosis Research. 2000;99(3):209-21. [pmid: 10944241].
Pines A, Skulkeo K, Pollak E, Peritz E, Steif J. Rates of sickness absenteeism among employees of a modern hospital: the role of demographic and occupational factors. British Journal of Industrial Medicine. 1985;42(5):326-35. [pmid: 3986143].
Pinsky JL, Leaverton PE, Stokes J III. Predictors of good function: the Framingham Study. Journal of Chronic Diseases. 1987;40(Suppl 1):159S-162S. [pmid: 2954993].
Poikolainen K, Vartiainen E. Determinants of gamma-glutamyltransferase: positive interaction with alcohol and body mass index, negative association with coffee. American Journal of Epidemiology. 1997;146(12):1019-24. [pmid: 9420526].
Poikolainen K, Vartiainen E, Korhonen H. Alcohol intake and subjective health. American Journal of Epidemiology. 1996;144(4):346-50. [pmid: 8712191].
Ponte F, Giuffré G, Giammanco R, Dardanoni G. Risk factors of ocular hypertension and glaucoma: the Casteldaccia Eye Study. Documenta Ophthalmologica. 1994;85(3):203-10. [pmid: 7924848].
Pope CR. Life-styles, health status and medical care utilization. Medical Care. 1982;20(4):402-13. [pmid: 7078296].
Post WK, Burdorf A, Bruggeling TG. Relations between respiratory symptoms and sickness among workers in the animal feed industry. Occupational and Environmental Medicine. 1994;51(7):440-6. [pmid: 8044241].
Practicò D, Barry OP, Lawson JA, Adiyaman M, Hwang S-W, Khanapure SP, Iuliano L, Rokach J, FitzGerald GA. IPF_2α-I_: an index of lipid peroxidation in humans. Proceedings of the National Academy of Sciences of the United States of America. 1998;95(7):3449-54. [pmid: 9520386].
Preber H, Bergström J. Occurrence of gingival bleeding in smoker and non-smoker patients. Acta Odontologica Scandinavica. 1985;43(5):315-20. [pmid: 3878653].
Preber H, Bergström J. Cigarette smoking in patients referred for periodontal treatment. Scandinavian Journal of Dental Research. 1986;94(2):102-8. [pmid: 3458283].
Preber H, Bergström J. Effect of cigarette smoking on periodontal healing following surgical therapy. Journal of Clinical Periodontology. 1990;17(5):324-8. [pmid: 2355098].
Preber H, Bergström J, Linder LE. Occurrence of periopathogens in smoker and non-smoker patients. Journal of Clinical Periodontology. 1992;19(9 Pt 1):667-71. [pmid: 1331203].
Preber H, Kant T. Effect of tobacco-smoking on periodontal tissue of 15-year-old schoolchildren. Journal of Periodontal Research. 1973;8(5):278-83. [pmid: 4269769].
Preber H, Kant T, Bergström J. Cigarette smoking, oral hygiene and periodontal health in Swedish army conscripts. Journal of Clinical Periodontology. 1980;7(2):106-13. [pmid: 6929791].
Preber H, Linder L, Bergström J. Periodontal healing and periopathogenic microflora in smokers and non-smokers. Journal of Clinical Periodontology. 1995;22(12):946-52. [pmid: 8613564].
Prevent Blindness America. Vision Problems in the U.S.: Prevalence of Adult Vision Impairment and Age-Related Eye Disease in America. http://www.preventblindness.org/resources/vision_data.html. accessed: October 28, 2002.
Prokopczyk B, Cox J, Hoffman D, Waggoner SE. Identification of tobacco-specific carcinogen in the cervical mucus of smokers and nonsmokers. Journal of the National Cancer Institute. 1997;89(12):868-73. [pmid: 9196253].
Pronk NP, Goodman MJ, O’Connor PJ, Martinson BC. Relationship between modifiable health risks and short-term health care charges. Journal of the American Medical Association. 1999;282(23):2235-9. [pmid: 10605975].
Prummel MF, Wiersinga WM. Smoking and risk of Graves’ disease. Journal of the American Medical Association. 1993;269(4):479-82. [pmid: 8419666].
Quigley HA, Enger C, Katz J, Sommer A, Scott R, Gilbert D. Risk factors for the development of glauco-matous visual field loss in ocular hypertension. Archives of Ophthalmology. 1994;112(5):644-9. [pmid: 8185522].
Quinn SM, Zhang JB, Gunsolley JC, Schenkein HA, Tew JG. The influence of smoking and race on adult periodontitis and serum IgG2 levels. Journal of Periodontology. 1998;69(2):171-7. [pmid: 9526916].
Raichlen JS, Healy B, Achuff SC, Pearson TA. Importance of risk factors in the angiographic progression of coronary artery disease. American Journal of Cardiology. 1986;57(1):66-70. [pmid: 3942078].
Ramakrishnan S, Sulochana KN, Selvaraj T, Abdul Rahim A, Lakshmi M, Arunagiri K. Smoking of beedies and cataract: cadmium and vitamin C in the lens and blood. British Journal of Ophthalmology. 1995;79(3):202-6. [pmid: 7703194].
Rand LI, Krolewski AS, Aiello LM, Warram JH, Baker RS, Maki T. Multiple factors in the prediction of risk of proliferative diabetic retinopathy. New England Journal of Medicine. 1985;313(23):1433-8. [pmid: 3864010].
Raulin LA, McPherson JC III, McQuade MJ, Hanson BS. The effect of nicotine on the attachment of human fibroblasts to glass and human root surfaces in vitro. Journal of Periodontology. 1988;59(5):318-25. [pmid: 3164382].
Rauws E, Tytgat G. Helicobacter pylori in duodenal and gastric ulcer disease. Baillière’s Clinical Gastroenterology. 1995;9(3):529-47.
Ravald N, Birkhed D, Hamp S-E. Root caries susceptibility in periodontally treated patients: results after 12 years. Journal of Clinical Periodontology. 1993;20(2):124-9. [pmid: 8436631].
Ray NF, Chan JK, Thamer M, Melton LJ III. Medical expenditures for the treatment of osteoporotic fractures in the United States in 1995: report from the National Osteoporosis Foundation. Journal of Bone and Mineral Research. 1997;12(1):24-35. [pmid: 9240722].
Recker RR, Davies KM, Hinders SM, Heaney RP, Stegman MR, Kimmel DB. Bone gain in young adult women. Journal of the American Medical Association. 1992;268(17):2403-8. [pmid: 1404797].
Reed WL. Physical health status as a consequence of health practices. Journal of Community Health. 1983;89(4):217-28. [pmid: 6643707].
Reed DM, Foley DJ, White LR, Heimovitz H, Burchfiel CM, Masaki K. Predictors of healthy aging in men with high life expectancies. American Journal of Public Health. 1998;88(10):1463-8. [pmid: 9772845].
Reilly M, Delanty N, Lawson JA, FitzGerald GA. Modulation of oxidant stress in vivo in chronic cigarette smokers. Circulation. 1996;94(1):19-25. [pmid: 8964113].
Renvert S, Dahlén G, Wikström M. The clinical and microbiological effects of non-surgical periodontal therapy in smokers and non-smokers. Journal of Clinical Periodontology. 1998;25(2):153-7. [pmid: 9495614].
Repine JE, Bast A, Lankhorst I. Oxidative stress in chronic obstructive pulmonary disease: Oxidative Stress Study Group. American Journal of Respiratory and Critical Care Medicine. 1997;156(2 Pt 1):341-57. [pmid: 9279209].
Reynolds KL, Heckel HA, Witt CE, Martin JW, Pollard JA, Knapik JJ, Jones BH. Cigarette smoking, physical fitness, and injuries in infantry soldiers. American Journal of Preventive Medicine. 1994;10(3):145-50. [pmid: 7917440].
Reznick AZ, Cross CE, Hu M-L, Suzuki YJ, Khwaja S, Safadi A, Motchnik PA, Packer L, Halliwell B. Modification of plasma proteins by cigarette smoke as measured by protein carbonyl formation. Biochemistry Journal. 1992;286(Pt 2):607-11.
Rice DP, Hodgson TA, Sinsheimer P, Browner W, Kopstein A. The economic costs of the health effects of smoking, 1984. The Milbank Quarterly. 1986;64(4):489-547. [pmid: 3102916].
Riebel GD, Boden SD, Whitesides TE, Hutton WC. The effect of nicotine on incorporation of cancellous bone graft in an animal model. Spine. 1995;20(20):2198-202. [pmid: 8545712].
Rimer BK, Orleans CT, Keintz MK, Cristinzio S, Fleisher L. The older smoker: status, challenges and opportunities for intervention. Chest. 1990;97(3):547-53. [pmid: 2306958].
Rimm EB, Giovannucci EL, Willett WC, Colditz GA, Ascherio A, Rosner B, Stampfer MJ. Prospective study of alcohol consumption and risk of coronary disease in men. Lancet. 1991;338(8765):464-8. [pmid: 1678444].
Rockman CB, Cappadona C, Riles TS, Lamparello PJ, Giangola G, Adelman MA, Landis R. Causes of the increased stroke rate after carotid endarterectomy in patients with previous strokes. Annals of Vascular Surgery. 1997;11(1):28-34. [pmid: 9061136].
Rosen MP, Greenfield AJ, Walker TG, Grant P, Dubrow J, Bettmann MA, Fried LE, Goldstein I. Cigarette smoking: an independent risk factor for atherosclerosis in the hypogastric-cavernous arterial bed of men with arteriogenic impotence. Journal of Urology. 1991;145(4):759-63. [pmid: 2005695].
Rosenberg ES, Cutler SA. The effect of cigarette smoking on the long-term success of guided tissue regeneration: a preliminary study. Annals of the Royal Australasian College of Dental Surgeons. 1994;12:89-93. [pmid: 7993065].
Ross MA, Crosley LK, Brown KM, Duthie SJ, Collins AC, Arthur JR, Duthie GG. Plasma concentrations of carotenoids and antioxidant vitamins in Scottish males: influences of smoking. European Journal of Clinical Nutrition. 1995;49(11):861-5. [pmid: 8557024].
Rundgren A, Mellström D. The effect of tobacco smoking on the bone mineral content of the ageing skeleton. Mechanisms of Ageing and Development. 1984;28(2–3):273-7. [pmid: 6521507].
Ryan J, Zwerling C, Jones M. Cigarette smoking at hire as a predictor of employment outcome. Journal of Occupational and Environmental Medicine. 1996;38(9):928-33. [pmid: 8877844].
Ryan J, Zwerling C, Orav EJ. Occupational risks associated with cigarette smoking: a prospective study. American Journal of Public Health. 1992;82(1):29-32. [pmid: 1536330].
Ryder MI, Fujitaki R, Johnson G, Hyun W. Alterations of neutrophil oxidative burst by in vitro smoke exposure: implications for oral and systemic diseases. Annals of Periodontology. 1998;3(1):76-87. [pmid: 9722692].
Saenz de Tejada I, Goldstein I, Azadzoi K, Krane RJ, Cohen RA. Impaired neurogenic and endothelium-mediated relaxation of penile smooth muscle from diabetic men with impotence. New England Journal of Medicine. 1989;320(16):1025-30. [pmid: 2927481].
Sakki TK, Knuuttila MLE, Vimpari SS, Hartikainen MSL. Association of lifestyle with periodontal health. Community Dentistry and Oral Epidemiology. 1995;23(3):155-8. [pmid: 7634770].
Salvi M, Pedrazzoni M, Girasole G, Guiliani N, Minelli R, Wall JR, Roti E. Serum concentrations of pro-inflammatory cytokines in Graves’ disease: effect of treatment, thyroid function, ophthalmopathy, and smoking. European Journal of Endocrinology. 2000;143(2):197-202. [pmid: 10913938].
Samuels LE, Sharma S, Kaufman MS, Morris RJ, Brockman SK. Coronary artery bypass grafting in patients in their third decade of life. Journal of Cardiac Surgery. 1996;11(6):402-7. [pmid: 9083865].
Santavirta S, Konttinen YT, Heliövaara M, Knekt P, Lüthje P, Aromaa A. Determinants of osteoporotic thoracic vertebral fracture: screening of 57,000 Finnish women and men. Acta Orthopaedica Scandinavica. 1992;63(2):198-202. [pmid: 1590058].
Sarks SH, Sarks JP. Age-related macular degeneration: atrophic form. Ryan SJ, Schachat AP, Murphy RB, editors. Retina. 2nd ed. St. Louis. Mosby. 1994;2:1071-102.
Sasajima T, Kubo Y, Inaba M, Goh K, Azuma N. Role of infrainguinal bypass in Buerger’s disease: an eighteen-year experience. European Journal of Vascular and Endovascular Surgery. 1997;13(2):186-92. [pmid: 9091153].
Sayers NM, James JA, Drucker DB, Blinkhorn AS. Possible potentiation of toxins from Prevotella intermedia, Prevotella nigrescens, and Porphyromonas gingivalis by cotinine. Journal of Periodontology. 1999;70(11):1269-75. [pmid: 10588489].
Scane AC, Francis RM, Sutcliffe AM, Francis MJD, Rawlings DJ, Chapple CL. Case-control study of the pathogenesis and sequelae of symptomatic vertebral fractures in men. Osteoporosis International. 1999;9(1):91-7. [pmid: 10367034].
Scheffler E, Huber L, Fruhbis J, Schulz I, Ziegler R, Dresel HA. Alteration of plasma low density lipo-protein from smokers. Atherosclerosis. 1990;82(3):261-5. [pmid: 2375790].
Scheffler E, Wiest E, Woehrle J, Otto I, Schulz I, Huber L, Ziegler R, Dresel HA. Smoking influences the atherogenic potential of low-density lipoprotein. Clinical Investigations. 1992;70(3–4):263-8.
Schenkein HA, Gunsolley JC, Koertge TE, Schenkein JG, Tew JG. Smoking and its effects on early-onset periodontitis. Journal of the American Dental Association. 1995;126(8):1107-13. [pmid: 7560567].
Schlemper RJ, van der Werf SDJ, Vandenbroucke JP, Biemond I, Lamers CBHW. Risk factors of peptic ulcer disease: different impact of Helicobacter pylori in Dutch and Japanese populations?. Journal of Gastroenterology and Hepatology. 1996;11(9):825-31. [pmid: 8889960].
Schnurr PP, Spiro A III. Combat exposure, post-traumatic stress disorder symptoms, and health behaviors as predictors of self-reported physical health in older veterans. Journal of Nervous and Mental Disease. 1999;187(6):353-9. [pmid: 10379722].
Schoenborn CA, Horm J. Negative moods as correlates of smoking and heavier drinking: implications for health promotion. Advance Data. 1993;236:1-16. [pmid: 10171806].
Schubert TT, Bologna SD, Nensey Y, Schubert AB, Mascha EJ, Ma CK. Ulcer risk factors: interactions between Helicobacter pylori infection, nonsteroidal use, and age. American Journal of Medicine. 1993;94(4):413-8. [pmid: 8475935].
Schulte-Hobein B, Schwartz-Bickenbach D, Abt S, Plum C, Nau H. Cigarette smoke exposure and development of infants throughout the first year of life: influence of passive smoking and nursing on cotinine levels in breast milk and infant’s urine. Acta Paediatrica. 1992;81(6–7):550-7. [pmid: 1392372].
Schwartz J, Weiss ST. Host and environmental factors influencing the peripheral blood leukocyte count. American Journal of Epidemiology. 1991;134(12):1402-9. [pmid: 1776614].
Schwartz-Bickenbach D, Schulte-Hobein B, Abt S, Plum C, Nau H. Smoking and passive smoking during pregnancy and early infancy: effects on birth weight, lactation period, and cotinine concentrations in mother’s milk and infant’s urine. Toxicology Letters. 1987;35(1):73-81. [pmid: 3810685].
Secker-Walker RH, Solomon LJ, Flynn BS, Dana GS. Comparisons of the smoking cessation counseling activities of six types of health professionals. Preventive Medicine. 1994;23(6):800-8. [pmid: 7855113].
Seddon JM, Willett WC, Speizer FE, Hankinson SE. A prospective study of cigarette smoking and age-related macular degeneration in women. Journal of the American Medical Association. 1996;276(14):1141-6. [pmid: 8827966].
Seeley DG, Kelsey J, Jergas M, Nevitt MC. Predictors of ankle and foot fractures in older women. Journal of Bone and Mineral Research. 1996;11(9):1347-55. [pmid: 8864910].
Segovia J, Bartlett RF, Edwards AC. The association between self-assessed health status and individual health practices. Canadian Journal of Public Health. 1989;80(1):34-7.
Seidell JC, Bakx KC, Deurenberg P, Burema J, Hautvast JG, Huygen FJ. The relation between overweight and subjective health according to age, social class, slimming behavior and smoking habits in Dutch adults. American Journal of Public Health. 1986;76(12):1410-5. [pmid: 3777287].
Shabsigh R, Fishman IJ, Schum C, Dunn JK. Cigarette smoking and other vascular risk factors in vasculogenic impotence. Urology. 1991;38(3):227-31. [pmid: 1887536].
Sheiham A. Periodontal disease and oral cleanliness in tobacco smokers. Journal of Periodontology. 1971;42(5):259-63. [pmid: 5280493].
Shephard RJ, Ponsford E, Basu PK, LaBarre R. Effects of cigarette smoking on intraocular pressure and vision. British Journal of Ophthalmology. 1978;62(10):682-7. [pmid: 708669].
Shiloah J, Patters MR, Waring MB. The prevalence of pathogenic periodontal microflora in healthy young adult smokers. Journal of Periodontology. 2000;71(4):562-7. [pmid: 10807119].
Shine B, Fells P, Edwards OM, Weetman AP. Association between Graves’ ophthalmopathy and smoking. Lancet. 1990;335(8700):1261-3. [pmid: 1971331].
Shizukuishi S, Hayashi N, Tamagawa H, Hanioka T, Maruyama S, Takeshita T, Morimoto K. Lifestyle and periodontal health status of Japanese factory workers. Annals of Periodontology. 1998;3(1):303-11. [pmid: 9722714].
Silcox DH 3rd, Daftari T, Boden SD, Schimandle JH, Hutton WC, Whitesides TE Jr. The effect of nicotine on spinal fusion. Spine. 1995;20(14):1549-53. [pmid: 7570168].
Silverman NA, Potvin C, Alexander JC Jr, Chretien PB. In vitro lymphocyte reactivity and T-cell levels in chronic cigarette smokers. Clinical and Experimental Immunology. 1975;22(2):285-92. [pmid: 1082401].
Sinclair DR, Chung F, Mezei G. Can postoperative nausea and vomiting be predicted?. Anesthesiology. 1999;91(1):109-18. [pmid: 10422935].
Sinha RN, Patrick AW, Richardson L, Wallymahmed M, MacFarlane IA. A six-year follow-up study of smoking habits and microvascular complications in young adults with type 1 diabetes. Postgraduate Medical Journal. 1997;73(859):293-4. [pmid: 9196703].
Sippel JM, Pedula KL, Vollmer WM, Buist AS, Osborne ML. Associations of smoking with hospital-based care and quality of life in patients with obstructive airway disease. Chest. 1999;115(3):691-6. [pmid: 10084477].
Sjolie AK. Ocular complications in insulin treated diabetes mellitus: an epidemiological study. Acta Ophthalmologica Supplement. 1985;172:1-77. [pmid: 2988264].
Slemenda CW, Christian JC, Reed T, Reister TK, Williams CJ, Johnston CC Jr. Long-term bone loss in men: effects of genetic and environmental factors. Annals of Internal Medicine. 1992;117(4):286-91. [pmid: 1637023].
Slemenda CW, Hui SL, Longcope C, Johnston CC Jr. Cigarette smoking, obesity, and bone mass. Journal of Bone and Mineral Research. 1989;4(5):737-41. [pmid: 2816518].
Slemenda CW, Longcope C, Zhou L, Hui SL, Peacock M, Johnston CC. Sex steroids and bone mass in older men: positive associations with serum estrogens and negative associations with androgens. Journal of Clinical Investigation. 1997;100(7):1755-9. [pmid: 9312174].
Smeets-Goevaers CG, Lesusink GL, Papapoulos SE, Maartens LW, Keyzer JJ, Weerdenburg JP, Beijers LM, Zwinderman AH, Knottnerus JA, Pols HA, Pop VJ. The prevalence of low bone mineral density in Dutch perimenopausal women: the Eindhoven perimenopausal osteoporosis study. Osteoporosis International. 1998;8(5):404-9. [pmid: 9850346].
Smith DJ. Absenteeism and “presenteeism” in industry. Archives of Environmental Health. 1970;21(5):670-7. [pmid: 5475430].
Smith GC, Athanasou JA, Reid CC, Ng TKW, Ferguson DA. Sickness absence, respiratory impairment and smoking in industry. Medical Journal of Australia. 1981;1(5):235-7. [pmid: 7231312].
Smith W, Mitchell P, Leeder SR. Smoking and age-related maculopathy: the Blue Mountains Eye Study. Archives of Ophthalmology. 1996;114(12):1518-23. [pmid: 8953988].
Söder B, Jin LJ, Söder P-Ö, Wikner S. Clinical characteristics of destructive periodontitis in a risk group of Swedish urban adults. Swedish Dental Journal. 1995;19(1–2):9-15. [pmid: 7597634].
Söder B, Nedlich U, Jin LJ. Longitudinal effect of non-surgical treatment and systemic metronidazole for 1 week in smokers and non-smokers with refractory periodontitis: a 5-year study. Journal of Periodontology. 1999;70(7):761-71. [pmid: 10440638].
Söder P-Ö, Jin LJ, Söder B, Wikner S. Periodontal status in an urban adult population in Sweden. Community Dentistry and Oral Epidemiology. 1994;22(2):106-11. [pmid: 8205774].
Solomon HA, Priore RL, Bross ID. Cigarette smoking and periodontal disease. Journal of the American Dental Association. 1968;77(5):1081-4. [pmid: 5245655].
Sommer A, Tielsch JM, Katz J, Quigley HA, Gottsch JD, Javitt JC, Martone JF, Royall RM, Witt KA, Ezrine S. Racial differences in the cause-specific prevalence of blindness in east Baltimore. New England Journal of Medicine. 1991;325(20):1412-7. [pmid: 1922252].
Sonnenberg A. Smoking and mortality from peptic ulcer in the United Kingdom. Gut. 1986;27(11):1369-72. [pmid: 3792919].
Sonnenberg A, Everhart JE. The prevalence of self-reported peptic ulcer in the United States. American Journal of Public Health. 1996;86(2):200-5. [pmid: 8633736].
Sorensen LT, Jorgensen T, Kirkeby LT, Skodval J, Vennits B, Wille-Jorgensen P. Smoking and alcohol abuse are major risk factors for anastomotic leakage in colorectal surgery. British Journal of Surgery. 1999;86(7):927-31. [pmid: 10417567].
Sowers MR, Clark MK, Hollis B, Wallace RB, Jannausch M. Radial bone mineral density in pre- and perimenopausal women: a prospective study of rates and risk factors for loss. Journal of Bone and Mineral Research. 1992;7(6):647-57. [pmid: 1414483].
Sowers MR, Wallace RB, Lemke JH. Correlates of mid-radius bone density among postmenopausal women: a community study. American Journal of Clinical Nutrition. 1985;41(5):1045-53. [pmid: 3873171].
Sparrow D, Glynn RJ, Cohen M, Weiss ST. The relationship of the peripheral leukocyte count and cigarette smoking to pulmonary function among adult men. Chest. 1984;86(3):383-6. [pmid: 6467999].
Spelman DW, Russo P, Harrington G, Davis BB, Rabinov M, Smith JA, Spicer WJ, Esmore D. Risk factors for surgical wound infection and bacter-aemia following coronary artery bypass surgery. Australian and New Zealand Journal of Surgery. 2000;70(1):47-51. [pmid: 10696943].
Stamm JW, Banting DW, Imrey PB. Adult root caries survey of two similar communities with contrasting natural water fluoride levels. Journal of the American Dental Association. 1990;120(2):143-9. [pmid: 2299058].
Stansfeld SA, Smith GD, Marmot M. Association between physical and psychological morbidity in the Whitehall II Study. Journal of Psychosomatic Research. 1993;37(3):227-38. [pmid: 8478817].
Steers RM, Rhodes SR. Major influences on employee attendance: a process model. Journal of Applied Psychology. 1978;63(4):391-407.
Steinberg EP, Javitt JC, Sharkey PD, Zuckerman A, Legro MW, Anderson GF, Bass EB, O’Day D. The content and cost of cataract surgery. Archives of Ophthalmology. 1993;111(8):1041-9. [pmid: 8352686].
Steinhardt M, Greenhow L, Stewart J. The relationship of physical activity and cardiovascular fitness to absenteeism and medical care claims among law enforcement officers. American Journal of Health Promotion. 1991;5(6):455-60. [pmid: 10171669].
Stoltenberg JL, Osborn JB, Pihlstrom BL, Herzberg MC, Aeppli DM, Wolff LF, Fischer GE. Association between cigarette smoking, bacterial pathogens, and periodontal status. Journal of Periodontology. 1993;64(12):1225-30. [pmid: 8106950].
Strawbridge WJ. The attribution of health problems to aging. American Journal of Public Health. 1993;83(9):1351-2. [pmid: 8363023].
Stryker WS, Kaplan LA, Stein EA, Stampfer MJ, Sober A, Willett WC. The relation of diet, cigarette smoking, and alcohol consumption to plasma beta-carotene and alpha-tocopherol levels. American Journal of Epidemiology. 1988;127(2):283-96. [pmid: 3257350].
Summers CJ, Oberman A. Association of oral disease with 12 selected variables. I: periodontal disease. Journal of Dental Research. 1968;47(3):457-62. [pmid: 5240797].
Sunyer J, Muñoz A, Peng Y, Margolick J, Chmiel JS, Oishi J, Kingsley L, Samet JM. Longitudinal relation between smoking and white blood cells. American Journal of Epidemiology. 1996;144(8):734-41. [pmid: 8857822].
Suzuki Y, Kadowaki H, Atsumi Y, Hosokawa K, Katagiri H, Kadowaki T, Oka Y, Uyama K, Mokubo A, Asahina T, Murata C, Matsuoka K. A case of diabetic amyotrophy associated with 3243 mitochondrial tRNA(leu; UUR) mutation and successful therapy with coenzyme Q10. Endocrine Journal. 1995;42(2):141-5. [pmid: 7542975].
Svanes C, Soreide JA, Skarstein A, Fevang BT, Bakke P, Vollset SE, Svanes K, Sooreide O. Smoking and ulcer perforation. Gut. 1997;41(2):177-80. [pmid: 9301495].
Swenson HM. The effect of cigarette smoking on plaque formation. Journal of Periodontology. 1979;50(3):146-7. [pmid: 285264].
Taani DSQ. Association between cigarette smoking and periodontal health. Quintessence International. 1997;28(8):535-9. [pmid: 9477881].
Tagesson C, Chabiuk D, Axelson O, Baranski B. Increased urinary excretion of the oxidative DNA adduct, 8-hydroxydeoxyguanosine, as a possible early indicator of occupational cancer hazards in the asbestos, rubber and azo-dye industries. Polish Journal of Occupational Medicine and Environmental Health. 1993;6(4):357-68. [pmid: 8019198].
Tagesson C, Källberg M, Wingren G. Urinary malondialdehyde and 8-hydroxydeoxyguanosine as potential markers of oxidative stress in industrial art glass workers. International Archives of Occupational and Environmental Health. 1996;69(1):5-13. [pmid: 9017428].
Taha AS, Angerson W, Nakshabendi I, Beekman H, Morran C, Sturrock RD, Russell RI. Gastric and duodenal mucosal blood flow in patients receiving non-steroidal anti-inflammatory drugs—influence of age, smoking, ulceration and Helicobacter pylori. Alimentary Pharmacology and Therapeutics. 1993;7(1):41-5. [pmid: 8439636].
Takada H, Washino K, Iwata H. Risk factors for low bone mineral density among females: the effect of lean body mass. Preventive Medicine. 1997;26(5 Pt 1):633-8. [pmid: 9327470].
Takeishi M, Shaw WW, Ahn CY, Borud L. TRAM flaps in patients with abdominal scars. Plastic Reconstruction and Surgery. 1997;97(3):713-22.
Takeuchi T, Nakajima M, Ohta Y, Mure K, Takeshita T, Morimoto K. Evaluation of 8-hydroxydeoxyguanosine, a typical oxidative DNA damage, in human leukocytes. Carcinogenesis. 1994;15(8):1519-23. [pmid: 8055628].
Talamini G, Zamboni G, Cavallini G. Antral mucosal Helicobacter pylori infection density as a risk factor of duodenal ulcer. Digestion. 1997;58(3):211-7. [pmid: 9243115].
Tamakoshi A, Yuzawa M, Matsui M, Uyama M, Fujiwara NK, Ohno Y. Smoking and neovascular form of age related macular degeneration in late middle aged males: findings from a case-control study in Japan. British Journal of Ophthalmology. 1997;81(10):901-4. [pmid: 9486034].
Taylor PJ. Personal factors associated with sickness absence: a study of 194 men with contrasting sickness absence experience in a refinery population. British Journal of Industrial Medicine. 1968;25(2):106-18. [pmid: 4231051].
Taylor A, Jacques PF, Epstein EM. Relations among aging, antioxidant status, and cataract. American Journal of Clinical Nutrition. 1995;62(6 Suppl):1439S-1447S. [pmid: 7495245].
Taylor A, Jacques PF, Nowell T, Perrone G, Blumberg J, Handelman J, Jozwiak B, Nadler D. Vitamin C in human and guinea pig aqueous, lens and plasma in relation to intake. Current Eye Research. 1997;16(9):857-64. [pmid: 9288446].
Tell GS, Grimm RH Jr, Vellar OD, Theodorsen L. The relationship of white cell count, platelet count, and hematocrit to cigarette smoking in adolescents: the Oslo Youth Study. Circulation. 1985;72(5):971-4. [pmid: 4042305].
Tellez M, Cooper J, Edmonds C. Graves’ ophthalmopathy in relation to cigarette smoking and ethnic origin. Clinical Endocrinology. 1992;36(3):291-4. [pmid: 1563082].
Telmer S, Christiansen JS, Andersen AR, Nerup J, Deckert T. Smoking habits and prevalence of clinical diabetic microangiopathy in insulin-dependent diabetics. Acta Medica Scandinavica. 1984;215(1):63-8. [pmid: 6695564].
ten Cate B. The role of saliva in mineral equilibrium— caries and calculus formation. Edgar WM, O’Mullane DM, editors. Saliva and Oral Health. 2nd ed. London. British Dental Association. 1996:123-36.
Tengs TO, Osgood ND. The link between smoking and impotence: two decades of evidence. Preventive Medicine. 2001;32(6):447-52. [pmid: 11394947].
Terry PE, Fowler EJ, Fowles JB. Are health risks related to medical care charges in the short-term? Challenging traditional assumptions. American Journal of Health Promotion. 1998;12(5):340-7. [pmid: 10181144].
Thomas CB. Characteristics of smokers compared with nonsmokers in a population of healthy young adults, including observations on family history, blood pressure, heart rate, body weight, cholesterol and certain psychologic trails. Annals of Internal Medicine. 1960;53(4):697-718. [pmid: 13776447].
Thomas S, Raja RV, Kutty R, Strayer MS. Pattern of caries experience among an elderly population in south India. International Dental Journal. 1994;44(6):617-22. [pmid: 7851994].
Thylefors B, Negrel AD, Pararajasegaram R, Dadzie KY. Global data on blindness. Bulletin of the World Health Organization. 1995;73(1):115-21. [pmid: 7704921].
Tibblin E, Bengtsson C, Hallberg L, Lennartsson J. Haemoglobin concentration and peripheral blood cell counts in women: the population study of women in Goteborg 1968–1969. Scandinavian Journal of Haematology. 1979;22(1):5-16. [pmid: 424698].
Tillmann M, Silcock J. A comparison of smokers’ and ex-smokers’ health-related quality of life. Journal of Public Health Medicine. 1997;19(3):268-73. [pmid: 9347449].
Tipton DA, Dabbous MK. Effects of nicotine on proliferation and extracellular matrix production of human gingival fibroblasts in vitro. Journal of Periodontology. 1995;66(12):1056-64. [pmid: 8683418].
Tomar SL, Asma S. Smoking-attributable periodontitis in the United States: findings from NHANES III. Journal of Periodontology. 2000;71(5):743-51. [pmid: 10872955].
Tomar SL, Husten CG, Manley MW. Do dentists and physicians advise tobacco users to quit?. Journal of the American Dental Association. 1996;127(2):259-65. [pmid: 8682997].
Tomar SL, Swango PA, Kleinman DV, Burt BA. Loss of periodontal attachment in HIV-seropositive military personnel. Journal of Periodontology. 1995;66(6):421-8. [pmid: 7562330].
Tomar SL, Winn DM. Chewing tobacco use and dental caries among U.S. men. Journal of the American Dental Association. 1999;130(11):1601-10. [pmid: 10573940].
Tonetti MS, Pini-Prato G, Cortellini P. Effect of cigarette smoking on periodontal healing following GTR in infrabony defects: a preliminary retrospective study. Journal of Clinical Periodontology. 1995;22(3):229-34. [pmid: 7790529].
Tracy RP, Psaty BM, Macy E, Bovill EG, Cushman M, Cornell ES, Kuller LH. Lifetime smoking exposure affects the association of C-reactive protein with cardiovascular disease risk factors and subclinical disease in healthy elderly subjects. Arteriosclerosis, Thrombosis, and Vascular Biology. 1997;17(10):2167-76.
Trombelli L, Scabbia A. Healing response of gingival recession defects following guided tissue regeneration procedures in smokers and non-smokers. Journal of Clinical Periodontology. 1997;24(8):529-33. [pmid: 9266338].
Tsai SP, Gilstrap EL, Colangelo TA, Menard AK, Ross CE. Illness absence at an oil refinery and petrochemical plant. Journal of Occupational and Environmental Medicine. 1997;39(5):455-62. [pmid: 9172091].
Turner WED. Sickness absence in the freezing industry. New Zealand Medical Journal. 1988;101(856 Pt 1):663-6. [pmid: 3186006].
Turner LW, Fu Q, Taylor JE, Wang MQ. Osteoporotic fracture among older U.S. women: risk factors quantified. Journal of Aging and Health. 1998;10(3):372-91. [pmid: 10342937].
Tytgat GNJ, Noach LA, Rauws EAJ. Helicobacter pylori infection and duodenal ulcer disease. Gastroenterology Clinics of North America. 1993;22(1):127-39. [pmid: 8449562].
Unge P, Gad A, Eriksson K, Bergman B, Carling L, Ekström P, Glise H, Gnarpe H, Junghard O, Lindholmer C, Sandzén B, Strandberg L, Stubberöd A, Weywad L. Amoxicillin added to omeprazole prevents relapse in the treatment of duodenal ulcer patients. European Journal of Gastroenterology and Hepatology. 1993;5(5):325-31.
US Department of Health and Human Services. The Health Consequences of Smoking for Women A Report of the Surgeon General. Washington. U.S. Department of Health and Human Services, Public Health Service, Office of the Assistant Secretary for Health, Office on Smoking and Health. 1980.
US Department of Health and Human Services. The Health Consequences of Smoking: Chronic Obstructive Lung Disease A Report of the Surgeon General. Rockville (MD). U.S. Department of Health and Human Services, Public Health Service, Office on Smoking and Health. 1984. DHHS Publication No. (PHS) 84–50205.
US Department of Health and Human Services. The Health Consequences of Smoking: Nicotine Addiction A Report of the Surgeon General. Atlanta. US Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health. 1988. DHHS Publication No. (CDC) 88–8406.
US Department of Health and Human Services. The Health Benefits of Smoking Cessation A Report of the Surgeon General. Atlanta. US Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health. 1990. DHHS Publication No. (CDC) 90–8416.
US Department of Health and Human Services. Preventing Tobacco Use Among Young People: A Report of the Surgeon General. Atlanta. US Department of Health and Human Services, Public Health Service, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health. 1994.
US Department of Health and Human Services. Oral Health in America: A Report of the Surgeon General. Rockville (MD). U.S. Department of Health and Human Services, National Institutes of Health, National Institute of Dental and Craniofacial Research. 2000.
US Department of Health and Human Services. Women and Smoking A Report of the Surgeon General. Rockville (MD). U.S. Department of Health and Human Services, Public Health Service, Office of the Surgeon General. 2001.
US Department of Health, Education, and Welfare. Smoking and Health Report of the Advisory Committee to the Surgeon General of the Public Health Service. Washington. U.S. Department of Health, Education, and Welfare, Public Health Service. 1964. PHS Publication No. 1103.
US Department of Health, Education, and Welfare. The Health Consequences of Smoking A Public Health Service Review: 1967. Washington. U.S. Department of Health, Education, and Welfare, Public Health Service, Health Services and Mental Health Administration. 1967. PHS Publication No. 1696.
US Department of Health, Education, and Welfare. The Health Consequences of Smoking A Report of the Surgeon General. Rockville (MD). U.S. Department of Health, Education, and Welfare, Public Health Service, Health Services and Mental Health Administration. 1971. DHEW Publication No. (HSM) 71–7513.
US Department of Health, Education, and Welfare. The Health Consequences of Smoking A Report of the Surgeon General. Rockville (MD). U.S. Department of Health, Education, and Welfare, Public Health Service, Health Services and Mental Health Administration. 1972. DHEW Publication No. (HSM) 72–7516.
US Department of Health, Education, and Welfare. The Health Consequences of Smoking A Report of the Surgeon General, 1975. Washington. U.S. Department of Health, Education, and Welfare, Public Health Service, Center for Disease Control. 1975. DHEW Publication No. (CDC) 76–8704.
US Department of Health, Education, and Welfare. Smoking and Health A Report of the Surgeon General. Rockville (MD). U.S. Department of Health, Education, and Welfare, Public Health Service, Office of the Assistant Secretary for Health, Office on Smoking and Health. 1979. DHEW Publication No. (PHS) 79–50066.
Utley JR, Leyland SA, Fogarty CM, Smith WP, Knight EB, Feldman GJ, Wilde EF. Smoking is not a predictor of mortality and morbidity following coronary artery bypass grafting. Journal of Cardiac Surgery. 1996;11(6):377-84. [pmid: 9083862].
Välimäki MJ, Kärkkäinen M, Lamberg-Allardt C, Laitinen K, Alhava E, Heikkinen J, Impivaara O, Mäkelä P, Palmgren J, Seppänen R, Vuori I. the Cardiovascular Risk in Young Finns Study Group. Exercise, smoking, and calcium intake during adolescence and early adulthood as determinants of peak bone mass. British Medical Journal. 1994;309(6949):230-5. [pmid: 8069139].
Van Der Hulst RWM, Rauws EAJ, Köycü B, Keller JJ, Bruno MJ, Tijssen JGP, Tytgat GNJ. Prevention of ulcer recurrence after eradication of Helicobacter pylori: a prospective long-term follow-up study. Gastroenterology. 1997;113(4):1082-6. [pmid: 9322501].
Van Peenen PFD, Blanchard AG, Wolkonsky PM, Gill TM. Health insurance claims of petrochemical company employees. Journal of Occupational Medicine. 1986;28(3):237-40. [pmid: 3701470].
Van Tuinen M, Land G. Smoking and excess sick leave in a department of health. Journal of Occupational Medicine. 1986;28(1):33-5. [pmid: 3950778].
van Zeeland AA, de Groot AJL, Hall J, Donato F. 8-Hydroxydeoxyguanosine in DNA from leukocytes of healthy adults: relationship with cigarette smoking, environmental tobacco smoke, alcohol and coffee consumption. Mutation Research. 1999;439(2):249-57. [pmid: 10023075].
Vanuxem D, Sampol J, Weiller PJ, M’Barki M, Grimaud C. Influence of chronic smoking on leukocytes [French]. Respiration. 1984;46(3):258-64. [pmid: 6494620].
Varenna M, Binelli L, Zucchi F, Ghiringhelli D, Gallazzi M, Sinigaglia L. Prevalence of osteoporosis by educational level in a cohort of postmenopausal women. Osteoporosis International. 1999;9(3):236-41. [pmid: 10450413].
Vasse RM, Nijhuis FJN, Kok G. Associations between work stress, alcohol consumption and sickness absence. Addiction. 1998;93(2):231-41. [pmid: 9624724].
Vinding T, Appleyard M, Nyboe J, Jensen G. Risk factor analysis for atrophic and exudative age-related macular degeneration: an epidemiological study of 1000 aged individuals. Acta Ophthalmologica. 1992;70(1):66-72. [pmid: 1557977].
Vingerling JR, Hofman A, Grobbee DE, de Jong PT. Age-related macular degeneration and smoking: the Rotterdam Study. Archives of Ophthalmology. 1996;114(10):1193-6. [pmid: 8859077].
Virag R, Bouilly P, Frydman D. Is impotence an arterial disorder? A study of arterial risk factors in 440 impotent men. Lancet. 1985;1(8422):181-4. [pmid: 2857264].
Vogel JM, Davis JW, Nomura A, Wasnich RD, Ross PD. The effects of smoking on bone mass and the rates of bone loss among elderly Japanese-American men. Journal of Bone and Mineral Research. 1997;12(9):1495-501. [pmid: 9286767].
Vogt TM, Schweitzer SO. Medical costs of cigarette smoking in a health maintenance organization. American Journal of Epidemiology. 1985;122(6):1060-6. [pmid: 4061440].
Wabrek AJ, Shelley MA, Horowitz LM, Bastarache MM, Giuca JE. Noninvasive penile arterial evaluation in 120 males with erectile dysfunction. Urology. 1983;22(3):230-4. [pmid: 6604973].
Wagner EH, Curry SJ, Grothaus L, Saunders DW, McBride CM. The impact of smoking and quitting on health care use. Archives of Internal Medicine. 1995;155(16):1789-95. [pmid: 7654113].
Wagner G, Béjin A, Fugl-Meyer AR, Glina S, Kimoto Y, Lukacs CSB, Mulcahy J, O’Leary M. Symptom score and quality of life. Jardin A, Wagner G, Khoury S, Giuliano F, Padma-Nathan H, Rosen R, editors. Erectile Dysfunction. Plymouth (United Kingdom). Health Publication. 2000:105-13.
Wakai K, Kawamura T, Umemura O, Hara Y, Machida J-I, Anno T, Ichihara Y, Mizuno Y, Tamakoshi A, Lin Y, Nakayama T, Ohno Y. Associations of medical status and physical fitness with periodontal disease. Journal of Clinical Periodontology. 1999;26(10):664-72. [pmid: 10522778].
Wakefield M, Ruffin R, Campbell D, Roberts L, Wilson D. Smoking-related beliefs and behaviour among adults with asthma in a representative population sample. Australian and New Zealand Journal of Medicine. 1995;25(1):12-7. [pmid: 7786238].
Walker JM, Cove DH, Beevers DG, Dodson PM, Leatherdale BA, Fletcher RF, Wright AD. Cigarette smoking, blood pressure and the control of blood glucose in the development of diabetic retinopathy. Diabetes Research. 1985;2(4):183-6. [pmid: 4085172].
Wang J-Y, Liu S-B, Chen S-Y, Dobson A. Risk factors for peptic ulcer in Shanghai. International Journal of Epidemiology. 1996;25(3):638-43. [pmid: 8671567].
Warner DO, Warner MA, Offord KP, Schroeder DR, Maxson P, Scanlon PD. Airway obstruction and perioperative complications in smokers undergoing abdominal surgery. Anesthesiology. 1999;90(2):372-9. [pmid: 9952139].
Warner KE, Smith RJ, Smith DG, Fries BE. Health and economic implications of a work-site smoking-cessation program: a simulation analysis. Journal of Occupational and Environmental Medicine. 1996;38(10):981-92. [pmid: 8899574].
Wasada T, Kawahara R, Katsumori K, Naruse M, Omori Y. Plasma concentration of immunoreactive vascular endothelial growth factor and its relation to smoking. Metabolism. 1998;47(1):27-30. [pmid: 9440473].
Watterson PA, Bostwick J 3rd, Hester TR Jr, Bried JT, Taylor GI. TRAM flap anatomy correlated with a 10-year clinical experience with 556 patients. Plastic Reconstruction and Surgery. 1995;95(7):1185-94.
Weaver MT, Forrester BG, Brown KC, Phillips JA, Hilyer JC, Capilouto EI. Health risk influence on medical care costs and utilization among 2,898 municipal employees. American Journal of Preventive Medicine. 1998;15(3):250-3. [pmid: 9791645].
Weil J, Langman MJS, Wainwright P, Lawson DH, Rawlins M, Logan RFA, Brown TP, Vessey MP, Murphy M, Colin-Jones DG. Peptic ulcer bleeding: accessory risk factors and interactions with non-steroidal anti-inflammatory drugs. Gut. 2000;46(1):27-31. [pmid: 10601050].
Weinkam JJ, Rosenbaum W, Sterling TD. Smoking and hospital utilization. Social Science and Medicine. 1987;24(11):983-6. [pmid: 3616692].
Weiss NS, Liff JM, Ure CL, Ballard JH, Abbott GH, Daling JR. Mortality in women following hip fracture. Journal of Chronic Diseases. 1983;36(12):879-82. [pmid: 6655032].
West KM, Erdreich LS, Stober JA. Absence of a relationship between smoking and diabetic microangiopathy. Diabetes Care. 1980;3(2):250-2. [pmid: 7389546].
West S, Munoz B, Emmett EA, Taylor HR. Cigarette smoking and risk of nuclear cataracts. Archives of Ophthalmology. 1989a;107(8):1166-9. [pmid: 2757547].
West S, Muñoz B, Schein OD, Vitale S, Maguire M, Taylor HR, Bressler NM. Cigarette smoking and risk for progression of nuclear opacities. Archives of Ophthalmology. 1995;113(11):1377-80. [pmid: 7487597].
West SK, Muñoz B, Schein OD, Duncan DD, Rubin GS. Racial differences in lens opacities: the Salisbury Eye Evaluation (SEE) Project. American Journal of Epidemiology. 1998;148(11):1033-9. [pmid: 9850124].
West SK, Rosenthal FS, Bressler NM, Bressler SB, Munoz B, Fine SL, Taylor HR. Exposure to sunlight and other risk factors for age-related macular degeneration. Archives of Ophthalmology. 1989b;107(6):875-9. [pmid: 2786410].
West SK, Valmadrid CT. Epidemiology of risk factors for age-related cataract. Survey of Ophthalmology. 1995;39(4):323-34. [pmid: 7725232].
Wetterslev J, Hansen EG, Kamp-Jensen M, Roikjaer O, Kanstrup IL. PaO2 during anaesthesia and years of smoking predict late postoperative hypoxaemia and complications after upper abdominal surgery in patients without preoperative cardiopulmonary dysfunction. Acta Anaesthesiologica Scandinavica. 2000;44(1):9-16. [pmid: 10669265].
Wetzler HP, Ursano RJ. A positive association between physical health practices and psychological well-being. Journal of Nervous and Mental Disease. 1988;176(5):280-3. [pmid: 3259260].
Wickham CAC, Walsh K, Cooper C, Barker DJP, Margetts BM, Morris J, Bruce SA. Dietary calcium, physical activity, and risk of hip fracture: a prospective study. British Medical Journal. 1989;299(6704):889-92. [pmid: 2510879].
Wiley JA, Camacho TC. Life-style and future health: evidence from the Alameda County Study. Preventive Medicine. 1980;9(1):1-21. [pmid: 7360725].
Williams AR, Weiss NS, Ure CL, Ballard J, Daling JR. Effect of weight, smoking, and estrogen use on the risk of hip and forearm fractures in postmenopausal women. Obstetrics and Gynecology. 1982;60(6):695-9. [pmid: 7145267].
Wilson MR, Hertzmark E, Walker AM, Childs-Shaw K, Epstein DL. A case-control study of risk factors in open angle glaucoma. Archives of Ophthalmology. 1987;105(8):1066-71. [pmid: 3632414].
Wilson RW. Cigarette smoking, disability days and respiratory conditions. Journal of Occupational Medicine. 1973;15(3):236-40. [pmid: 4693167].
Wilson RW, Elinson J. National Survey of Personal Health Practices and Consequences: background, conceptual issues, and selected findings. Public Health Reports. 1981;96(3):218-25. [pmid: 7232681].
Winsa B, Mandahl A, Karlsson FA. Graves’ disease, endocrine ophthalmopathy and smoking. Acta Endocrinologica. 1993;128(2):156-60. [pmid: 8451910].
Witteman EM, Hopman WP, Becx MC, De Koning RW, Tytgat GN, Janssen AJ, Jansen JB. Short report: smoking habits and the acquisition of metronidazole resistance in patients with Helicobacter pylori-related gastritis. Alimentary Pharmacology and Therapeutics. 1993;7(6):683-7. [pmid: 8161676].
Wood EA, Olmstead GW, Craig JL. An evaluation of lifestyle risk factors and absenteeism after two years in a worksite health promotion program. American Journal of Health Promotion. 1989;4(2):128-33. [pmid: 22204406].
Wooden M, Bush R. Smoking cessation and absence from work. Preventive Medicine. 1995;24(5):535-40. [pmid: 8524730].
World Health Organization. Periodontal Disease. Technical Report Series No 207. Geneva. World Health Organization. 1961.
Wouters FR, Salonen LWE, Frithiof L, Helldén LB. Significance of some variables on interproximal alveolar bone height based on cross-sectional epidemiologic data. Journal of Clinical Periodontology. 1993;20(3):199-206. [pmid: 8450085].
Xia HH, Talley NJ. Natural acquisition and spontaneous elimination of Helicobacter pylori infection: clinical implications. American Journal of Gastroenterology. 1997;92(10):1780-7. [pmid: 9382036].
Xie Y, Garban H, Ng C, Rajfer J, Gonzalez-Cadavid NF. Effect of long-term passive smoking on erectile function and penile nitric oxide synthase in the rat. Journal of Urology. 1997;157(3):1121-6. [pmid: 9072555].
Yarnell JWG, Sweetnam PM, Rogers S, Elwood PC, Bainton D, Baker IA, Eastham R, O’Brien JR, Etherington MD. Some long term effects of smoking on the haemostatic system: a report from the Caerphilly and Speedwell Collaborative Surveys. Journal of Clinical Pathology. 1987;40(8):909-13. [pmid: 3654991].
Yeung DL. Relationships between cigarette smoking, oral contraceptives, and plasma vitamins A, E, C, and plasma triglycerides and cholesterol. American Journal of Clinical Nutrition. 1976;29(11):1216-21. [pmid: 998536].
York JL, Hirsch JA. Drinking patterns and health status in smoking and nonsmoking alcoholics. Alcoholism, Clinical and Experimental Research. 1995;19(3):666-73.
Zalokar JB, Richard JL, Claude JR. Leukocyte count, smoking, and myocardial infarction. New England Journal of Medicine. 1981;304(8):465-8. [pmid: 7453772].
Zambon JJ, Grossi SG, Machtei EE, Ho AW, Dunford R, Genco RJ. Cigarette smoking increases the risk for subgingival infection with periodontal pathogens. Journal of Periodontology. 1996;67(10 Suppl):1050-4. [pmid: 8910822].
Zitterbart PA, Matranga LF, Christen AG, Park KK, Potter RH. Association between cigarette smoking and the prevalence of dental caries in adult males. General Dentistry. 1990;38(6):426-31. [pmid: 2097244].