# Reproductive Effects

## Introduction

Smoking harms many aspects of reproduction. An estimated 6 million women become pregnant each year in the United States, and more than 11,000 give birth each day (Ventura et al. 2000; Martin et al. 2002). Studies have shown that women who smoke are at an increased risk for a delay in becoming pregnant and for both primary and secondary infertility. Research has also shown that women who smoke during pregnancy risk complications, premature birth, low birth weight (LBW) infants, stillbirth, and infant mortality. LBW is a leading cause of infant deaths (Martin et al. 2002). Despite increased knowledge of the adverse health effects of smoking during pregnancy, only 18 to 25 percent of women quit smoking once they become pregnant. Data also suggest that a substantial number of pregnant women and girls continue to smoke (estimates range from 12 to 22 percent) (U.S. Department of Health and Human Services [USDHHS] 2001). This chapter reviews the evidence for a relationship between smoking and adverse reproductive effects. In particular, it examines the associations between smoking and fertility, smoking and pregnancy complications, and the health of children born to smokers.

## Conclusions of Previous Surgeon General’s Reports

Numerous previous reports of the Surgeon General on smoking and health have examined the effects of active smoking on the reproductive capabilities and outcomes for both men and women (Table 5.1). The 1964 Surgeon General’s report (U.S. Department of Health, Education, and Welfare [USDHEW] 1964) identified an association between smoking during pregnancy and LBW (infants weighing <2,500 grams [g] at birth) that has been further explored in subsequent reports. The 1969 Surgeon General’s report (USDHEW 1969) presented evidence on smoking during pregnancy and preterm delivery (<37 weeks completed gestation), spontaneous abortion, stillbirths, and neonatal mortality. The 1978 Surgeon General’s report (USDHEW 1978) introduced new findings concerning smoking and pregnancy complications including placental abruption, placenta previa, and the premature rupture of membranes. The 1980 report on the health consequences of smoking for women (USDHHS 1980) extended previous findings on birth weight, retarded fetal growth, benefits of smoking cessation early in pregnancy, pregnancy complications, effects of smoking on the placenta, and mortality including sudden infant death syndrome (SIDS). This report also introduced new information on smoking risks and fertility, congenital malformations, and longer-term morbidity. The 1989 report (USDHHS 1989) evaluated new data and continued to find (1) a relationship between maternal smoking during pregnancy and lower birth weights, (2) higher rates of fetal and perinatal mortality associated with maternal smoking during pregnancy, (3) mixed findings on the relationship of maternal smoking to congenital malformations, (4) a higher risk of infertility among women and possibly men related to smoking, and (5) conflicting findings with regard to maternal smoking and longer-term physical development in the infant and child. The 1990 report on the health benefits of cessation (USDHHS 1990) noted that LBW could be reduced by 26 to 42 percent if smoking during pregnancy were eliminated. The 2001 report described findings on birth weight, infertility, ectopic pregnancy, spontaneous abortion, pregnancy complications, and SIDS (USDHHS 2001). That report also addressed smoking and breastfeeding, a topic not considered in this report. In prior reports, causal conclusions have been reached for a number of adverse reproductive outcomes (Table 5.1).

Table 5.1 Conclusions from previous Surgeon General’s reports concerning smoking as a cause of reproductive effects

Disease and statement | Surgeon General’s report
Low birth weight
“Women who smoke cigarettes during pregnancy tend to have babies of lower birth weight.” (p. 39) | 1964
“New data are presented which confirm the finding that maternal smoking during pregnancy is associated with low birth weight in infants. . . .” (p. 5) | 1969
“Maternal smoking during pregnancy exerts a retarding influence on fetal growth as manifested by decreased infant birthweight and an increased incidence of prematurity, defined by weight alone.” (p. 13) | 1971
“Among all women in the United States, cigarette smokers are nearly twice as likely to deliver low-birth-weight infants as are non-smokers.” (p. 121) | 1973
“A dose-response relationship exists between smoking and the incidence of low birth weight, preterm delivery, perinatal mortality, abruptio placentae, placenta previa, bleeding during pregnancy, and prolonged and premature rupture of the membranes.” (p. 17) | 1978
“There is abundant evidence that maternal smoking is a direct cause of the reduction in birth weight. . . .Birth weight is affected by maternal smoking independently of other determinants of birth weight. The more the mother smokes, the greater the baby’s birth-weight reduction.” (p. 1–21) | 1979
“Babies born to women who smoke during pregnancy are, on the average, 200 grams lighter than babies born to comparable nonsmoking women.” (p. 10) | 1980
“There is a dose-response relationship between maternal smoking and reduced birth weight; the more the woman smokes during pregnancy, the greater the reduction in birth weight.” (p. 10) | 1980
“If a woman gives up smoking early during pregnancy, her risk of delivering a low-birth-weight baby approaches that of a nonsmoker.” (p. 10) | 1980
“Women who stop smoking before pregnancy or during the first 3 to 4 months of pregnancy reduce their risk of having a low birthweight baby to that of women who never smoked.” (p. i) | 1990
“Infants born to women who smoke during pregnancy have a lower average birth weight. . .than infants born to women who do not smoke.” (p. 307) | 2001
Small for gestational age
“. . .maternal smoking is associated with an increased incidence of prematurity defined by weight alone.” (p. 5) | 1969
“Overwhelming evidence indicates that maternal smoking during pregnancy affects fetal growth rate. . . .” (p. 1–21) | 1979
“Maternal smoking during pregnancy exerts a direct growth-retarding effect on the fetus; this effect does not appear to be mediated by reduced maternal appetite, eating or weight gain.” (p. 11) | 1980
“Although there is little effect of maternal smoking on mean gestation, the proportion of fetal deaths and live births that occur before term increases directly with maternal smoking level. Up to 14 percent of all preterm deliveries in the United States may be attributable to maternal smoking.” (p. 11) | 1980
“Infants born to women who smoke during pregnancy. . .are more likely to be small for gestational age than are infants born to women who do not smoke.” (p. 307) | 2001
Infertility
“Studies in women and men suggest that cigarette smoking may impair fertility.” (p. 12) | 1980
“. . .the data suggest that impairment of fertility measured as delay in time to conception is related to smoking near the time of attempting to conceive and that smoking cessation prior to conception returns fertility to that of never smokers.” (p. 375) | 1990
“Women who smoke have increased risks for conception delay and for both primary and secondary infertility.” (p. 307) | 2001
Ectopic pregnancy
“Women who smoke may have a modest increase in risks for ectopic pregnancy.” (p. 307) | 2001
Spontaneous abortion
“. . .it appears that maternal smoking during pregnancy may be associated with an increased incidence of spontaneous abortion, stillbirth, and neonatal death and that this relationship may be most marked in the presence of other risk factors.” (p. 5) | 1969
“There is insufficient evidence to support a comparable statement for abortions [as for fetal deaths and stillbirths].” (p. 13) | 1971
“Perinatal mortality increases significantly with smoking as well as with other risk factors such as maternal age, parity, socioeconomic status, previous pregnancy history, and hemoglobin level.” (p. 17) | 1978
“The risk of spontaneous abortion, fetal death, and neonatal death increases directly with increasing levels of maternal smoking during pregnancy; interaction of maternal smoking with other factors which increase perinatal mortality may result in an even greater risk.” (p. 11) | 1980
“Cigarette smoking is now considered to be a probable cause of unsuccessful pregnancies. . . .” (p. 20) | 1989
“Women who smoke may have a modest increase in risks for. . .spontaneous abortion.” (p. 307) | 2001
Pregnancy complications
“Maternal smoking increases the risk of fetal death through maternal complications such as abruptio placenta, placenta previa, antepartum hemorrhage, and prolonged rupture of membranes.” (p. 1–22) | 1979
“Increasing levels of maternal smoking result in a highly significant increase in the risk of abruptio placentae, placenta previa, bleeding early or late in pregnancy, premature and prolonged rupture of membranes, and preterm delivery—all of which carry high risks of perinatal loss.” (p. 11) | 1980
“The incidence of preeclampsia is decreased among women who smoke during pregnancy; however, if preeclampsia develops in a smoking woman, the risk of perinatal mortality is markedly increased compared to preeclamptic nonsmokers.” (p. 11) | 1980
“Smoking during pregnancy is associated with increased risks for preterm premature rupture of membranes, abruptio placentae, and placenta previa, and with a modest increase in risk for preterm delivery.” (p. 307) | 2001
“Women who smoke during pregnancy have a decreased risk for preeclampsia.” (p. 307) | 2001
Fetal deaths and stillbirths
“There is strong evidence to support the view that smoking mothers have a significantly greater number of unsuccessful pregnancies due to stillbirth and neonatal death as compared to nonsmoking mothers.” (p. 13) | 1971
“A strong, probably causal association between cigarette smoking and higher late fetal and infant mortality among smokers’ infants is supported by the. . .evidence.” (p. 134) | 1973
“A strong, probably causal, association exists between cigarette smoking and higher late fetal and infant mortality among smokers’ infants.” (p. 17) | 1978
“When adjustments are made for age-parity differences in mothers, their socio-economic status, and previous pregnancy histories, the risk of perinatal mortality attributable to smoking is highly significant, independent of these factors, and is dose-related.” (p. 1–22) | 1979
“The risk for perinatal mortality—both stillbirth and neonatal deaths—and the risk for sudden infant death syndrome (SIDS) are increased among the offspring of women who smoke during pregnancy.” (p. 307) | 2001
Infant mortality
“Maternal smoking increases the risk of fetal death through maternal complications such as abruptio placenta, placenta previa, antepartum hemorrhage, and prolonged rupture of membranes. . . .Smoking by pregnant women contributes to the risk of their infants being victims of the ‘sudden infant death syndrome’. . . .Maternal smoking can be a direct cause of fetal or neonatal death in an otherwise normal infant.” (p. 1–22) | 1979
“Excess deaths of smokers’ infants are found mainly in the coded cause categories of ‘unknown’ and ‘anoxia’ for fetal deaths, and the categories of ‘prematurity alone’ and ‘respiratory difficulty’ for neonatal deaths. . . .” (p. 11) | 1980
“An infant’s risk of developing the ‘sudden infant death syndrome’ is increased by maternal smoking during pregnancy.” (p. 11) | 1980
“Cigarette smoking is now considered to be a probable cause of. . .increased infant mortality. . . .” (p. 20) | 1989
Congenital malformations
“. . .no conclusions can be drawn about any relationship between maternal cigarette smoking and congenital malformation at the present time.” (p. 137) | 1973
“The accumulated evidence does not support a conclusion that maternal smoking increases the incidence of congenital malformations.” (p. 1–22) | 1979
“There are insufficient data to support a judgement on whether maternal and/or paternal cigarette smoking increases the risk of congenital malformations.” (p. 11) | 1980
“Smoking does not appear to affect the overall risk for congenital malformations.” (p. 307) | 2001
Impairment of children’s development
“According to studies of long-term growth and development, smoking during pregnancy may affect physical growth, mental development, and behavioral characteristics of children at least up to the age of 11.” (p. 1–21) | 1979
“Maternal smoking during pregnancy may adversely affect the child’s long-term growth, intellectual development, and behavioral characteristics.” (p. 11) | 1980
Low sperm quality
“The available information suggests that current smoking is related to low sperm density. However, these data are limited.” (p. 405) | 1990

Sources: U.S. Department of Health, Education, and Welfare 1964, 1969, 1971, 1973, 1978, 1979; U.S. Department of Health and Human Services 1980, 1989, 1990, 2001.

## Biologic Basis

The biologic basis of smoking and reproductive effects is complicated by how exposure is defined for reproductive effects, and is perhaps best discussed using a methodologic framework. When researchers examine the effects of smoking on reproductive outcomes, measuring exposure to smoking and adjusting for possible confounding are two important methodologic concerns. The critical exposure periods during gestation are brief for some adverse reproductive outcomes that have possible causal associations with active smoking. For example, when examining the relationship between smoking and congenital malformations, relevant data include exposure to tobacco smoke during the early part of pregnancy or during organogenesis. Similarly, for studying fetal growth restrictions, knowledge of smoking habits during the third trimester—the time when most of the growth in the fetus occurs—is of critical importance. However, in many studies the average amount smoked during pregnancy has been used as the exposure measure without collecting or reporting information sorted by the month of pregnancy or by the trimester.

For pregnancy outcomes, several potential confounding factors should be considered along with tobacco use, such as social class and racial and ethnic group. Among women of a lower social standing, not only are rates of smoking higher but rates of adverse pregnancy outcomes are also higher. Whereas lower social standing is thus a potential confounding variable, it may also be part of a common causal pathway serving as one of the determinants of exposure to smoking. Most recent studies do take potential confounders into account, and within the body of relevant literature, confounding has been adequately considered in the aggregate. However, for studies of some outcomes, such as those that examine associations of active smoking during pregnancy with child outcomes (i.e., physical, neurologic, and cognitive development), fully accounting for all potential confounders in the postpartum period is not feasible. The appropriateness of accounting for confounders will be discussed in each of the three sections that follow.

Another challenging issue that should be addressed is the mechanistic role of smoking in the causal pathway of adverse reproductive outcomes. For the role of smoking in preterm deliveries, for example, prenatal cigarette exposure might (1) increase the risk for pregnancy complications leading to a preterm delivery (e.g., the premature rupture of membranes), (2) decrease immune system functioning leading to an increased susceptibility to infections, or (3) act more directly through mechanisms not yet understood. Many studies do not capture data in a way that facilitates an adequate dissection of the underlying pathway. For example, few studies stratify analyses by the presence of pregnancy complications, and most such studies do not account for infections, as this purported risk factor for a preterm delivery has emerged only recently.

This methodologic challenge is further illustrated by SIDS, smoking during pregnancy, and the role of birth weight in the causal pathway. Because prenatal smoking results in lower birth weights and LBW is also a risk factor for SIDS, most studies account for birth weight, and some studies even limit the analyses to infants born weighing at least 2,500 g. It is unclear, however, that this analytic strategy is the most appropriate if the total contribution of smoking to the risk of SIDS is of interest. Only a few studies have examined the association between smoking and SIDS by stratifying the sample by birth weight.

Studies reviewed for this chapter were selected from a MEDLINE literature search from the mid-1960s to 2000, with some earlier studies identified through bibliographies. Title and abstract search terms included “smoking,” and outcomes of interest such as “pregnancy,” “fertility,” “pregnancy complications,” “birth weight,” “preterm delivery,” “cognitive development,” “congenital malformations,” “infant mortality,” and “SIDS.” For some searches (e.g., pregnancy complications), specific disorders were used as a search term (e.g., placenta previa). “Smoking” was also used as a Medical Subject Headings term, and review articles were consulted as additional sources for references.

As some of the topics presented in this chapter have been extensively investigated and the evidence found to support causality (e.g., smoking and birth weight), this chapter focuses on more recent studies and emerging areas such as male erectile dysfunction. When possible, recent studies were reviewed as the patterns of smoking among women of childbearing age and pregnant women have changed over the past few decades. In addition, the topic of smoking and cervical cancer is discussed in Chapter 2.

## Fertility

### Epidemiologic Evidence

#### Smoking and Sperm Quality

Cigarette smoking among men can affect spermatogenesis and sperm quality through hormonal and toxic influences. In a review of the literature on male reproduction and smoking, Vine (1996) noted that the cytotoxic effects of exposures to tobacco smoke may reduce the numbers and function of sperm, or may affect male reproductive hormone levels and lead to impairment of spermatogenesis. Although the results of studies supporting the latter mechanism are mixed, several studies have found that levels of testosterone, estradiol, estrone, androstenedione, and follicle-stimulating hormone are increased among smokers compared with nonsmokers (Barrett-Connor and Khaw 1987; Simon et al. 1992; Field et al. 1994; Vine 1996), while other studies have found decreases among smokers compared with nonsmokers or no differences between the two groups (Andersen et al. 1984; Barrett-Connor and Khaw 1987; Klaiber and Broverman 1988; Simon et al. 1992). Small sample sizes may partially explain the conflicting findings (Vine 1996) as larger studies tend to find increased levels of male reproductive hormones in smokers compared with nonsmokers (Simon et al. 1992; Field et al. 1994). Toxins found in tobacco smoke, such as cadmium, nicotine, lead, and radioactive alpha-particle emitting elements (internal emitters in particular), may be directly toxic as they circulate in the blood and reach the testes (Mattison 1982; Ravenholt 1982; Mattison et al. 1989; Oldereid et al. 1989).

In the following discussion, the studies examined associations between sperm production and male smoking and had larger sample sizes as well as some consideration of potential confounders. However, many of the studies on sperm quality included men seeking treatments for infertility, and the findings may have restricted generalizability. Also most do not adequately consider potential confounders such as abstinence, occupational exposures (e.g., teratogens and toxins in the workplace), or health behaviors (e.g., caffeine, alcohol, or drug use). Studies on smoking and sperm quality have examined measures such as ejaculate volume and sperm output, density, viability, motility, and morphology (Vogel et al. 1979; Evans et al. 1981; Godfrey 1981; Andersen et al. 1984; Handelsman et al. 1984; Kulikauskas et al. 1985; Dikshit et al. 1987; Saaranen et al. 1987; Marshburn et al. 1989; Oldereid et al. 1989; Close et al. 1990; Holzki et al. 1991; Lewin et al. 1991; Chia et al. 1994) (Table 5.2). Handelsman and colleagues (1984) studied 119 healthy volunteer sperm donors and examined a variety of physical, demographic, and health behavioral factors and sperm quality. Although it is not clear how the category of smokers was defined, when compared with nonsmokers this group had a significantly reduced total sperm output (316 million versus 181 million sperm), motility (72 million versus 67 million sperm), motile sperm (235 million versus 127 million sperm), and total oval sperm (251 million versus 120 million sperm). These values were unadjusted for other factors. Marshburn and colleagues (1989) studied 445 men and reported a significantly reduced sperm volume for smokers compared with nonsmokers but no differences in sperm density, sperm motility, or the presence of abnormalities or dead sperm. The authors, however, warned against the confounding effect of coffee drinking in this and other studies. Chia and colleagues (1994) studied 618 men receiving treatment for infertility and reported means for volume, density, motility, and morphology adjusted for age, medical history, occupational exposure to cigarette smoke, and testicular size. Current smokers had a lower sperm density, a lower proportion with normal morphology, and a higher proportion with head defects than nonsmokers (lifetime nonsmokers and former smokers). Most studies have not found dose-response relationships with the amount smoked, and a number of studies found no difference in sperm quality between smokers and non-smokers (Saaranen et al. 1987; Oldereid et al. 1989; Close et al. 1990; Holzki et al. 1991; Lewin et al. 1991). One large study found no differences between those exposed to tobacco smoke and chewing and those not exposed to tobacco smoke and chewing (Dikshit et al. 1987).

Table 5.2 Studies on the association between smoking and sperm quality

Study | Study period | Population | Definition of smoking | Key results
Vogel et al. 1979 | NR^*^ | 474 men | Smokers and nonsmokers (242 nonsmokers and 232 smokers) | - Smoking may be correlated with gonadal function and with particular central nervous system functions influenced by gonadal hormones; - Smokers had less gonadal hormone stimulation than nonsmokers; - Differences were observed only in smokers who started smoking at 15 years of age or younger (early smokers), compared with late smokers who were older than 15 years of age when they began
Evans et al. 1981 | NR | 86 men | Number of cigarettes/day (0, <15, ±20, ±25, >30) (43 smokers of ≥1 cigarette/day and 43 nonsmokers) | - An examination of morphologic abnormalities in sperm samples revealed that smokers had a significantly greater percentage of abnormal forms than nonsmokers; - There was no clear quantitative association between the degree of abnormality and the number of cigarettes smoked; - Sperm abnormalities in cigarette smokers may reflect genetic damage as a consequence of cigarette smoke
Godfrey 1981 | | 344 men | - Nonsmokers; - Smokers: <20 and ≥20 cigarettes/day | - Sperm morphology did not differ significantly among the three groups; - No differences in sperm motility; - No significant differences in sperm counts
Andersen et al. 1984 | 1977–1981 | 233 men and 250 women referred to an infertility clinic | Smokers: >10 cigarettes/day | - Male smokers had significantly higher serum testosterone levels and lower semen volumes, while luteinizing hormone, follicle stimulating hormone, and sperm density, motility, and morphology did not differ between smokers and nonsmokers; - Cigarette smoking may increase central dopaminergic tonus and reduce serum prolactin levels, but the biologic significance of this finding to reproductive functions is unknown
Handelsman et al. 1984 | NR | 119 healthy men presenting for screening as potential sperm donors | Smokers: Current and former | - Smoking was associated with a highly significant reduction in sperm output and motility; - Sperm density and output as well as the equivalent parameters for motile and morphologically normal sperm were lower in smokers than in nonsmokers; - Semen volume or the percentage of atypical forms did not differ between the two groups
Kulikauskas et al. 1985 | NR | 253 men aged 19–32 years | - Smokers: ≥4 cigarettes/day for at least the last 5 years; - Nonsmokers had never smoked or had not smoked for at least 5 years | - Spermatozoa from smokers possessed significantly decreased density and motility compared with nonsmokers; - Individual sperm counts indicated more than twice as many smokers as nonsmokers had a sperm density of <40 x 10^6^ sperm/mL, considered to be the lower limit of the normal range; - Morphologic abnormalities appeared to be more prevalent among smokers, but did not differ significantly
Barrett-Connor and Khaw 1987 | 1972–1974 1985–1986 | 590 men aged 30–79 years without a history of cardio-vascular disease | Never/former/current smokers were classified at time of interview:; - 176 never smokers; - 304 former smokers; - 110 current smokers (<10, 11–20, >20 cigarettes/day) | - Current cigarette smokers had significantly higher mean endogenous androstenedione, estrone, and estradiol levels compared with nonsmokers; - Among smokers, a dose-response relationship was apparent for these hormones, with mean levels increasing with increased cigarette use
Dikshit et al. 1987 | July 1985–September 1986 | 626 male partners aged 20–32 years of couples undergoing idiopathic infertility | - Nonusers: no tobacco use in any form; - Smokers: >10 cigarettes/day; - Tobacco chewers: >10 helpings/day; (288 nonusers, 219 smokers, and 119 tobacco chewers) | - Results failed to demonstrate a significant influence of tobacco use (smoking or chewing) on seminal parameters; - Although there was a reduction in volume, sperm density, and total count among tobacco users, the differences were statistically insignificant; - Tobacco use was not associated with impaired sperm quality in males selected from an idiopathically hypofertile population
Saaranen et al. 1987 | NR | 190 men of reproductive age with no previous history of infertility | - Nonsmokers; - Occasional smokers (1–15 cigarettes/day); - Regular smokers (≥ 16 cigarettes/day) | - Sperm output was normal in both smokers and nonsmokers, but semen volume was smaller in heavy smokers than in nonsmokers; - Percentage change in sperm motility during 24 hours was different in men with different smoking habits: initially, sperm motility was better in heavy smokers than in those who smoked <16 cigarettes/day; the motility decreased more rapidly for heavy smokers than for nonsmokers, and the rapid decrease in the survival spermatozoa in smokers may be harmful with respect to fertility
Dai et al. 1988 | 1980–1986 | - Longitudinal study, 121 men from the Multiple Risk Factor Intervention Trial (MRFIT); - Case-control study, 163 MRFIT men who developed coronary heart disease, and 163 matched controls | Smokers averaged 34 cigarettes/day | - Serum total and free testosterone concentrations were positively correlated with cigarette smoking among the longitudinal sample and controls but not for the baseline serum from the coronary heart disease cases; - There was no association between either serum estradiol or estrone concentrations and cigarette smoking in this population
Marshburn et al. 1989 | 1978–1982 | 445 men | None, <20 cigarettes/day, and ≥20 cigarettes/day | - Individuals who drank >4 cups of coffee/day and smoked ≥20 cigarettes/day had a lower proportion of motile spermatozoa and a higher proportion of dead cells compared with nonsmokers who did not drink coffee; - The effects of smoking on seminal volume, and of coffee drinking on sperm density, did not appear to be dose-dependent
Oldereid et al. 1989 | NR | 350 men aged 20–58 years under fertility investigation | - Moderate smokers: 1–14 cigarettes/day; - Heavy smokers: 15–40 cigarettes/day; (203 smokers, 147 nonsmokers) | - There were no significant differences in any aspect of sperm quality including DNA distribution among nonsmokers, moderate smokers, and heavy smokers; - Using conventional parameters, the study did not show that smoking has deleterious effects on sperm quality
Close et al. 1990 | NR | 164 men from infertile couples referred to a urologic fertility clinic | - Number of packs/day; - Nonsmokers included former smokers | - Current cigarette smokers, marijuana users, and heavy alcohol users showed greater numbers of leukocytes in the seminal fluid than did nonusers; - Cigarette smokers had lower sperm penetration assay scores than nonsmokers (median: 2.5 vs. 8.0, respectively); - Compared with nonusers of cigarettes, users of marijuana or alcohol showed no decrease in sperm counts or motility, or in the percentage of oval sperm
Holzki et al. 1991 | 1984–1987 | 90 men retrospectively selected from an infertility clinic | - Nonsmokers had never smoked; - Smokers: >10 cigarettes/day; (50 smokers, 40 nonsmokers) | - Smokers had sperm volumes significantly smaller than nonsmokers of the same age; - No additional effects on sperm parameters were found; - Cigarette smoking revealed no detrimental effect on spermatogenesis
Lewin et al. 1991 | November 1986–February 1988 | 675 men aged <45 years under infertility investigation | Smokers: >10 cigarettes/day (293 smokers, 382 nonsmokers) | - An overall reduction of sperm concentrations was seen in smokers compared with nonsmokers in relation to the effects of the number of cigarettes/day and number of pack-years (the number of years of smoking multiplied by the number of packs smoked per day) calculated to measure the cumulative effects of smoking; - No differences were observed in sperm motility and sperm penetration assay; - In men <45 years of age with sperm analyses showing motility >30%, concentration >10 x 10^6^/mL, and normal morphology, smoking was not detrimental to fertility
Chia et al. 1994 | January 1991–June 1992 | 618 men undergoing infertility screening | - Nonsmokers had never smoked a cigarette or had quit for more than a year; - Current smokers | - Smokers had a significantly poorer sperm density, a lower percentage of sperm with normal morphology, and a higher percentage of headpiece spermatozoa defects compared with nonsmokers; - Cigarette smoking appeared to affect sperm density and spermatozoa morphology, especially the headpiece; - A dose-response relationship between cigarette smoking and spermatogenesis is suggested based on calculated cigarette-years (the number of years of smoking multiplied by the number of cigarettes smoked per day): 0, 1–199, ≥200; - Sperm density (10^6^/mL) shows a decreasing trend as cigarette-years increase. Differences are significant (p <0.0001) even after using ANCOVA to adjust for medical history, occupational exposure, age, and testicular volumes

* NR = Data were not reported.

A meta-analysis of 20 different study populations conducted by Vine and colleagues (1994) found that sample size was a major contributor to apparent inconsistencies among the study findings. Overall, the weighted estimate of reduction in sperm density among smokers compared with nonsmokers was 13 percent (95 percent confidence interval [CI], 8.0–21.0) adjusted for population source, minimum number of cigarettes smoked by smokers, number of specimens analyzed, and whether laboratory staff were blinded to the status of the participants (Vine et al. 1994). This estimate is somewhat lower than that of an earlier review of 10 studies, which found a reduction in smokers compared with nonsmokers to be 22 percent.

In summary, studies on the association between smoking and sperm quality have produced conflicting findings. Many studies have small sample sizes comprised of men who may have problems with infertility unrelated to smoking. And despite comments about similarities between smokers and nonsmokers, few included adjustments for potential confounders such as sexual abstinence, occupational exposures, and health practices of participants (e.g., consumption of alcohol, caffeine, or drugs). Nonetheless, the evidence suggests that smokers may have decreased semen volume and sperm number and increased abnormal forms, although any clinical relevance of these findings is not clear.

#### Smoking and Fertility in Women

Numerous studies have shown that smoking results in reduced fertility and fecundity for couples with one or both partners who smoke (Table 5.3). Fertility might be reduced by active smoking through numerous mechanisms. Animal studies suggest that prenatal exposure to polycyclic aromatic hydrocarbons has a destructive effect on oocytes and may affect the release of gonadotropins, corpora lutea formation, gamete interaction, and implantation. Studies in rats and humans also have shown that postfertilization cleavage is delayed in smokers (Mattison et al. 1989; Hughes et al. 1992; Rowlands et al. 1992). In the rat, nicotine delays implantation of the fertilized ovum, but whether this delay affects fertility remains to be determined. Smoking also has been shown to affect menstrual function by shortening cycles and increasing anovulation, which may also contribute to subfecundity and infertility (Windham et al. 1999).

Table 5.3 Studies on the association between smoking and fertility in women

Study | Study period | Population | Definition of smoking | Key results
Tokuhata 1968 | NR^*^ | 2,016 women from a death registry | - Number of cigarettes smoked; - Tobacco habits data included chewing tobacco and using snuff | - Cigarette smokers had increased risks of infertility, reduced frequency of pregnancies, and an increased risk of fetal losses; - Risks of infertility and fetal losses were higher in those who developed breast and genitalia cancer, but were not further increased by smoking; - In contrast, the risks were lower in those with noncancerous diseases, but were elevated by smoking; - The husband’s smoking history was independent of the association between the wife’s smoking and reproductive histories
Baird and Wilcox 1985 | 1983 | 678 pregnant women who had stopped using birth control in order to get pregnant | - Smokers: ≥1 cigarette/day during at least the first month after stopping birth control; - Nonsmokers: all others | - Smokers were 3.4 times more likely to have taken more than a year to conceive compared with nonsmokers; - Fertility of smokers was estimated to be 72% of that for nonsmokers; - Heavy smokers experienced lower fertility rates than light smokers (57% and 75% of the pregnancy rate of nonsmokers, respectively); - Fertility was not affected by the husband’s smoking
Howe et al. 1985 | 1968–1974 | 17,032 white married women, aged 25–39 years, from the Oxford Family Planning Association contraceptive study | - Never smoked; - Former smokers; - Current smokers stratified by cigarettes/day (1–5, 6–10, 11–15, 16–20, ≥21) | - There was an inverse relationship between the age at stopping contraception and fertility, in both nulliparous and parous women, but the effect was greater in nulliparous women; - There was a dose-response relationship between smoking and decreased fertility: more cigarettes/day were associated with decreased relative fertility rates
Trapp et al. 1986 | 1984–1985 | 114 patients who underwent IVF^†^ | Smokers or nonsmokers | - There were no significant differences in IVF outcomes (fertilization and pregnancy rates) between smokers and nonsmokers; - The rhodanide (SCN) concentrations in serum and follicular fluid were higher in smokers than in non- smokers; - The influence of smoking on IVF is difficult to ascertain; IVF methods need to improve
de Mouzon et al. 1988 | 1977–1982 | 1,887 couples | - Nonsmokers did not smoke; - Smokers: ≥1 cigarette/day | - Cigarette smoking by both spouses was related to decreased fertility when considered independently, but the association did not remain significant when confounding variables were controlled; - The relationship between tobacco and subfertility is not clear, and if it exists, is very low; - The effects of tobacco on fertility found by different studies may be explained by behavioral factors related to tobacco use
Suonio et al. 1990 | 1983 | 2,198 mothers 20 weeks pregnant | - Nonsmokers; - Light smokers (1–4 cigarettes/day); - Heavy smokers (>4 cigarettes/day) | - A significant deleterious effect of smoking on fecundity was observed, which increased with longer delays in conception; - The OR^‡^ shifted from 1.1 at 6 months to 3.2 at 18 months for those who smoked 1–4 cigarettes/day; and from 1.6 to 2.0 for smokers of >4 cigarettes/day; - Among those who became successfully pregnant in 12 months, both maternal and paternal smoking increased the risk of conception delay (OR = 1.5 and 1.3, respectively), and the effect was potentiated by advancing age (OR = 2.3 and 1.6, respectively)
Elenbogen et al. 1991 | NR | 41 women aged <37 years suffering from mechanical infertility | - Nonsmokers; - Smokers: >15 cigarettes/day | - Follicular fluid levels of estradiol were significantly lower in smokers than in nonsmokers; - Fertilization rates were lower for smokers (40.9 vs. 61.7%); - Cigarette smoking had a detrimental effect on IVF and embryo transfer
Pattinson et al. 1991 | March 1984–March 1989 | 447 couples seeking IVF^†^ | Both partners were asked if they smoked and if so, how many cigarettes/day | - There were no significant differences between smokers and nonsmokers in peak estradiol levels, the number of eggs retrieved, or fertilization or implantation rates; - The incidence of spontaneous abortion was higher in smokers (42%) than in nonsmokers (19%); consequently, the delivery rate per IVF cycle was significantly lower in smokers (11 of 124, 9%) than nonsmokers (40 of 236, 17%); - There was no effect when only the husband was a smoker
Hughes et al. 1992 | March 1990–May 1991 | 222 couples undergoing consecutive IVF and embryo transfer | Women were classified as nonsmokers, smokers of 1–14 cigarettes/day, and smokers of ≥15 cigarettes/day | - There were no differences in ovarian stimulation, peak estradiol levels, or the number of oocytes retrieved; - Heavy smokers had higher fertilization rates than nonsmokers (79.3 vs. 61.3%); - The rate of embryo cleavage was retarded in a dose-dependent fashion: in smokers of 1–14 cigarettes/day, the likelihood of transferring an embryo at >4-cell stage was 0.87 (95% CI^§^, 0.56–1.4); and in smokers of ≥15 cigarettes/day, the likelihood was 0.52 (95% CI, 0.31–0.88); - No significant differences were noted in clinical outcomes following embryo transfer
Laurent et al. 1992 | December 1980–April 1983 | 2,714 randomly selected women aged 20–54 years; 483 had primary infertility and 2,231 served as controls | Smokers began smoking cigarettes before or during the period of unprotected intercourse (for the infertile cases) or before the first conception (for the controls) | - Smoking 1 pack/day (OR = 1.36) and starting to smoke (OR = 1.3) were significantly associated with increased infertility; - Smoking did not significantly increase the time required to conceive among infertile women; - Women should stop smoking when they are attempting to become pregnant
Rosevear et al. 1992 | 1989–1991 | 45 women with tubal and other complications of infertility | Smoking was determined by concentration levels of nicotine metabolite cotinine (less or more than 20 ng/mL) in ovarian follicular fluid | - Smoking (57%) is associated with reduced fertilization of eggs to about two-thirds of the normal rate for nonsmokers (75%); - The median fertilization rates for high vs. low cotinine groups were 57% and 75%, respectively; - Analysis of individual fertilization rates gave medians of 75% (range 0–100) for the cotinine-undetectable group, and 57% (0–100) for the cotinine-detectable group (p <0.05, Kruskal Wallis); - Women should be advised to stop or reduce smoking generally, especially before IVF
Rowlands et al. 1992 | NR | Couples who received IVF | Smoking histories for both partners were recorded | - There was a significant difference in fertilization rates among couples who were: nonsmokers, female only smokers, male only smokers, and both smokers; - Reduced numbers of mature oocytes and reduced preovulatory estradiol concentrations were seen in the partners of men who smoked, but the differences were not significant
Joffe and Li 1994 | 1958–1991 | 11,407 persons: 3,132 female and 2,576 male cohort members who had borne or fathered at least 1 live birth | Current smoking habits of the cohort member and partner, and the smoking habit of the cohort member for 12 months before conception of each ascertained pregnancy | - Both the time to pregnancy and clinical subfertility were associated with smoking habits and educational levels of both partners; - A multivariate analysis showed that paternal smoking failed to enter the model if educational variables were also included (p >0.05 did not meet the criteria for inclusion); - Maternal smoking affects fertility, but earlier reports of an apparent effect of paternal smoking may be due to confounding with socioeconomic status
Sharara et al. 1994 | January 1991–December 1992 | 210 women from a general infertile population with 102 undergoing IVF | - Nonsmokers had never smoked cigarettes; - Current cigarette smokers; - Former smokers not currently smoking were excluded | - Smokers had an increased incidence of diminished ovarian reserves (12.31%) compared with age-matched nonsmoking controls (4.83%); - Smokers with normal ovarian reserves had ovarian responses and pregnancy rates equivalent to nonsmoking controls; - A diminished ovarian reserve may be a principal mechanism reducing fecundity among women who smoke cigarettes
Alderete et al. 1995 | 1959–1966 | 1,341 women who were primigravidas | - Smokers: ≥1 cigarette/day after discontinuing contraception; - Nonsmokers: gravidas who had never smoked; - To assess dose responses, light = 1–9 cigarettes/day, moderate = 10–19, heavy = ≥20 | - Smokers had about one-half the fertility (OR = 0.5–0.6) of nonsmokers and noncoffee drinkers for times to conception of 6 and 12 months, regardless of whether they drank coffee; - Nonsmoking coffee drinkers did not have decreased fertility compared with nonsmokers who did not drink coffee (adjusted OR = 1.0–1.2); - Coffee drinking did not further increase the risk of delayed conception among smokers over the risk posed by smoking (OR = 0.6–0.8)
Bolumar et al. 1996 | August 1991–February 1993 | - Women aged 25–44 years randomly selected; the unit of analysis was the couple; - Women at least 20 weeks pregnant recruited during prenatal visits (unit of analysis was a pregnancy); - More than 4,000 couples in each sample | - Cigarettes/day (1–10, ≥11); - For male partners, dichotomous data on smoking (yes/ no) were available | - Female smoking was associated with subfecundity both with the first pregnancy (OR = 1.7) and during the most recent waiting time to pregnancy (OR = 1.6); - No significant association was found with male smoking
Sterzik et al. 1996 | NR | 197 women aged 23–39 years from an IVF^†^ program | - Nonsmokers: cotinine concentrations <20 ng/mL; - Passive smokersΔ: cotinine concentrations >20 ng/mL and <50 ng/mL; - Active smokers: cotinine concentrations >50 ng/mL; 68 nonsmokers, 26 passive smokers, 103 active smokers) | - There were no significant differences in fertilization and pregnancy rates among nonsmokers, passive smokers, and active smokers; - The serum estradiol levels were decreased significantly in women who smoked when compared with nonsmokers and passive smokers; decreased serum estradiol concentrations were not associated with adverse effects on fertilization and pregnancy rates in smokers; - There was no clinically detectable impairment of fertilization potential attributable to female smoking, and other factors have a greater influence on IVF outcomes
Van Voorhis et al. 1996 | January 1989–July 1994 | 499 women treated at an assisted reproductive techniques program | - Smoking was determined by asking if women ever smoked and if yes, number of pack-years (number of packs of cigarettes smoked per day multiplied by the number of years the woman smoked) was ascertained; - Nonsmokers (had never smoked); - Former smokers (had quit before their cycle); - Current (smoked during their assisted reproductive cycle) | - Current and former smokers had reduced gonadotropin-stimulated ovarian function compared with nonsmokers; - Increased tobacco exposures were associated with decreased serum estradiol concentrations, decreased number of retrieved oocytes, and fewer embryos obtained; - Women who smoked during their treatment cycle had a 50% reduction in implantation and ongoing pregnancy rates compared with never smokers; - Cigarette smoking was associated with prolonged and dose-dependent adverse effects on ovarian function
Curtis et al. 1997 | 1991–1992 | 2,607 planned pregnancies over the previous 30 years | - Nonsmokers did not smoke (former smokers who had quit smoking as of the year they started trying to conceive were treated as nonsmokers, except in analyses requiring former smokers to be examined separately); - Smoking was stratified by cigarettes/day (0, 1–5, 6–10, 11–20, >20) and pack-years (0, 0–5, >5–10, >10); - Data were also collected on ever smoked, current smoking habits, number of years smoked; and for those who quit, the year of cessation | - Cigarette smoking among women and men was associated with decreased fecundability (fecundability ratio 0.90 and 0.88, respectively); - Caffeine consumption among women was not associated with decreased fecundability, even in higher amounts; - Alcohol use among women and men was not associated with fecundability
El-Nemr et al. 1998 | 9-month period in 1995 | 173 women undergoing IVF^†^-embryo transfer cycle at a fertility center | - 108 nonsmokers, 65 smokers at the time of the interview; - Cigarettes/day | - Cigarette smoking in women appeared to significantly reduce their ovarian reserve and lead to poor responses to ovarian stimulation at an earlier age; - Women who smoked had a higher mean basal follicle stimulating hormone concentration and required a higher mean dosage of gonadotropins for ovarian stimulation than nonsmokers; - Compared with nonsmokers, smokers had a lower mean number of oocytes, and higher rates of abandoned cycles and total fertilization failure; - The difference in the clinical pregnancy rate per cycle, 16.9% for smokers vs. 21.3% for nonsmokers, was not statistically significant
Joesbury et al. 1998 | January 1994–December 1995 | 385 couples, 498 IVF treatment cycles | - Nonsmokers included never and former smokers; - Current smokers | - Male smoking interacted with age and was associated with a 2.4% decrease in the likelihood of achieving a 12-week pregnancy with every 1-year increase in age; - Ovarian reserves diminished with increasing age more significantly for female smokers than for nonsmokers; - The study failed to show that there was an elevated incidence of pregnancy loss among female smokers
Hull et al. 2000 | April 1991–December 1992 | 14,893 pregnant women | - Cigarettes/day; - Smokers were active, passive, or both | - Active smoking by women was significantly associated with failure to conceive at >6 months (OR = 1.23 [95% CI, 0.98–1.49]) and at >12 months (OR = 1.54 [95% CI, 1.19–2.01]) after adjusting for confounding factors; - Compared with women who did not smoke, female passive smokers had significantly delayed conception of >6 months (OR = 1.17 [95% CI, 1.02–1.37]) and >12 months (OR = 1.14 [95% CI, 0.92–1.42]), after adjusting for confounding factors; - Active smoking by the men was significantly associated with failure to conceive within 6 months, after adjusting for confounding factors including the women’s smoking. However, active smoking by men was not significantly associated with failure to conceive within 6 months; - Heavy smoking by men was independently associated with delayed conception, and delays lengthened with an increasing number of cigarettes smoked

* NR = Data were not reported.

† IVF = In vitro fertilization.

‡ OR = Odds ratio.

§ CI = Confidence interval.

Δ Exposed to someone else’s tobacco smoke.

The literature uses a number of different indicators to measure fertility and fecundity. Infertility in the United States is defined as the inability to conceive for 12 months; the World Health Organization uses failure to conceive for 24 months or more. Primary infertility refers to women who have not had prior pregnancies while secondary infertility concerns women who have been pregnant before. Unfortunately, the literature on smoking and fertility among women does not consistently employ these standard measures.

Laurent and colleagues (1992) studied primary infertility in 2,714 cases and controls. Primary infertility was associated with smoking more than one pack per day compared with nonsmokers (odds ratio [OR] = 1.36 [95 percent CI, 1.14–1.61]) and starting to smoke before 18 years of age compared with nonsmokers (OR = 1.30 [95 percent CI, 1.0–1.68]). These estimates were adjusted for education, age, race, and history of ovarian disease. Joffe and Li (1994) examined the time to first pregnancy among 3,132 women. After adjusting for age, education, and smoking status of the father in a Cox survival model, women who smoked before conception were less likely to become pregnant than nonsmokers; the risk ratio for time to pregnancy for women who smoked was 0.89 (95 percent CI, 0.83–0.97). Alderete and colleagues (1995) studied 1,341 primiparas and reported that women who smoked, regardless of whether they drank coffee, had about one-half the fertility (OR = 0.5 to 0.6 for conception times of 6 and 12 months) of nonsmokers who did not drink coffee.

As early as the 1960s, an association between smoking and decreased fertility was observed. In a sample of 2,016 women in Tennessee, women who smoked had a 46 percent higher rate of infertility than women who did not smoke (Tokuhata 1968). In a large prospective family planning study of more than 17,000 women, which included 6,199 episodes of contraceptive stoppage for the purpose of becoming pregnant, Howe and colleagues (1985) demonstrated a dose-response relationship between the amount of current smoking and reduced fertility that was based on pregnancy rates five years after terminating contraception. Women who smoked more than 20 cigarettes per day had their fertility reduced by 22 percent compared with lifetime nonsmokers and former smokers. Lighter smokers (<15 cigarettes per day) did not show demonstrable reductions in fertility. Although this study did not adjust for potential confounders, reduced fertility in smokers did not vary significantly by social class. Suonio and colleagues (1990) demonstrated a dose-response relationship between any current smoking and a delay to conception for short (6-month) and long (18-month) periods of time. In this sample of 2,198 mothers interviewed at 20 weeks of gestation, with adjustments for several confounders (age, prior pregnancies, prior terminations and spontaneous abortions, alcohol consumption, occupation of the mother, employment, smoking status and alcohol consumption of the father), the OR of conception delay for smokers (>four cigarettes per day) compared with nonsmokers at six months was 1.6. Conception delays continued for smokers (any smoking) compared with nonsmokers at 12 and 18 months after discontinuing contraception. Women who smoked more than four cigarettes per day had a 2.1 OR for conception delay at 18 months compared with nonsmokers. Dose-response relationships were demonstrated for lighter and heavier smokers for most outcomes (Suonio et al. 1990).

In a large multicountry study, Bolumar and colleagues (1996) examined the association between smoking and time to pregnancy that exceeded nine and one-half months in two large samples: (1) a population-based sample of women aged 25 through 44 years and (2) a sample of pregnant women recruited from prenatal clinics. Each sample had more than 4,000 couples. The OR was 1.7 (95 percent CI, 1.3–2.1) for a longer time to pregnancy for women smoking 11 or more cigarettes per day compared with nonsmokers in the population sample. For current pregnancy in the pregnant sample, the OR was also 1.7 (95 percent CI, 1.3–2.3), demonstrating a dose-response relationship for this outcome. Women who smoked 1–10 cigarettes per day had an OR of 1.4 in the population sample (95 percent CI, 1.1–1.7) and also in the pregnant sample (95 percent CI, 1.0–1.8). In the population-based sample, associations were also examined for the most recent pregnancies. For the most recent wait time, women who smoked 11 cigarettes or more per day compared with nonsmokers had an OR of 1.6 (95 percent CI, 1.3–2.1). ORs in this study were adjusted for age, coital frequency, education, oral contraceptive use, and coffee consumption (Bolumar et al. 1996). Curtis and colleagues (1997) reported a decreased fecundability (the monthly probability of conception), measured by time to pregnancy after discontinuing contraception, among smokers compared with nonsmokers. The fecundability ratio of smokers was 0.90 (95 percent CI, 0.81–0.95), and a dose-response relationship was observed for heavier smokers. Fecundability ratios for those smoking 11–20 cigarettes and more than 20 cigarettes per day were 0.87 (95 percent CI, 0.77–0.99) and 0.74 (95 percent CI, 0.59–0.92), respectively. Curtis and colleagues (1997) also reported associations with spousal smoking habits. Compared with both partners who were nonsmokers, when both the woman and her spouse smoked the fecundability ratio was 0.77 (0.68–0.86). In their study of 678 pregnant women, Baird and Wilcox (1985) reported that smokers had 3.4 times the risk of taking more than one year to conceive than nonsmokers, and heavy smokers showed an even greater reduced fertility than light smokers. In a review of 13 studies on this topic, Hughes and Brennan (1996) reported that all but one study found a reduced fecundity among smokers compared with nonsmokers.

Not all studies have reported positive associations between smoking and reduced fertility. A prospective study of fertility conducted by de Mouzon and colleagues (1988) with 1,887 couples found that reduced fertility associated with smoking was no longer statistically significant once possible confounders (method of birth control, attempting to conceive, oral contraceptive use as the most recent method, social class, prior deliveries, and year) were included in the analyses. Specifically comparing smokers with nonsmokers, cigarette smoking by the woman produced a 0.86 rate of relative fertility (95 percent CI, 0.63–1.19) and by the man a rate of 0.99 (95 percent CI, 0.85–1.14) after accounting for oral contraceptive methods, previous deliveries, social class, and prior attempts to conceive.

An increasing number of studies have used couples seeking treatment for infertility. These studies have consistently shown that treatment success is affected by smoking. Several studies documented that the success of in vitro fertilization (IVF) is significantly reduced among smokers compared with nonsmokers (Elenbogen et al. 1991; Pattinson et al. 1991; Hughes et al. 1992; Rosevear et al. 1992; Rowlands et al. 1992; Van Voorhis et al. 1996; El-Nemr et al. 1998), but other studies have not shown this reduction (Trapp et al. 1986; Sharara et al. 1994; Sterzik et al. 1996). Joesbury and colleagues (1998) examined the association of smoking by both partners with the likelihood of pregnancy within 498 consecutive IVF treatment cycles. Although female smoking had no association, male smoking was associated with a reduction in the probability of achieving a 12-week pregnancy. This study observed that age did modify the effect of smoking. For every one-year increase in age, there was a 2.4 percent reduction in the probability that the man’s partner would achieve a 12-week pregnancy (Joesbury et al. 1998). The authors suggest that pre-zygotic genetic damage is the mechanism causing these reductions in a successful pregnancy.

### Evidence Synthesis

Although mechanisms for an effect of smoking on sperm quality have been proposed, study findings are inconsistent for an association between active smoking and sperm quality. Some studies have shown positive associations, with a few demonstrating dose-response relationships with the amount smoked; others find no association. Many of the studies have potential flaws related to participant selection and confounding.

The evidence for a positive association between active smoking and subfertility and subfecundity in women consistently shows that active cigarette smoking reduces fecundity and increases the risk of primary infertility. The number of studies is substantial and various study designs and outcome measures have been used. Several studies demonstrated a dose-response relationship with the number of cigarettes smoked. Although the evidence is less consistent in studies examining the impact of smoking on the success of IVF, these studies may be limited by inadequate adjustment for fertility-related confounders. Moreover, animal and human studies are beginning to provide an understanding of the mechanisms by which cigarette smoke or its components affect fertilization in females, pointing to the plausibility of this association. The evidence reviewed shows consistency, dose-response relationships, and appropriate temporality, and partially characterizes the mechanistic basis. Based on the evidence through 2000, the 2001 Surgeon General’s report concluded that “women who smoke have increased risks for conception delay and for primary and secondary infertility” (USDHHS 2001, p. 307).

### Conclusions

1. The evidence is inadequate to infer the presence or absence of a causal relationship between active smoking and sperm quality.
2. The evidence is sufficient to infer a causal relationship between smoking and reduced fertility in women.

### Implications

Regarding smoking and sperm quality, future studies should also include more samples of men not seeking treatment for infertility, larger study populations, and the information to adjust for potential confounding factors such as occupational exposures (e.g., teratogens and toxins in the workplace) and health behaviors (e.g., caffeine, alcohol, or drug use). Women intending to become pregnant should be warned that their smoking reduces fertility; health care workers should be aware of the causal association of smoking by women with reduced fertility.

## Pregnancy and Pregnancy Outcomes

### Epidemiologic Evidence

#### Smoking Patterns Among Women During Childbearing Years

National data for the United States indicate that somewhere between 13 percent (National Center for Health Statistics, reported in Guyer et al. 1999) and 17 percent (Substance Abuse and Mental Health Services Administration 2001) of pregnant women smoke. For 1998, the 2001 Surgeon General’s report gives a figure of 12.9 percent based on birth certificate data (USDHHS 2001). The prevalence of pregnant women who smoked in 2001 was 12 percent, and the prevalence of teenage mothers aged 15 through 19 years who smoked during pregnancy was 17.5 percent in 2001 (Martin et al. 2002). The proportion of women who smoke during pregnancy has declined over the last 10 years; in 1990, 18 percent of women reported prenatal smoking (Guyer et al. 2000). At the same time, smoking among teenage mothers was increasing. In 1994, 16.7 percent of teenage mothers smoked during pregnancy, rising to 17.5 percent in 2001 (Martin et al. 2002). Since somewhere between 18 and 25 percent of women quit smoking once they become pregnant, the proportion of women who smoke around the time of pregnancy is greater than these numbers suggest (Lumley 1987; O’Campo et al. 1995).

Most information on smoking during pregnancy, including that obtained for studies on reproductive effects, comes from self-reports by the pregnant woman. In the United States, smoking during pregnancy is now widely viewed as unacceptable— that is, women are considered responsible for exposing the fetus to tobacco metabolites, and a number of researchers have noted that underreporting of smoking during pregnancy is common. High rates of underreporting have been reported in intervention trials. In a randomized trial from public health maternity clinics, Windsor and colleagues (1993) found a deception rate of 28 percent for self-reports provided at the end of pregnancy using salivary cotinine as a comparison. Underreporting can be a result of the social stigma associated with smoking or the typical change in patterns of smoking during pregnancy. Most women who smoke before pregnancy either quit or reduce their levels of smoking during pregnancy (O’Campo et al. 1995). Thus, if women reduce smoking levels as the pregnancy progresses, they may report the lowest smoking level rather than the greatest, or an average level over the course of their pregnancy. This underreporting, however, is likely to move any positive associations toward a null relationship as this type of misclassification will result in classifying heavy smokers as light smokers and classifying some true smokers as nonsmokers. Researchers have tried to address this problem by incorporating biochemical measures of tobacco exposure into their studies. Three studies showed that cotinine levels in blood collected along with self-reports during the prenatal period were more highly correlated with birth weight than were self-reported smoking levels (Haddow et al. 1987; English et al. 1994; Peacock et al. 1998).

#### Smoking and Ectopic Pregnancy

Ectopic pregnancy, a rare yet serious complication, occurs when implantation of the fertilized ovum takes place outside of the uterus, often in the fallopian tubes. The etiology of ectopic pregnancy is not fully known but involves the motility and patency of the fallopian tubes. Exposure to nicotine in rhesus monkeys has been shown to decrease tubal motility. Reduced motility may result in the fertilized ovum remaining in the tubes for a longer time which, in turn, may increase the chance of tubal implantation and ectopic pregnancy (Mattison et al. 1989). Cigarette smoking also has been associated with pelvic inflammatory disease, a strong risk factor for tubal pregnancy (Marchbanks et al. 1990). It is unclear whether this association is due to confounding factors such as more sex partners among smokers compared with nonsmokers, or to a direct biologic effect through suppressed immune function in smokers (Holt 1987).

Several studies report an increased risk of ectopic pregnancy among active smokers (Matsunaga and Shiota 1980; Handler et al. 1989; Coste et al. 1991; Kalandidi et al. 1991; Stergachis et al. 1991; Tuomivaara and Ronnberg 1991) (Table 5.4). ORs for active smokers compared with nonsmokers in these studies ranged from 1.3 to 2.5. Dose-response relationships have been reported in some studies (Handler et al. 1989; Coste et al. 1991) but not others (Phillips et al. 1992). Confounding is a potential source of bias when examining maternal smoking and ectopic pregnancy, although most studies adjusted for some potential confounders (e.g., prior problems relating to fertility involving the fallopian tubes or prior infections). The association with smoking does not appear to represent confounding alone.

Table 5.4 Studies on the association between maternal smoking and ectopic pregnancy

Study | Study period | Population | Definition of smoking | Key results
Matsunaga and Shiota 1980 | January 1962– December 1974 | 3,614 human embryos derived from artificial termination of pregnancy | Data were not reported | - A number of maternal characteristics including smoking and drinking were significantly associated with either ectopic or myomatous pregnancy; - Ectopic pregnancy was significantly associated with lowered parity, previous ectopic pregnancy, and maternal smoking and drinking
Daling et al. 1987 | 1979–1981 | 340 women: 170 with primary infertility and170 matched controls | Smoking history included number of cigarettes/day, age at smoking initiation, and age at cessation if they had quit | - Among current smokers, women who had more than 5 pack-years^*^ of exposure had 4.2 (95% CI^†^, 1.8–10.2) times the risk of tubal infertility^‡^ than women who had never smoked; - Among women who used both an intrauterine device and smoked, the RR^§^ for tubal infertility was 6.7(95% CI, 1.4–32.2); - There is a possibility that both smoking and tubal infertility are related to factors not addressed in the study, such as exposure to sexually transmitted infections that can cause tubal damage
Handler et al. 1989 | 1983–1987 | 4,921 women: 634 with ectopic pregnancy, and 4,287 controls who delivered a single live- born infant | - Maternal smoking was recorded as a dichotomous variable (yes/no), and as a continuous variable (number of cigarettes/day); - Four levels of smoking were considered: <10 cigarettes/day, 10–19, 20–29, and ≥30 | - Women who reported smoking during pregnancy had a greater than twofold risk of ectopic pregnancy(ORΔ = 2.5 [95% CI, 1.9–3.2]) compared with women who had never smoked; - The estimated RR rose from 1.4 (95% CI, 0.8–2.5) for a woman smoking <10 cigarettes/day to 5.0 (95% CI, 2.9–8.7) at ≥30 cigarettes/day; - The dose-response relationship supports the argument that smoking may be a causal factor in ectopic pregnancy
Coste et al. 1991 | During 1998 | Women aged 15–44 years attending maternity hospitals | Smokers were classified by the number of cigarettes/day at the time of conception | - Maternal cigarette smoking was associated with an increased risk of ectopic pregnancy (OR = 1.3–2.49); - The partner’s smoking was not associated with ectopic pregnancy
Kalandidi et al. 1991 | 1986–1987 | 203 women: 70 with ectopic pregnancy and133 controls | Never, former, and current smokers | - Tobacco smoking significantly increased the risk of an ectopic pregnancy, RR = 2.35 (95% CI, 1.19–4.67)
Stergachis et al. 1991 | October 1981– September1986 | 1,001 women: 274 who were hospitalized for tubal pregnancy and 727 controls | - Never smoked cigarettes; - Ever smoked; - Current and former smokers | - The RR of tubal pregnancy associated with ever having smoked cigarettes was 1.3 (95% CI, 1.0–1.8); - Those who smoked at the time of conception had a 40% increase in the risk of tubal pregnancy compared with never smokers (95% CI, 1.0–2.0); - Results support earlier reports of a greater risk of tubal pregnancy associated with current or recent maternal smoking
Tuomivaara and Ronnberg1991 | 1977–1981 | 929 infertile couples examined and treated for complications | Smoking or not smoking | - Previous ectopic pregnancy, an industrial occupation, and smoking reduced fecundity and increasedthe risk of ectopic pregnancy; - The strongest risk of ectopic pregnancy was associated with a previous tubal pregnancy (9.9-fold risk); - Although current smokers had an increased risk of infertility and ectopic pregnancy, smoking was not a significant indicator in the stepwise logistic analysis, so it could be of secondary importance
Phillips et al. 1992 | July 1986– April 1987 | 170 pregnant women: 69 with tubal ectopic pregnancy and 101 controls | - Current smokers (number of cigarettes/day smoked during the month of conception, and the total number of years of smoking); - Not currently smoking; - Former smokers (smoked before the month of conception) | - When current smokers were compared with never smokers and former smokers, the adjusted OR forsmoking associated with ectopic pregnancy was 2.4 (95% CI, 1.2–5.1); - Cigarette smoking may be associated independently with ectopic pregnancy, and smoking cessation before the month of conception may reduce this risk

* Pack years = The number of years of smoking multiplied by the number of packs of cigarettes smoked per day.

† CI = Confidence interval.

‡ Primary infertility due to tubal conditions. The focus of this study is on women with primary infertility (those who have never conceived despite unprotected intercourse for at least one year), diagnosed by the patient’s physician and attributed to a tubal condition on the basis of an abnormal hysterosalpingogram or a tubal abnormality identified during surgery.

§ RR = Relative risk.

Δ OR = Odds ratio.

#### Smoking and Spontaneous Abortion

Fetal loss or spontaneous abortion is defined as the involuntary termination of an intrauterine pregnancy before 20 weeks of gestation; some studies define spontaneous abortion as occurring before 28 weeks. Spontaneous abortions are extremely difficult to study, as most early fetal losses are underreported and unrecognized. As many as 50 percent of all pregnancies end in miscarriage, and 20 to 40 percent of all pregnancy losses may occur too early to be recognized or confirmed (Wilcox et al. 1988; Eskenazi et al. 1995a). Furthermore, the etiology of spontaneous abortions is multifactorial and not fully understood. Some early miscarriages result from chromosomal abnormalities in the developing embryo; others are related to factors associated with maternal age, the pregnancy, or exposures (e.g., occupational, alcohol consumption, or fever). There is evidence that smoking has a role in promoting spontaneous abortions, and various mechanisms have been proposed. Exposure to nicotine in sea urchins prevents the cortical granule reaction, which eliminates the entry of additional sperm into the egg. If this same process operates in humans, it may be a mechanism by which abnormalities in the developing embryo result in spontaneous abortions (Longo and Anderson 1970; Mattison et al. 1989). Several tobacco components and metabolites are potentially toxic to the developing fetus, including lead, nicotine, cotinine, cyanide, cadmium, carbon monoxide, and polycyclic aromatic hydrocarbons (Lambers and Clark 1996; Werler 1997).

Several studies have reported an increased risk of spontaneous abortion among smokers compared with nonsmokers; the reported ORs range from 1.2 to 3.4 (Kline et al. 1977; Stein et al. 1981; Armstrong et al. 1992; Dominguez-Rojas et al. 1994) (Table 5.5). Various potential confounding factors have been considered in these studies (USDHHS 2001). Dose-response relationships also have been reported (Stein et al. 1981; Armstrong et al. 1992). Armstrong and colleagues (1992) examined three strata of cigarette smoking and compared rates of early fetal loss among smokers and nonsmokers. ORs and CIs for spontaneous abortions for women smoking 1 to 9, 10 to 19, and 20 or more cigarettes compared with nonsmokers were 1.07 (95 percent CI, 0.97–1.18), 1.22 (95 percent CI, 1.13–1.32), and 1.68 (95 percent CI, 1.57–1.79), respectively. Most studies of smoking have not provided an opportunity to explore the basis for a spontaneous abortion. In a study of 2,305 karyotyped cases of miscarriage that separated chromosomally normal from abnormal fetuses, Kline and colleagues (1995) found a higher risk of aborting a chromosomally normal fetus among heavier smokers (>14 cigarettes per day) compared with nonsmokers (OR = 1.3 [95 percent CI, 1.1–1.7]). Data from a study of women undergoing IVF indicate that smokers have a higher rate of spontaneous abortions compared with nonsmokers, 42 percent versus 19 percent, respectively (Pattinson et al. 1991).

Table 5.5 Studies on the association between maternal smoking and spontaneous abortion

Study | Study period | Population | Definition of smoking | Key results
Kline et al. 1977 | April 1974– August 1976 | 894 women aged 18–40 years, who were admitted to public services for spontaneous abortions(574 cases and 320 controls) | - Nonsmokers did not smoke during pregnancy; - Smokers smoked during pregnancy (0–19 cigarettes/day or ≥20 cigarettes/day) | - Women who had aborted spontaneously reported smoking during pregnancy more often (OR^*^ = 1.8) thanthose who delivered after 28 weeks of gestation; - Findings suggest that the association between spontaneous abortion and smoking status is lower in women with a history of two or more spontaneous abortions than in women without previous multiple abortions; - This trend should be confirmed through independent data before making interpretations
Stein et al. 1981 | 6 years | 4,088 women: 2,748 with spontaneous abortion, and 1,340 controls who carried their pregnancies to 28 weeks or more | - Never smokers; - Current smokers; - Former smokers | - There was a dose-response relationship between an increased risk of spontaneous abortion and the number of cigarettes/day; - The OR of spontaneous abortion increased by 46% for the first 10 cigarettes smoked and 61% for the first20 cigarettes smoked; - The OR of spontaneous abortion for a woman who smoked 1 pack/day and who drank alcohol daily was 4.08 times more than for an abstinent nonsmoker; - Findings suggest that smoking during pregnancy but not before conception is associated with spontaneous abortion
Sandahl 1989 | Data were not reported | 2,747 pregnant women who consulted a hospital: 610 with spontaneous abortion, 800 with induced abortion, and 1,337 deliveries | Two different definitions of smoking: (1) smokers and nonsmokers, (2) smoked>10 cigarettes/day, and nonsmokers | - There was no significant effect of smoking on miscarriage; the only trend was that smokers had a slightlyreduced OR for miscarriage; - In late miscarriages (week 20 or later), there is a tendency for an OR above 1, but this finding is based on a small number of pregnancies and is not statistically significant
Armstrong et al. 1992 | 1982–1984 | 56,000 women who had a delivery or a spontaneous abortion in a hospital | Number of cigarettes/day | - The OR for spontaneous abortion increased by a factor of 1.2 for each 10 cigarettes/day; - Alcohol consumption was also associated with an elevated risk for spontaneous abortion; the OR increasedby a factor of 1.26 for each drink/day; - The association between coffee consumption and spontaneous abortion was weaker but statistically significant; the OR increased by a factor of 1.1 for each cup/day
Dominguez- Rojas et al. 1994 | January 1989– June 1991 | 711 female hospital workers aged 20–41 years | - Nonsmokers; - Smokers: 1–10 cigarettes/day and >10 cigarettes/day | - Tobacco and caffeine were clear risk factors for spontaneous abortion; - There was a dose-response relationship between maternal smoking and spontaneous abortion: the adjusted OR for ≥11 cigarettes/day was 3.35 (95% confidence interval, 1.65–6.92)
Kline et al. 1995 | 1974–1986 | 6,609 women: 2,376 with spontaneous abortion and 4,233 controls | - Never smoked; - Former smokers; - Current smokers (1–13 cigarettes/day); - Current smokers (≥14 cigarettes/day) | - Cigarette smoking during pregnancy was associated with chromosomally normal spontaneous abortions; - Both former and current smoking were associated inversely with trisomic loss in women under 30 years of age and positively in older women

* OR = Odds ratio.

Some studies have found no association between smoking and spontaneous abortions (Sandahl 1989). In a review of 13 U.S. and European studies, DiFranza and Lew (1995) reported fairly consistent findings across studies despite differences in design, sample selection, and adjustments for confounding. Pooled relative risks (RRs) and ORs were 1.2 (95 percent CI, 1.19–1.3) for cohort studies and 1.32 (95 percent CI, 1.18–1.48) for case-control studies for smokers compared with nonsmokers.

#### Smoking and Pregnancy Complications

##### Placenta Previa

Placenta previa occurs when the maturing placenta is close to the cervical os or completely obstructs the os. The etiology of placenta previa is still largely unknown. Some researchers claim that placental enlargement among smokers increases the chance that the placenta implants near or at the cervical os. However, others have found that placentas in smokers and nonsmokers are similar in size, so differences in placental size may be due to factors other than smoking (Zhang and Fried 1992). Zhang and Fried (1992) also note that a detection bias may lead to the greater ascertainment of placenta previa among smokers and will consequently inflate this association in many studies.

Placenta previa consistently has been found to be more frequent in smokers compared with nonsmokers; ORs range from 1.3 to 4.4 with most estimates around 2.3 (Kramer et al. 1991; Williams et al. 1991b; Zhang and Fried 1992; Handler et al. 1994; Chelmow et al. 1996) (Table 5.6). A few studies have examined dose-response associations based on the number of cigarettes smoked per day; one reported a significant dose-dependent relationship (Monica and Lilja 1995) while others were only suggestive (Handler et al. 1994; Chelmow et al. 1996). Most recent studies adjusted for potential confounders including age, parity, prior caesarean sections, and prior pregnancy terminations.

Table 5.6 Studies on the association between maternal smoking and placenta previa

Study | Study period | Population | Definition of smoking | Key results
Kramer et al. 1991 | 1984–1987 | 3,020 singleton births: 598 with placenta previa and 2,422 controls | - Smokers: mothers who smoked at any time during pregnancy; - Nonsmokers: mothers who did not smoke at any time during pregnancy | - Maternal smoking approximately doubled the risk of placenta previa after adjusting for maternal age(OR^*^ = 2.1 [95% CI^†^, 1.7–2.5]); - The association between maternal smoking and placenta previa did not alter when other confounding variables were adjusted for including marital status, parity, gravidity, previous cesarean section, and both previous spontaneous abortions and elective abortions
Williams et al. 1991b | August 1977– March 1980 | 12,420 mothers: 69 with placenta previa and12,351 controls | - Smokers ever smoked duringfirst or second trimester; - Three levels of cigarette smoking: nonsmokers, smokers of 1–9 cigarettes/day, and smokers of ≥10 cigarettes/day; - Three levels of smoking duration: never smokers, smokers for 1–5 years, and smokers for ≥6 years | - Women who smoked during the first two trimesters of pregnancy had a 90% increase in risk for placentaprevia (OR = 1.9 [95% CI, 1.2–3.0]) than women who did not smoke during pregnancy; - Compared with never smokers, women who smoked throughout pregnancy had a threefold increase in risk for placenta previa (OR = 3.1 [95% CI, 1.2–8.1]); - The duration of smoking was not an independent risk factor for placenta previa when smoking during pregnancy was considered
Zhang and Fried 1992 | 1988–1989 | 4,646 women from birth certificate data from 1 state: 766 women with placenta previa and3,880 controls | - Smoking during pregnancy; - Average number of cigarettes/day | - Although maternal smoking during pregnancy might affect placenta previa, the magnitude was substantially smaller than previously reported; - After potential confounders such as maternal age, race, gravidity, parity, and previous pregnancy terminations were controlled for, the OR was 1.29 (95% CI, 1.05–1.58) with slight dose-response gradients
Handler et al. 1994 | 1988–1990 | 3,036 women: 304 with placenta previa and2,732 controls | - Maternal smoking was recorded as a dichotomous variable (yes/no), and as a continuous variable (number of cigarettes/day); - Women who had quit smoking were included in the “smoking yes” category | - A dose-response relationship between smoking cigarettes and placenta previa was observed independently of other known risk factors; - Pregnant women who smoked >20 cigarettes/day were more than two times more likely to experience placenta previa compared with nonsmokers (OR = 2.3 [95% CI, 1.5–3.5]); - Pregnant women who used cocaine were 1.4 times (95% CI, 0.8–2.4) as likely to experience placenta previa as nonusers
Monica and Lilja 1995 | 1973–1990 | 1,825,998 infants from a birth registry | Women were classified by cigarette smoking during pregnancy as nonsmokers, smokers of <10 cigarettes/day, and smokers of ≥10 cigarettes/day | - Maternal smoking was an independent risk factor for placenta previa. The OR for placenta previa andmaternal smoking compared with women without placenta previa was 1.53 (95% CI, 1.4–1.67) for allsmokers; - The effect of smoking on the risk of having placenta previa increased with increasing parity but did not differ in the maternal age groups; - A dose-response relationship between the number of cigarettes/day during pregnancy and the risk of placenta previa was indicated
Chelmow et al. 1996 | July 1992– March 1994 | 128 pregnant women: 32 with placenta previa and 96 controls | - Never, former, and present smokers; - Light smokers: <1 pack/day; - Heavy smokers: ≥1 pack/day | - Current cigarette smoking was associated with a 2.6- to 4.4-fold increased risk of placenta previa; - A dose-response relationship was suggested: compared with never smokers, the OR for light smokers was 2.2 (95% CI, 0.87–7.83) and for heavy smokers 4.0 (95% CI, 0.69–93.1)

* OR = Odds ratio.

† CI = Confidence interval.

##### Placental Abruption

A placental abruption occurs when the normally implanted placenta prematurely separates from the wall of the uterus, and it is associated with high rates of preterm deliveries, stillbirths, and early infant deaths. The etiology of this rare pregnancy complication is not fully known, but risk factors are trauma, multiple births, uterine tumors, advanced maternal age, hypertensive disorders, history of uterine scarring, and prior history of placental abruption (Ananth et al. 1996). Active smoking during pregnancy results in decreased intervillous placental blood flow (Lambers and Clark 1996). Smoking has been proposed as a link to placental abruptions through vasoconstriction and underperfusion around the site of placental implantation, leading to necrosis and hemorrhage (Lehtovirta and Forss 1978).

Most studies have found an increased risk of placental abruption associated with active smoking during pregnancy (Voigt et al. 1990; Williams et al. 1991a; Raymond and Mills 1993; Spinillo et al. 1994a) (Table 5.7). Studies have reported adjusted ORs ranging from 1.4 to 2.4; some report a dose-response relationship, with risks increasing for heavy smokers compared with light smokers (Ananth et al. 1996).

Table 5.7 Studies on the association between maternal smoking and placental abruption

Study | Study period | Population | Definition of smoking | Key results
Lehtovirta and Forss 1978 | NR^*^ | 12 healthy women aged19–31 years, 35–40 weeks pregnant | All participants had smoked cigarettes before but not during pregnancy | - Smoking caused an acute reduction in intervillous blood flow of the human placenta in near-termpregnancy; - Repeated decreases in intervillous blood flow could explain growth retardation of the fetus and other pregnancy-related complications in women who smoke; - A possible effect of nicotine was also seen in accelerated heart rate and elevated blood pressure during smoking
Voigt et al. 1990 | 1984–1986 | 3,412 singleton births: 1,089 with abruptio placentae and2,323 controls | Smokers smoked at any time during pregnancy | - Smoking was associated with placental abruption (RR^†^ = 1.6 [95% CI^‡^, 1.3–1.8]); - The association with small for gestational age (SGA) status was identical for smokers and nonsmokers; - The increase in SGA infants among women whose pregnancies were complicated by abruption was not explained by maternal smoking
Williams et al. 1991a | 1977–1980 | 1,400 women: 143 with abruptio placentae and1,257 controls | NR | - Lifestyle factors associated with abruptio placentae in univariate analyses include maternal cigarettesmoking, marijuana use, and alcohol consumption during pregnancy; - Although the association of cigarette smoking during pregnancy was of borderline significance(OR^§^ = 1.5 [95% CI, 1.0–2.2]), the risk of abruption rose with increased levels of smoking
Raymond and Mills 1993 | 1974–1977 | 30,681 singleton pregnancies at ≥28 weeks of gestation | - Smokers or nonsmokers unless otherwise noted; - Categorized by packs/day (0, <0.5, 1, ≥1.5); - Heavy smokers (≥1 pack/day) | - Each pack of cigarettes smoked/day increased the risk of placental abruption by 40% (OR = 1.39[95% CI, 1.09–1.79]); - If abruption occurred, the perinatal mortality rate was substantially higher in offspring of women who smoked ≥1 pack/day than in offspring of nonsmokers (RR = 2.53 [95% CI, 1.14–5.61]); - Heavier smoking increased the risk of both abruption and perinatal death
Spinillo et al. 1994a | 1985–1991 | 781 women: 55 with abruptio placentae, and 726 controls who delivered between 24 and 36 weeks of gestation | - Nonsmokers; - Former; - <10 cigarettes/day; - ≥10 cigarettes/day | - Abruptio placentae was associated with a low number of antenatal visits, smoking during pregnancy, hypertension, intravenous drug abuse, and a history of recent abdominal trauma; - Since abruption is highly associated with low gestational age, and smoking is a primary risk factor for preterm delivery, the increased rate of preterm deliveries among smokers may in part account for the correlation between smoking and abruptio placentae
Ananth et al. 1996 | January 1986– December1992 | 61,667 women seeking antenatal care from hospitals | Smokers had smoked during pregnancy | - Smokers had a RR of 2.05 for abruption and 1.36 for placenta previa compared with nonsmokers(RR = 1.0); - Cigarette smoking was not associated with uterine bleeding of unknown etiology

* NR = Data were not reported.

† RR = Relative risk.

‡ CI = Confidence interval.

§ OR = Odds ratio.

##### Preeclampsia and Eclampsia

Preeclampsia is a hypertensive disorder developed during pregnancy with proteinuria and edema. The more severe form, eclampsia, includes one or more seizures and/or coma. Preeclampsia is a severe disorder in pregnancy that is associated with maternal mortality, intrauterine growth retardation (IUGR), and preterm birth. Smoking has been negatively associated with hypertensive disorders during pregnancy, although the underlying mechanism is uncertain (Salafia and Sheverick 1999).

Studies on smoking during pregnancy consistently find reduced rates of preeclampsia among smokers compared with nonsmokers (Marcoux et al. 1989; Eskenazi et al. 1991; Klonoff-Cohen et al. 1993; Spinillo et al. 1994b; Sibai et al. 1995; Cnattingius et al. 1997) (Table 5.8). ORs for smokers range from 0.45 to 0.71. Some studies have reported a dose-response relationship, with the lowest rates of preeclampsia among heavier smokers compared with light smokers and nonsmokers (Marcoux et al. 1989).

Table 5.8 Studies on the association between maternal smoking and preeclampsia

Study | Study period | Population | Definition of smoking | Key results
Marcoux et al. 1989 | 1984–1986 | 928 women: 172 with preeclampsia, 251 with gestational hypertension, and 505 controls | - Never smokers had never smoked; - Former smokers stopped smoking at any time before pregnancy; - Smokers smoked ≥1 cigarette/day at the beginning of the pregnancy | - Compared with women who had never smoked, women who were smokers at the onset of pregnancy hada reduced risk of preeclampsia (RR^*^ = 0.51 [95% CI^†^, 0.34–0.77]); - The protective effect of smoking on preeclampsia was stronger for women who continued to smoke after20 weeks of pregnancy; - While smoking tended to reduce the risk of gestational hypertension, the effect was less evident than that of preeclampsia
Eskenazi et al. 1991 | 1984–1985 | 271 pregnant women: 139 women with preeclampsia and 132 controls with no hypertensive pregnancy disorder | Smoking habits were classified as yes/no | - Smoking had a protective effect on preeclampsia (adjusted OR^‡^ = 0.45 [95% CI, 0.18–1.1]) in both multi-parous and nulliparous women; - High body mass, working during pregnancy, and a family history of hypertension were significant risk factors for preeclampsia
Klonoff- Cohen et al. 1993 | January 1984– December1986 | 225 women aged 15–35 years: 110 nulliparous women with preeclampsia and 115 healthy nulliparous women | Smoking was determined by(1) lifetime smoking history(ever smoked/never smoked); and (2) smoking during pregnancy (smoked/did not smoke) | - Smoking during pregnancy was not associated with preeclampsia (OR = 0.71 [95% CI, 0.33–1.5]) afteradjusting for confounding variables; - There was no evidence of a dose-response relationship with a reduced risk for heavy smokers (nonsmokers= 0 packs/day, light smokers = <1/2 pack/day, heavy smokers = >1/2 pack/day); - To identify dose-response relationships, smokers were divided into the following categories: 0 packs, <1/2pack/day, and ≥1/2 pack/day; adjusted ORs = 0.65 (95% CI, 0.27–1.55) for light smokers and 0.88 (95% CI, 0.23–3.28) for heavy smokers, compared with nonsmokers; these ORs reflect a slight inverse trend where heavy smokers had a lower reduction in risk than light smokers
Spinillo et al. 1994b | 1990–1992 | 585 pregnant women who had prenatal care and delivered at a hospital | - Never smoked; - Smoked <10 cigarettes/day; - Smoked ≥10 cigarettes/day | - Smoking during pregnancy was a significant protective factor against the occurrence of preeclampsia(adjusted OR = 0.5 [95% CI, 0.28–0.8]); - A history of preeclampsia in previous pregnancies, low educational level, a body mass index >24, andmaternal blood group AB were factors independently associated with increased risks of preeclampsia; - The study confirms that smoking during pregnancy reduces the risk of preeclampsia; however, the harmful consequences of smoking on pregnancy outcomes far outweigh this risk reduction
Sibai et al. 1995 | Data were not reported. | 2,947 healthy women with a single fetus | - Never smoked or had not smoked for >1 year; - Quit at the start of pregnancy; - Continued smoking | - There was a significant inverse relationship between cigarette smoking and preeclampsia when smoking history was dichotomized between current or recent smokers, and those who had never smoked or had quit at least a year earlier; - Findings indicate that cigarette smoking during pregnancy is associated with a reduced incidence of preeclampsia; - The highest incidence of preeclampsia was among women who had never smoked (5.9%), and the lowest incidence was among those who had quit at the start of pregnancy (2.7%)
Cnattingius et al. 1997 | 1987–1993 | 317,652 women aged 15–34 years who had had a single birth | - Nonsmokers: nondaily smokers; - Moderate smokers: 1–9 cigarettes/day; - Heavy smokers: ≥10 cigarettes/day | - Maternal smoking was associated with significantly reduced risks of mild and severe preeclampsia (RR =0.6 and 0.5, respectively); - In pregnancies with severe preeclampsia, smoking ≥10 cigarettes/day was associated with increased ratesof perinatal mortality (from 24–36 per 1,000), abruptio placentae (from 31–67 per 1,000), and small for gestational age (SGA) infants (from 28–68%); - Smokers in whom preeclampsia develops have very high risks of perinatal mortality, abruptio placentae, and SGA infants

* RR = Relative risk.

† CI = Confidence interval.

‡ OR = Odds ratio.

##### Preterm Premature Rupture of Membranes

The rupture of the amniotic sac before the onset of labor is called a premature rupture of membranes (PROM). When PROM occurs before 37 weeks of gestation, it is referred to as preterm PROM. PROM is multifaceted in its etiology, possibly involving multiple steps before the membranes rupture (French and McGregor 1996). Potential determinants of PROM include infections, inflammation, physical stress, disturbance of collagen metabolism, and health behaviors such as nutrition and smoking. Cigarette smoke components may increase the risk of PROM through several mechanisms, including disruption of the cytokine system, impairment of immune function in the reproductive tract, and promotion of inflammatory mechanisms (French and McGregor 1996). It also is possible that impaired nutrition, specifically the reduction of available nutrients and cellular amino acid uptake, is involved in PROM (French and McGregor 1996). However, confirmation of any one of these pathways from smoking to PROM awaits future studies. It is likely that preterm PROM and non-preterm PROM have somewhat different etiologies (French and McGregor 1996).

Preterm PROM has been studied in relation to smoking during pregnancy (Harger et al. 1990; Williams et al. 1992; Spinillo et al. 1994d), with most studies finding an elevated risk (Table 5.9). Adjusted ORs for smokers range from 1.6 to 2.1, and dose-response relationships of risk with daily smoking levels have been investigated but with mixed results (Williams et al. 1992; Spinillo et al. 1994d). Studies that have shown no increased risk for smokers generally had small sample sizes and inadequate consideration of potential confounding (Harger et al. 1990).

Table 5.9 Studies on the association between maternal smoking and premature rupture of membranes

Study | Study period | Population | Definition of smoking | Key results
Harger et al. 1990 | 1982–1983 | 594 women: 341 women with PROM^*^ and 253 controls | - Cigarette smoking only; - Nonsmokers; - Stopped before pregnancy; - Stopped during pregnancy; - Current smokers | - Current smoking, antepartum vaginal bleeding in more than one trimester, and previous preterm delivery were independent risk factors for preterm PROM; - The OR^†^ for current smoking was 2.1 (95% CI^‡^, 1.4–3.1); - Smoking cessation by pregnant women may reduce the risk of preterm PROM
Williams et al. 1992 | August 1977– March 1980 | 3,047 mothers who delivered at 1 hospital: 307 with PROM, 488 preterm non- PROM mothers, and 2,252 controls | Average number of cigarettes/day | - The RR^§^ of preterm PROM for women who reported ever having smoked during pregnancy compared with nonsmokers was 1.6 (95% CI, 1.1–2.4); - No gradient between the number of cigarettes/day and the risk of preterm PROM was observed; - Women who smoked during pregnancy had an increased risk of preterm non-PROM (adjusted OR = 2.1[95% CI, 1.4–3.1])
Spinillo et al. 1994d | 1988–1992 | 405 pregnant women: 138 diagnosed with idiopathic premature membrane rupture and267 controls | Data were not reported | - Previous preterm deliveries, preeclampsia, low social class, maternal smoking, high body mass index, 1stand 2nd–3rd trimester hemorrhages, maternal anemia, and incompetent cervix were significant risk factors for preterm PROM; - Cigarette smoking and reproductive history were significant risk factors for both early (<32 weeks) and late (≥32 weeks) PROM

* PROM = Premature rupture of membranes.

† OR = Odds ratio.

‡ CI = Confidence interval.

§ RR = Relative risk.

##### Shortened Gestation

A shortened gestational period can be measured in two ways: by the number of days or weeks of pregnancy and by a preterm delivery, defined as less than 37 weeks of completed gestation. One major mechanism whereby active smoking leads to a shortened gestation is through pregnancy complications. Smoking during pregnancy increases the risk for and exacerbates several pregnancy complications such as PROM, infections, placenta previa, and placental abruption, which in turn are associated with shortened gestations. When a shortened gestation is measured in continuous days, differences between smokers and nonsmokers are on the order of two to three days.

A shortened gestation attributable to smoking, measured by a preterm delivery, has been reported in numerous studies. In a meta-analysis of 20 prospective studies, Shah and Bracken (2000) reported an overall adjusted OR for a preterm delivery of 1.27 (95 percent CI, 1.21–1.33) for smokers compared with non-smokers. Not all of the 20 studies reported a significantly elevated risk for smokers compared with nonsmokers, and very few accounted for complications such as PROM, infections, placenta previa, or others. Shiono and colleagues (1986b) studied preterm delivery risks for light and heavy smokers, stratifying their sample by the presence of pregnancy complications (PROM, placenta previa, or placental abruption) and no complications. These authors reported that the risk of a preterm delivery was elevated both among the subsamples with complications and within the sample with no pregnancy complications, suggesting that prenatal smoking may act to increase rates of preterm deliveries by causing complications and also by a more direct pathway.

#### Birth Weight and Intrauterine Growth Retardation

Key outcomes in relation to maternal smoking during pregnancy include birth weight, LBW, and IUGR. Infants with LBW, defined as weighing less than 2,500 g at birth, have a higher risk of subsequent infant morbidity, mortality, and longer-term childhood and adult adverse consequences. IUGR, as the name implies, is reduced fetal physical growth during gestation. One indicator of IUGR, small for gestational age, is often defined as the lowest 10 percent of birth weights (or sometimes the lowest 5 percent) for any gestational age. A number of possible mechanisms leading to reductions in birth weight and fetal growth as a result of smoking have been suggested.

On the basis of animal studies, it appears that nicotine acts on the respiratory and central nervous systems of the fetus and concentrates in maternal and fetal blood, amniotic fluid, and breast milk (Lambers and Clark 1996). The physiologic effects of tobacco on fetal growth may result from the vasoconstrictive effects of nicotine on the uterine and umbilical arteries and an increase in carboxyhemoglobin, leading to reduced oxygenation of the fetus (Lambers and Clark 1996; Werler 1997). Nicotine may have a direct toxic effect on the fetal cardiovascular system resulting in reduced blood flow (Bruner and Forouzan 1991). Abstaining from smoking for 48 hours during the third trimester increased the available oxygen to the fetus by 8 percent (Davies et al. 1979). Cadmium from cigarette smoke accumulates in the placenta and leads to morphologic and functional impairment (Sikorski et al. 1988). The fetus is likely exposed to the cadmium because this element has been detected in cord blood (Chatterjee et al. 1988).

Some researchers have argued against a nutritional effect of smoking on reduced fetal weight and size; smoking mothers have been found to eat more than nonsmoking mothers, and an increased energy intake does not prevent IUGR (Muscati et al. 1996). Furthermore, tricep and subscapular skinfold measurements of infants of smokers were found to be normal and/or similar to those of infants of nonsmoking mothers (Harrison et al. 1983). In fact, infants of smokers lose lean body mass and not adipose tissue, which is consistent with the hypothesis that maternal nutrition is not a mediator of this effect. Hypoxia has been suggested as mediating part of this process (Harrison et al. 1983).

The primary mechanism by which birth weights are reduced among infants of smokers compared with those of nonsmokers is through fetal growth restriction. Birth weight and LBW, however, were often examined for research purposes, as both are available and reliably reported for nearly all infants. Accurate determination of IUGR, however, requires an estimate of the gestational age of the infant, which is subject to greater uncertainty and misreporting.

Reported birth weight differences between infants of smokers and infants of nonsmokers are surprisingly consistent across studies and populations (Simpson 1957; Butler et al. 1972; D’Souza et al. 1981; Sexton and Hebel 1984; Backe 1993; Bardy et al. 1993; Wilcox 1993; Ellard et al. 1996) (Table 5.10). On average, women who smoke throughout their pregnancies have infants who weigh about 200 g less than infants of women who do not smoke during pregnancy. Women who quit smoking early in their pregnancy have infants with similar weights to infants of non-smokers (USDHHS 1990). Thus, the evidence on birth weights after smoking cessation by the mother supports the hypothesis that smoking contributes to lighter infants. Numerous studies also document the association between active smoking during pregnancy and LBW (Hopkins et al. 1990; McDonald et al. 1992; Mainous and Hueston 1994). Only a few studies have not found an association between lower birth weights among smoking compared with nonsmoking mothers, and numerous studies have demonstrated a dose-response relationship with the number of cigarettes smoked and the degree of reduction in birth weights. Studies with biochemically measured smoking exposures (e.g., cotinine levels) also have confirmed, in an even stronger dose-response pattern than that seen from self-reported data, the relationship between pre-natal smoking and birth weight (Haddow et al. 1987; Bardy et al. 1993; Li et al. 1993; Eskenazi et al. 1995b; Peacock et al. 1998).

Table 5.10 Studies on the association between maternal smoking, birth weight, and intrauterine growth retardation

Study | Study period | Population | Definition of smoking | Key results
Simpson 1957 | 1953–1955 | 7,499 obstetric patients from 3 hospitals | - Nonsmokers did not smoke; - Light smokers: 1–10 cigarettes/day; - Heavy smokers: >10 cigarettes/day | - Incidence of premature births was twice as great for smokers as for nonsmokers; - Prematurity rates increased with the number of cigarettes/day; the highest rates were for heavy smokers and the lowest were for nonsmokers
Butler et al. 1972 | March 1958–May 1958 | 16,994 singleton births occurring in 1 week, and 7,000 late fetal and neonatal deaths occurring during the following 3 months | - Nonsmokers did not smoke; - Smokers: four groups based on the average number of cigarettes smoked (1–4, 5–9, 10–19, 20–30) | - Mortality rates for late fetal plus neonatal deaths, according to the average number of cigarettes/day, showed that the death rate was lowest for nonsmokers, intermediate for those smoking 1 to 4 cigarettes/day, and highest among those smoking >4 cigarettes/day; - Smoking habits established at the end of the fourth month of pregnancy had an effect on perinatal mortality independent of maternal prepregnancy smoking habits; - Similarly, the effect on birth weight of smoking before pregnancy became nonsignificant after taking into account the average number of cigarettes smoked regularly after the fourth month
D’Souza et al. 1981 | NR^*^ | 452 mothers aged 19–35 years, who attended antenatal clinics and had normal singleton pregnancies | - Nonsmokers did not smoke; - Light to moderate smokers: 1–14 cigarettes/day; - Heavy smokers: ≥15 cigarettes/day | - Heavy smokers gained significantly less weight than nonsmokers, but there was no significant difference in skinfold thickness; - Babies born to smokers weighed less, had smaller head circumferences, and were shorter than those born to nonsmokers, but skinfold thickness was similar
Sexton and Hebel 1984 | 2½ years | 935 women aged 14–42 years: 463 receiving smoking cessation interventions and 472 controls | Women were classified by the number of cigarettes/day (0, 1–5, 6–10, 11–20, >20) | - The treatment group infants had a mean birth weight 92 g heavier and were 0.6 cm longer than the control infants; - There were no significant differences between the two groups in head circumferences, gestational age, or Apgar scores; - Findings suggest that some fetal growth retardation can be overcome by smoking cessation assistance to pregnant women
Martin and Bracken 1986 | May 1980–March 1982 | 3,891 antenatal patients | Tobacco smoke exposure: none, passive (exposed to someone else’s cigarette for at least 2 hours/day), direct, and passive and direct | - The RR^†^ of low birth weight for passive exposures to smoke compared with unexposed women was 2.17 (95% CI^‡^, 1.05–4.5); - Those passively exposed to smoke delivered infants 24 g lighter on average; - The risk of low birth weight at term attributable to direct cigarette smoking was 3.54 (95% CI, 1.62–7.71)
Haddow et al. 1987 | July 1980–June 1983 | 4,211 women between 15 and 21 weeks of gestation | Smokers were classified by reported daily cigarette use and serum cotinine levels | - Both cotinine levels and smoking history were significantly associated with reduced birth weight, but cotinine correlated significantly better; - Women who smoked >25 cigarettes/day had infants 289 g lighter than nonsmokers; - Women with high serum cotinine levels (>284 ng/mL) had infants who were 441 g lighter than infants of women with the lowest cotinine levels (<24 ng/mL)
Cnattingius 1989 | 1983–1985 | 280,809 live births to women aged 15–44 years | - Nonsmokers: nondaily smokers; - Moderate smokers: 1–9 cigarettes/day; - Heavy smokers: ≥10 cigarettes/day | - A significant interaction between maternal age and moderate or heavy smoking was observed for the risk of having a SGAΔ infant; - The RR of SGA for heavy smokers vs. nonsmokers was 1.9 in the youngest age group and 3.4 in the oldest age group
Alameda County Low Birth Weight Study Group 1990 | NR | 311 black and 220 white singleton infants of normal birth weight selected randomly | Cigarette smoking during pregnancy: did not smoke at all, only at the beginning of the pregnancy, off and on throughout, and regularly throughout | - The RR of low birth weight in black smokers compared with black nonsmokers was 3.6; in white smokers it was 3.0; - The RR of term low birth weight (intrauterine growth retardation) was 4.5 in black smokers and 5.1 in white smokers; - Quitting smoking in the first 3 months of pregnancy was associated with a lower RR for low birth weight for black and white babies
Ferraz et al. 1990 | September 1984–February 1986 | 3,406 singleton infants: 429 preterm, 422 with intrauterine growth retardation, and 2,555 controls with normal birth weights and gestational ages | NR | - Smoking, a heavy workload during pregnancy, <5 or >10 antenatal visits, and any gestational or intrapartum complications were associated with higher risks of preterm and intrauterine growth-retarded births; - For preterm cases, the adjusted OR^§^ associated with smoking during pregnancy was 1.5 (95% CI, 1.2–2.0); - For intrauterine growth retardation, the adjusted OR for smoking during pregnancy was 1.5 (95% CI, 1.1–2.0)
Fox et al. 1990 | NR | 714 children whose mothers smoked at the beginning of pregnancy | - Women who smoked throughout the pregnancy; - Quitters (women who reported 0 cigarettes/day at the eighth month contact) | - By 3 years of age, the children of women who had quit smoking during pregnancy were taller and heavier than those of women who had smoked throughout the pregnancy; - Differences in weight but not in height were partly accounted for by the postpartum maternal smoking status; - Results suggest that deficits associated with maternal smoking are not overcome by 3 years of age, and some of the observed anthropometric deficits may be extensions of deficits in fetal growth
Hopkins et al. 1990 | January 1989–June 1989 | 74,139 singleton infants: 62,732 white infants and 11,407 black infants | - Light smokers: <0.5 pack/day; - Moderate smokers: 0.5–1 pack/day; - Heavy smokers: >1 pack/day | - Infants born to smokers were more than twice as likely to have low birth weight as infants born to non-smokers; - The risk of low birth weight increased by the level of exposure: adjusted ORs = 1.8, 2.2, and 2.4 for light, moderate, and heavy smokers, respectively; - For both blacks and whites, risks were directly proportionate to smoking levels
Wen et al. 1990 | January 1983–January 1988 | 15,539 births from women who received prenatal care and who delivered at 1 hospital | Cigarette use during the pregnancy before the first visit | - Smoking lowered birth weights by decreasing fetal growth and by lowering gestational age at delivery; - The effect was significantly greater as maternal age increased: smoking was associated with a fivefold increased risk of growth retardation in women aged >35 years, but less than a twofold risk in women aged <17 years; - Smoking reduced birth weights by 134 g in younger women, and by 301 g in women aged >35 years
McDonald et al. 1992 | NR | 40,445 single pregnancies from a survey | Women were classified as nonsmokers, smoked <10 cigarettes/day, 10–19 cigarettes/day, or ≥20 cigarettes/day | - The risk of low birth weight for gestational age (LBWGA) increased substantially with smoking: for every 10 cigarettes/day, the risk of LBWGA increased by a factor of 1.51 (95% CI, 1.44–1.57); - Smoking accounted for 39% of LBWGA cases, 35% of low birth weights, and 11% of preterm births; - Risk was reduced for women who decreased their smoking and who smoked before but not during the first trimester
Werler et al. 1992 | 1976–1990 | 2,657 infants from a surveillance program on birth defects: 76 with gastroschisis and 2,581 controls | Smoking was determined by the number of cigarettes/day during pregnancy | - Cigarette smoking was not associated with gastroschisis; - Age-adjusted RRs for smoking and coffee intake were close to 1.0; - There was a strong inverse relationship between maternal age and gastroschisis, with a 16-fold increased risk for the youngest mothers
Backe 1993 | 1988–1989 | 1,908 women in 1 county who delivered during a 1-year period | The number of cigarettes/day (0, 1–5, 6–10, 11–20, >20) | - Smokers experienced a mean birth weight impairment of 182 g (adjusted for parity and age); - There was a dose-response effect of the number of cigarettes/day on birth weight at the first visit; - The RR for SGAΔ newborns of smokers <25 years of age was not significant, whereas women aged ≥35 years had a RR of 3.8
Bakketeig et al. 1993 | January 1986–March 1988 | 5,722 pregnant women | Smokers: women who at first visit reported daily smoking at the time of conception | - Mothers who smoked cigarettes around the time of conception nearly doubled their risk of SGA births; - If the mother smoked and had a previous low birth weight delivery, the RR rose to nearly 5.5; - Low prepregnancy weight and smoking together increased the risk of a SGA birth fourfold
Bardy et al. 1993 | February 1991–March 1991 | 1,237 pregnancies and newborns representing all live birth pregnancies during 1 week in 1 country | - Nonsmokers: had not smoked; - Quitters: smoked during the first trimester and then quit; - Smokers: smoked during the entire pregnancy | - Tobacco exposure was associated with shorter gestational age, reduced birth weight, and shorter crown-heel length of newborns: exposed newborns were on average 188 g lighter and 10 mm shorter than unexposed newborns; - Maternal cotinine concentrations explained the neonatal findings better than the reported smoking habits; - There was a quantitative dose-response relationship with tobacco exposure, and a decrease in gestational age at birth and in the size of the neonate
Cnattingius et al. 1993 | 1983–1988 | 538,829 women with singleton births | - Nonsmokers: nondaily smokers; - Smokers: 1–9 cigarettes/day and ≥10 cigarettes/day | - Among multiparous women, smoking increased the ORs for low birth weight and preterm delivery by 2.4 and 1.6, respectively; the corresponding increases for nulliparous women were 1.7 and 1.1, respectively; - With advancing maternal age, there was a smoking-related relative increase in the ORs for SGA births; - The age effect on the relative increase of low birth weight, preterm delivery, and SGA births was greater among nulliparous women than among multiparous women
Li et al. 1993 | 1986–1991 | 1,277 women <32 weeks pregnant at the first prenatal visit to a clinic | Smokers: at her first prenatal visit reported at least one puff from a cigarette in the last 7 days, and/or had a baseline or follow-up cotinine level of >30 ng/mL | - Infants born to women who had quit smoking had the highest mean birth weight, followed by infants born to women who had reduced their smoking, and women who did not change their smoking behavior; - Although smoking cessation increased infant gestational age at delivery by 1 week, reducing smoking had no effect; - Cotinine-validated smoking reduction rates were positively associated with an increase in infant birth weight
Wilcox 1993 | 1980–1984 | 260,000 white singleton births in 1 state | - Nonsmokers: mothers who reported no smoking during pregnancy; - Smokers: mothers who reported smoking ≥1 pack of cigarettes/day; - Smokers of <1 pack were excluded | - Infants of mothers who smoked ≥1 pack of cigarettes/day were on average 320 g lighter than unexposed infants (3,180 g compared with 3,500 g); - Perinatal mortality for infants of smokers was 14.5 per 1,000 compared with 10.4 per 1,000 for infants of nonsmokers; - The RR was not uniform across birth weights: among infants less than 3 kg, weight-specific mortality rates were lower for exposed vs. unexposed infants; among heavier infants, the risk was reversed, with mortality higher for exposed infants; - When standardized weight-specific mortality rates are compared, the pattern becomes more consistent, with exposed infants showing a higher risk of mortality across all relative birth weights
Lieberman et al. 1994 | August 1977–March 1980 | 11,177 women with singleton pregnancies from a hospital-based cohort | Women were classified as nonsmokers, smoked throughout pregnancy, smoked during the first trimester only, smoked during the first and second trimesters only, and smoked during the second and third trimesters or during the third trimester only | - Women who began smoking during the second or third trimester had an elevated risk of SGAΔ births (OR = 1.83 [95% CI, 1.25–2.67]) similar to that of women who had smoked throughout pregnancy (OR = 2.2 [95% CI, 1.9–2.54]); - Risks for SGA births increased with the number of cigarettes smoked during the third trimester
Mainous and Hueston 1994 | 1988 | 4,876 women who gave birth | - Nonsmokers did not smoke cigarettes at all during the year before birth; - Smokers: (1) those who stopped smoking during the first trimester of pregnancy, (2) those who continued smoking beyond the first trimester of pregnancy | - Women who did not smoke during pregnancy were less likely to give birth prematurely (5.9 vs. 8.2%) or to give birth to a low birth weight baby (5.5 vs. 8.9%) than women who smoked at some time during the year before birth; - Compared with those who smoked beyond the first trimester, those who quit smoking within the first trimester had reductions in the proportion of preterm deliveries (6.7 vs. 9.1%) and low birth weight infants (7.9 vs. 9.6%)
Spinillo et al. 1994c | 1988–1992 | 1,041 pregnancies: 347 with fetal growth retardation and 694 controls | Maternal smoking was classified as none, 1–10 cigarettes/day, 11–20 cigarettes/day, and >20 cigarettes/day | - Fetal growth retardation was associated with maternal smoking (OR = 2.87 [95% CI, 2.17–3.8]); - Smoking-related risks of fetal growth retardation were increased in the case of a male fetus, nulliparity, maternal age <20 years, a history of first trimester hemorrhage, and low prepregnancy weight
Eskenazi et al. 1995b | 1964–1967 | 3,529 pregnant women around 27 weeks of gestation | - Smokers: current smokers at the time of interview; - Nonsmokers: never smoked or had quit before the pregnancy | - Compared with infants of unexposed nonsmokers, infants of exposed nonsmokers weighed 45 g less on average; - Infants of smokers weighed on average 78, 191, and 233 g less for the first, second, and third cotinine tertiles, respectively; - Birth weight decreased 1 g for every increase in nanogram per milliliter of cotinine
Ellard et al. 1996 | NR | 3,038 mothers who gave birth to live singleton babies after 28 weeks of gestation | - Smoking was determined by self-reported daily cigarette use (0, 1–12, >12), and urinary nicotine metabolites/creatinine ratios (0, 0.01–11.0, >11.0 μg/mg); - Proven nonsmokers: reported nonsmoking status was confirmed by negative urine tests; - Proven smokers: reported smoking was confirmed by positive urine test results | - Adjusted birth weight deficits of babies born to active smokers averaged 226 g (95% CI, 194–258 g); - Dose-dependent effects were only apparent when nicotine intake was based on urinary nicotine metabolites/creatinine ratios than on self-reports; - Maternal weight gain during pregnancy was substantially reduced in smokers; - Placental weight gain was unaffected by smoking
Muscati et al. 1996 | 1979–1989 | 1,339 pregnant women | - Nonsmokers: did not report smoking at any time during pregnancy, or had stopped by 10 weeks of pregnancy; - Smokers: ≥1 cigarette/day throughout entire pregnancy | - Smoking was independently associated with a higher energy intake but a lower maternal weight gain (−2.16 kg) and infant birth weight (−205 g); - The important negative effect of smoking on fetal growth retardation cannot be adequately mitigated by simply increasing energy intake; - The estimated percentage of SGAΔ infants attributable to smoking was 30.8%
Peacock et al. 1998 | August 1982–March 1984 | 1,254 white women seeking antenatal care from a hospital | Number of cigarettes/day | - Among smokers, cotinine levels were more closely related to birth weight than the number of cigarettes smoked, indicating that cotinine is a better predictor of birth weight than the reported number of cigarettes smoked; - Among nonsmokers, the association between cotinine levels and birth weight was not statistically significant after adjusting for confounding factors; - The difference in mean birth weights between nonsmokers in the lower and upper quintiles of cotinine was 0.2%; - Any effect of maternal passive smoking was small compared with the effects of maternal active smoking on birth weight

* NR = Data were not reported.

† RR = Relative risk.

‡ CI = Confidence interval.

§ OR = Odds ratio.

Δ SGA = Small for gestational age.

The greatest risk of subsequent mortality and morbidity is among infants born with very low birth weight (VLBW), or weight at birth of less than 1,500 g. VLBW occurs in approximately 3 percent or fewer births; thus, very few studies have a large enough sample size to be able to break out VLBW infants to examine the association with smoking. Hopkins and colleagues (1990) examined the association between smoking and VLBW for births in Ohio for 1989 and reported elevated risks (adjusted OR = 1.4 and population attributable risk = 8.4 percent) among smokers compared with nonsmokers. More recent reviews, however, suggest that the effect of smoking during pregnancy on birth weight is primarily on infants who weigh around 2,500 g and that smoking does not substantially increase the risk of VLBW (Shiono and Behrman 1995; Strobino 1999). Further studies are needed to determine whether and how smoking during pregnancy is related to VLBW births.

The association between smoking and IUGR also has been demonstrated in a number of studies (Cnattingius 1989; Ferraz et al. 1990; Wen et al. 1990; McDonald et al. 1992; Backe 1993; Bakketeig et al. 1993; Lieberman et al. 1994; Spinillo et al. 1994c) (Table 5.10). The RRs range from 1.5 to 2.5 for smokers compared with nonsmokers. Several studies demonstrated dose-response relationships of risk with the amount smoked, with the highest smoking categories showing RRs of 5.0 to 9.9 (Wen et al. 1990; Bakketeig et al. 1993; Lieberman et al. 1994; Spinillo et al. 1994c). Most studies adjusted for numerous potential confounding factors and still reported strong associations and dose-response relationships with daily smoking levels. These associations with active smoking by the mother may be underestimated as a substantial proportion of women in the nonsmoking control groups are exposed to secondhand cigarette smoke. Exposure to secondhand smoke also reduces birth weight, and removing the group of passively exposed women from the control group increases RRs (Martin and Bracken 1986). One study examining the contributions of smoking, energy intake, weight gain, and fetal growth reported that the effect of smoking was independent of energy intake (which was higher in smokers) and weight gain (which was lower in smokers) (Muscati et al. 1996). Thus, this finding supports a direct effect of smoking on the growth of the fetus rather than an indirect effect through nutritional intake among smokers.

### Evidence Synthesis

The evidence addresses smoking during pregnancy and diverse outcomes. For some of the outcomes, causal conclusions have been previously reached. Most studies on the relationship between smoking and ectopic pregnancy have demonstrated a positive association, with several demonstrating a dose-response relationship between risk and amount smoked. However, the number of studies is still limited, and uncontrolled confounding remains as an alternative explanation to a causal association. Biologic mechanisms include a possible indirect causal pathway through an increased risk for a pelvic infection in smokers, a delayed fertilization process, and reduced tubal motility in association with exposures to nicotine.

Despite methodologic challenges in studying spontaneous abortions, most studies on the association between active smoking and spontaneous pregnancy loss have reported increased risks for smokers compared with nonsmokers, and some studies demonstrate dose-response relationships. Animal models have indicated plausible mechanisms that may underlie the association.

Most studies demonstrate an increased risk for maternal smoking and preterm PROM, placenta pre-via, and placental abruption. These findings have been consistently observed across time and across many study populations in multiple countries. Also, biologic evidence supports the contribution of active smoking to these particular pregnancy conditions.

Many studies show an increased risk of preterm delivery among smokers compared with nonsmokers even though the overall risk of preterm delivery may be small, with ORs on the order of 1.2 or 1.3. One major mechanism by which smoking is related to preterm delivery is through an increase in the risks of pregnancy and/or fetal complications that result in a spontaneous abortion or a medically indicated early delivery.

Many studies have consistently demonstrated a positive association between maternal smoking during pregnancy and reduced birth weight, and several have demonstrated dose-response relationships with the amount smoked. For smoking throughout pregnancy the effect is large, and successful cessation of smoking before the third trimester eliminates much of the reduction caused by maternal smoking. Some mechanisms by which smoking reduces birth weight have been established. They act in large part through reduced fetal growth, but the association between smoking and birth weight also results from early delivery, often from pregnancy complications. The biologic evidence supporting this causal effect is strong and includes fetal hypoxia from increased carboxyhemoglobin; reduced blood flow to the uterus, placenta, and fetus; and direct effects of nicotine and other compounds in tobacco smoke on the placenta and fetus.

### Conclusions

1. The evidence is suggestive but not sufficient to infer a causal relationship between maternal active smoking and ectopic pregnancy.
2. The evidence is suggestive but not sufficient to infer a causal relationship between maternal active smoking and spontaneous abortion.
3. The evidence is sufficient to infer a causal relationship between maternal active smoking and premature rupture of the membranes, placenta previa, and placental abruption.
4. The evidence is sufficient to infer a causal relationship between maternal active smoking and a reduced risk for preeclampsia.
5. The evidence is sufficient to infer a causal relationship between maternal active smoking and preterm delivery and shortened gestation.
6. The evidence is sufficient to infer a causal relationship between maternal active smoking and fetal growth restriction and low birth weight.

### Implications

The evidence reviewed in this chapter suggests that smoking is associated with ectopic pregnancy and spontaneous abortion. As both ectopic pregnancy and infertility are on the rise, reducing smoking among women intending to become pregnant is warranted. More studies are needed that are designed to prospectively assess very early losses and to examine the association of smoking around the time of conception with types of spontaneous abortions.

The evidence of an association of smoking during pregnancy and adverse pregnancy complications, such as preterm PROM, placenta previa, and placental abruption, is sufficient to warrant promoting smoking cessation among women before they become pregnant and during pregnancy. Werler (1997) noted that as much as 10 percent of abnormal placentation could be avoided if smoking during pregnancy were eliminated. The decreased risk of preeclampsia among smokers compared with nonsmokers does not outweigh the adverse outcomes that can result from prenatal smoking.

The occurrence of LBW could be reduced by an estimated 20 percent, and fetal growth restriction by 30 percent, if all women were nonsmokers during pregnancy (Alameda County Low Birth Weight Study Group 1990; Cnattingius et al. 1993; Li et al. 1993; Muscati et al. 1996). The impact of smoking on these outcomes can be lessened if women quit before their third trimester; thus, there is a need for widespread implementation of effective smoking cessation interventions targeting all women of childbearing age as well as those already pregnant.

## Congenital Malformations, Infant Mortality, and Child Physical and Cognitive Development

### Epidemiologic Evidence

#### Congenital Malformations

Because of the direct fetal effects observed from exposure to tobacco smoke, and the chemically complex nature of cigarette smoke, researchers have assessed the association between prenatal exposure and congenital malformations. Researchers have examined these associations with malformations as an overall group and with single malformations separately. The etiologies of the multiple congenital malformations vary widely, making the discussion of the contribution of prenatal smoking to an increased risk of birth defects difficult overall.

Most studies investigating associations between maternal smoking during pregnancy and all congenital malformations together have not found an association (Hemminki et al. 1983; Shiono et al. 1986b; Malloy et al. 1989; Seidman et al. 1990; Van den Eeden et al. 1990) (Table 5.11). One study reported an increased risk only among heavy smokers (Kelsey et al. 1978), with an adjusted RR of 1.6 (p = 0.03) for women smoking 21 or more cigarettes per day during pregnancy compared with nonsmokers.

Table 5.11 Studies on the association between maternal smoking and congenital malformations

Study | Study period | Population | Definition of smoking | Key results
Saxen 1974 | 1967–1971 | 599 cases of oral clefts reported to a register of congenital malformations | Smoking during pregnancy: >5 cigarettes/day | - Smoking during pregnancy was significantly more frequent among mothers of children with clefts than among controls; - Other factors associated with oral clefts in children included parental age, socioeconomic status, threatened abortion (bleeding and/or pains during pregnancy), pelvic x-ray examinations before pregnancy, emotional factors, and birth weight
Kelsey et al. 1978 | 1974–1976 | 4,338 infants: 1,370 with congenital malformations and 2,968 normal controls | The number of cigarettes/day during pregnancy | - Women who smoked >20 cigarettes/day during pregnancy had a RR^*^ of about 1.6 for congenital malformations in offspring compared with women who smoked ≤20 cigarettes/day during pregnancy; - There was no significant increase in risk among women who reported smoking ≤20 cigarettes/day compared with women who did not smoke during pregnancy; - The higher risk in heavy smokers could be a result of confounding factors or response bias, so further research is needed to determine a causal relationship between maternal smoking and congenital malformations
Hemminki et al. 1983 | 1967–1977 | 3,300 children from a register of congenital malformations | - Smoking habits were described in 10 categories in the questionnaire; - Different categories of smokers were created separately for the analysis | - The associations between maternal smoking and congenital malformations were statistically nonsignificant; there was a slight increase with the number of cigarettes smoked, suggesting a minor effect; - Women who smoked >10 cigarettes/day had a higher frequency of spontaneous abortions than any other group of women
Hook and Cross 1985 | 1980–1981 | 300 mothers: 100 with Down syndrome children, 100 with children with other defects, and 100 with children with no defects | - Nonsmokers (those who never smoked); - Former smokers at the time of conception; - Current smokers | - The RR for the association of cigarette smoking around the time of conception with Down syndrome was 0.58 (90% CI^†^, 0.34–0.98) in the case-defect control group, and 0.56 (90% CI, 0.33–0.95) in the case-normal control group; - The negative association may be attributable to a selective effect of smoking on survival, on the fertilizability of >21 gametes before conception, or on survival of >21 conceptuses after fertilization
Shiono et al. 1986a | 1974–1977 (birth defects study) 1959–1966 (perinatal study) | 33,434 live births in a birth defects study, and 53,512 live births in a perinatal project | The number of cigarettes or packs/day | - Since associations found in a single study could be the result of chance, deficiencies in study design, or peculiarities of the population studied, data from another study were used to check for consistencies of the associations initially found; - The associations of specific congenital malformations with smoking during pregnancy were suggested in the birth defects study, but the results could not be confirmed by the results from the perinatal study; - Smoking is unlikely to be responsible for a large increase in malformations at birth
Khoury et al. 1987 | 1987 | 251 infants from a birth defects reporting system: 27 with cleft lip, 26 with cleft palate, and 198 with other sentinel defects | Asking respondents whether they smoked at any time during pregnancy and if yes, how many cigarettes/day (1–5, 6–10, 11–20, >20) | - Mothers of infants with oral clefts smoked more during pregnancy than mothers of infants with other defects; - The OR^‡^ for cleft lip with or without cleft palate was 2.56, and the OR for cleft palate was 2.39; - There was a dose-response relationship between the daily amount smoked and the risk of clefting
Malloy et al. 1989 | 1980–1983 | 288,067 singleton births recorded in birth defects registry | - Nonsmokers: did not smoke; - Smokers: <1 pack/day or ≥1 pack/day | - Infants of women who smoked were not at a greater risk for congenital malformations than infants of women who did not smoke; - Maternal smoking appears to be a risk factor for gastrointestinal malformations, but other congenital malformations occur less frequently in infants of smokers compared with nonsmokers
Cuckle et al. 1990a,b | NR^§^ | 462 pregnant women | - Smoking was determined by cotinine concentrations in maternal serum samples; - Maximum likelihood analysis was used to determine cotinine cut-off levels for separating smokers from nonsmokers | - In pregnancies with and without Down syndrome, the 25th, median, and 75th centiles of AFP (alpha- feto protein) and DHEAS (dehydroepiandrosterone) were higher in smokers than in nonsmokers, whereas those for uE_3_ (unconjugated estriol), hCG (human chorionic gonadotrophin), and progesterone were lower; - When screening for Down syndrome using maternal age, AFP, uE_3_, and hCG, allowance could be made for smoking by deriving separate medians for smokers and nonsmokers to calculate MoM values (multiple of the median value in unaffected pregnancies of the same gestation)
Van den Eeden et al. 1990 | 1984–1986 | 7,784 mothers with singleton live births: 3,284 with a congenital malformation and 4,500 controls without malformations | NR | - When all malformations were considered together, there was no association with maternal smoking; - Maternal smoking was associated with increased risks for a number of specific malformations, including microcephalus (RR = 2.0 [95% CI, 1.0–4.0]), cleft defects (RR = 1.4 [95% CI, 1.0–2.0]), and clubfoot (RR = 1.4 [95% CI, 1.0–2.0]); - No association was found with Down syndrome or any other malformation
Haddow et al. 1993 | January 1980–April 1989 | 62,103 consecutive second trimester singleton pregnancies | Smokers or nonsmokers | - Pregnant women who smoked cigarettes had at 2.1 times greater odds of having an infant with gastroschisis than nonsmokers (95% CI, 0.9–4.8); - Smoking data from this study combined with smoking data from two other studies showed an OR of 1.6 (95% CI, 1.2–2.2)
Torfs et al. 1994 | March 1988–August 1990 | 330 mothers: 110 mothers of infants with gastroschisis and 220 age-matched mothers of normal infants | <1 pack/day and >1 pack/day | - There was a significant association of gastroschisis with a history of maternal smoking and with the use of either a recreational drug, alcohol, or tobacco during the trimester preceding pregnancy; - During the preconceptional trimester, the OR for the risk of having an infant with gastroschisis for smokers of <1 pack/day was 1.4 (95% CI, 0.78–2.5) and 1.77 (95% CI, 0.93–3.39) for smokers of ≥1 pack/day
Hwang et al. 1995 | 1984–1992 | 467 infants: 69 with cleft palate, 114 with cleft lip with or without cleft palate, and 284 controls with noncleft birth defects | Records on whether and how many cigarettes were smoked during pregnancy | - A gene-environment interaction between infant genotype and maternal smoking was associated with birth defects among those with or without a family history of birth defects; - Infants carrying the C2 allele who were exposed to maternal smoking of <10 cigarettes/day showed a 6.16-fold increase in risks for cleft palate only (95% CI, 1.09–34.7), while similar infants whose mothers smoked ≥10 cigarettes/day showed an 8.69-fold higher risk (95% CI, 1.57–47.8)
Li et al. 1996 | 1990–1991 | 487 infants: 118 cases and 369 controls | Light smokers: 1–1,000 cigarettes during pregnancy | - Maternal smoking during pregnancy was associated with a twofold increased risk of congenital urinary tract anomalies in the offspring; - The risk was higher among light smokers (OR = 3.7 [95% CI, 1.7–8.6]) than among heavy smokers (OR = 1.4 [95% CI, 0.6–3.3]); - The increased risk of congenital urinary tract anomalies associated with light smoking but not with heavy smoking was more apparent among female than male offspring
Shaw et al. 1996 | January 1987–December 1989 | 1,465 infants: 731 with orofacial clefts and 734 nonmalformed controls | - Active smoking: number of cigarettes/day by the mother during the 4 months after date of conception; - Passive smoking: whether anyone else inside the mother’s home smoked daily during the 4 months after conception, or whether she regularly frequented places where others smoked; - Paternal smoking was determined by how many cigarettes the infant’s natural father smoked during the 3 months before through 3 months after conception | - The risks associated with maternal smoking were most elevated for isolated cleft lip with or without cleft palate (OR = 2.1 [95% CI, 1.3–3.6]) and for isolated cleft palate (OR = 2.2 [95% CI, 1.1–4.5]) when mothers smoked >20 cigarettes/day; - Clefting risks were even greater for infants with the transforming growth factor alpha (TGF-α) allele whose mothers smoked >20 cigarettes/day; - Risk of orofacial clefting in infants may be influenced by maternal smoke exposure alone, as well as in combination with the presence of the uncommon TGF-α allele (gene-environment interaction); - Paternal smoking was not associated with clefting, and passive exposures were associated with a slightly increased risk
Wasserman et al. 1996 | 1987–1988 | 1,130 infants: 207 with conotruncal heart defects, 264 with neural tube defects, 178 with limb deficiencies, and 481 controls | - Active smoking: number of cigarettes/day by the mother during the 4 months after date of conception; - Passive smoking: whether anyone else inside the mother’s home smoked daily during the 4 months after conception, or whether she regularly frequented places where others smoked; - Paternal smoking was determined by how many cigarettes the infant’s natural father smoked during the 3 months before through 3 months after conception | - Moderately elevated risks were observed for conotruncal heart defects (OR = 1.9 [95% CI, 1.24–3.1]) and limb deficiencies (OR = 1.7 [95% CI, 0.96–2.9]) with both parents smoking; - There were no increased risks for congenital abnormalities associated with maternal smoking in the absence of paternal smoking, although an increased risk associated with paternal smoking in the absence of maternal smoking was observed for limb deficiencies; - Risks associated with paternal smoking for conotruncal defects differed among racial and ethnic groups
Källén 1997a | 1983–1993 | 1,321 infants with Down syndrome | - None; - <10 cigarettes/day; - ≥10 cigarettes/day | - No association between maternal smoking and all cases of Down syndrome was found (OR = 0.98 [95% CI, 0.86–1.11]), but heterogeneity over strata existed; - A decreased OR (0.91 [95% CI, 0.72–1.15]) for any maternal smoking was indicated among primiparous women but not among multiparous women; - Findings indicate that no direct effect of smoking on Down syndrome risk exists, but the association observed in primiparous women is attributable to covarying factors
Källén 1997b | 1983–1992 | 1,834 infants with oral clefts selected from a birth registry and a congenital malformation registry | - None; - <10 cigarettes/day; - ≥10 cigarettes/day | - A statistically significant association between maternal smoking during pregnancy and oral clefts was found; - The OR for maternal smoking among cases of cleft lip with or without a cleft palate was 1.16 (95% CI, 1.02–1.32); - For cases of cleft palate alone, the OR was 1.29 (95% CI, 1.08–1.54)
Wyszynski et al. 1997 | 1966–1996 | Meta-analysis of 11 studies | NR | - There was a small increased risk among mothers who smoked during the first trimester of the pregnancy of having a child with either a cleft lip with or without a cleft palate (OR = 1.29 [95% CI, 1.18–1.42]), or with a cleft palate alone (OR = 1.32 [95% CI, 1.10–1.62])
Källén 1998 | 1983–1993 | 621 infants with neural tube defects | - None; - <10 cigarettes/day; - ≥10 cigarettes/day | - A highly significant effect of maternal smoking on the incidence of neural tube defects was found (adjusted OR = 0.75 [95% CI, 0.61–0.91]); - A protective dose-response effect of smoking was indicated but was not statistically significant

* RR = Relative risk.

† CI = Confidence interval.

‡ OR = Odds ratio.

§ NR = Data were not reported.

Down syndrome has been consistently shown not to be associated with maternal smoking in pregnancy (Hook and Cross 1985; Cuckle et al. 1990a; Van den Eeden et al. 1990; Källén 1997a). Neural tube defects are not elevated among smokers compared with non-smokers (Malloy et al. 1989; Wasserman et al. 1996; Källén 1998). However, Källén (1998) demonstrated a significant protective effect for neural tube defects among smokers compared with nonsmokers in the 1.2 million births studied (OR = 0.75 [95 percent CI, 0.61–0.91]).

Li and colleagues (1996) reported an association between maternal smoking and urinary tract anomalies among light smokers (<1,000 cigarettes smoked during pregnancy) compared with nonsmokers; the anomalies occurred mainly in female infants. The OR for light smokers versus nonsmokers was 3.7 (95 percent CI, 1.7–8.6); among mothers of female infants, comparing light smokers with nonsmokers yielded an OR of 6.1 (95 percent CI, 2.0–18.4). This study reported a lower risk for heavy smokers compared with non-smokers (OR = 1.4 [95 percent CI, 0.6–3.3]). As an explanation for this dose-dependent response, Li and colleagues (1996) suggest that heavier smokers may be more likely than light smokers to abort malformed fetuses. Malloy and colleagues (1989) and McDonald and colleagues (1992) found little association between smoking and genitourinary defects at birth.

Gastroschisis is a defect of the abdominal wall closely related to the defect omphalocele thought to result from vascular interruption (Hoyme et al. 1983). Findings on the association between gastroschisis and smoking have been conflicting. Smaller studies show a positive association (Haddow et al. 1993), whereas most larger studies and those controlling for confounders show no association (Werler et al. 1992; Torfs et al. 1994).

The association of fetal limb defects and smoking also has been studied. One study looked at the risk of limb defects from maternal and paternal smoking and found contradictory results (Wasserman et al. 1996). Risk was elevated only with heavy paternal smoking (OR = 2.0 [95 percent CI, 1.3–3.6]) compared with neither parent smoking. Maternal smoking, even heavy maternal smoking, did not elevate the risk of limb defects; nor did having both parents smoke or having passive exposures at home or at work. Because there is no evident biologic explanation for this particular pattern of association, paternal smoking in the absence of maternal smoking may be a proxy for other factors contributing to this risk. This study also reported that the risk of conotruncal heart defects was elevated when both parents smoked (OR = 1.9 [95 percent CI, 1.2–3.1]) (Wasserman et al. 1996).

The most convincing evidence supports an association between smoking and oral clefts (Saxen 1974; Khoury et al. 1987; Hwang et al. 1995; Shaw et al. 1996; Källén 1997b; Wyszynski et al. 1997), yet not all studies report an association (Shiono et al. 1986a; Malloy et al. 1989; Werler et al. 1990). Studies have examined the association with smoking for all oral cleft defects and for the categories of a cleft lip with or without a cleft palate, and cleft palate alone. Even when subgroups are examined, studies produce contradictory findings. One meta-analysis of 11 studies of oral clefts that compared mothers who smoked during the first trimester with mothers who did not smoke reported an overall OR of 1.29 (95 percent CI, 1.18–1.42) for a cleft lip with or without a cleft palate, and 1.32 (1.10– 1.62) for a cleft palate (Wyszynski et al. 1997). Recent studies have examined genetic and environmental interactions in relation to oral clefts. Two studies (Hwang et al. 1995; Shaw et al. 1996) reported that infants who were heterozygous or homozygous for transforming growth factor alpha allele and were exposed to smoking during pregnancy had significantly increased risks for a cleft palate of 7.0 (95 percent CI, 1.18–28) (Hwang et al. 1995) and 4.0 (95 percent CI, 1.7–9.2) (Shaw et al. 1996). Risks for a cleft lip with or without a cleft palate were lower, about twofold, and were only significant in one study where smoking alone significantly elevated the risks of both outcomes (OR = 1.6) (Shaw et al. 1996). In the other study, smoking alone was not associated with either category of oral clefts (Hwang et al. 1995).

#### Infant Mortality and Stillbirths

Stillbirths (fetal death after 28 weeks) and infant deaths (death within the first year of life) have been examined in relation to smoking in numerous studies. These outcomes have declined significantly in the United States in recent years, as infant mortality has declined from 13 deaths per 1,000 births in 1980 to 7 deaths per 1,000 in 1998 (Guyer et al. 1999). Much of this improvement before and after 1980 has been from advances in medical interventions for the very smallest and sickest infants. Numerous studies have demonstrated associations between active maternal smoking and stillbirths (Meyer and Tonascia 1977; Kiely et al. 1986; Cnattingius 1992; Little and Weinberg 1993; Raymond et al. 1994) and neonatal and perinatal mortality (Comstock and Lundin 1967; Rush and Kass 1972; Cnattingius et al. 1988; Malloy et al. 1988; Schramm 1997). Even in the face of modern neonatal intensive care, numerous studies have demonstrated increased risks for neonatal mortality (death of a live-born infant within 28 days) (Cnattingius et al. 1988; Malloy et al. 1988; Schramm 1997), with reported ORs for infants of smokers around 1.2 compared with infants of non-smokers.

SIDS—or sudden, unexplained, unexpected death before one year of age—has been investigated in relation to fetal exposures to maternal smoking and the exposure of the infant to smoking by the mother and others during the postpartum period. Although social and behavioral risk factors for SIDS have been identified, the biologic mechanism is still unknown. Concerning smoking and SIDS, one proposed mechanism is chronic hypoxia—via elevated levels of carbon monoxide or reduced placental perfusion—affecting factors such as the normal development of the central nervous system (Bulterys et al. 1990). In animal studies designed to investigate neurotoxic effects, nicotine was found to target neurotransmitter receptors in the fetal brain, leading to reduced cell proliferation and, consequently, altered synaptic activity. The cholinergic and catecholaminergic systems and neurotransmitter pathways are affected acutely and, possibly, over the long term. Alterations in the peripheral autonomic pathways may lead to increased susceptibility to hypoxia-induced brain damage and SIDS (Slotkin 1998). In a study of newborns, the auditory arousal threshold for babies whose mothers smoked during pregnancy was greater than for those whose mothers did not smoke (Franco et al. 1999). Stick and colleagues (1996) observed the respiratory function of newborns in the hospital and reported lower function in infants of smokers compared with non-smokers. This observation suggests a fetal effect of smoking that continues beyond the postpartum period.

The death rate attributable to SIDS has declined by more than half over the last two decades; the SIDS rate in 1979 was 151.1 per 100,000 live births, and in 1998 the rate was 64 per 100,000 live births (Guyer et al. 1999). SIDS has decreased dramatically because of interventions such as the “Back to Sleep” campaign implemented in the 1990s. The diagnosis of SIDS, preferably by conducting an autopsy to exclude other causes, makes it a difficult outcome to study. Moreover, studies that examine maternal smoking during pregnancy may not be able to account for levels of postpartum smoking. In such studies (Malloy et al. 1992), the risk estimates for maternal smoking may be underestimated, since many women who quit or reduce the amount they smoke during pregnancy resume or increase their prepregnancy smoking levels after giving birth (Floyd et al. 1993; O’Campo et al. 1995).

Most studies have demonstrated that an increased risk of SIDS is associated with maternal smoking during pregnancy (Bergman and Wiesner 1976; Malloy et al. 1988; Kraus et al. 1989; McGlashan 1989; Bulterys et al. 1990; Haglund and Cnattinguis 1990; Mitchell et al. 1991; Schoendorf and Kiely 1992; MacDorman et al. 1997); adjusted ORs for mothers who smoked compared with nonsmokers ranged from 1.4 to 3.0 (Table 5.12). Some studies reported a dose-response relationship, comparing mothers who smoked 1 to 9 cigarettes with those who smoked 10 or more cigarettes per day (Haglund and Cnattinguis 1990; MacDorman et al. 1997). However, because very few smokers smoke only during pregnancy and not after delivery, it is nearly impossible to identify the risks associated only with prenatal exposure. Recent studies have begun to examine differences in the risk for SIDS between infants of women who smoke only after giving birth and infants of women who smoke both during pregnancy and after delivery (Mitchell et al. 1991; Schoendorf and Kiely 1992; Klonoff-Cohen 1997). These studies suggest that both prenatal and postpartum exposures to tobacco smoke increase the risk of SIDS. For infants exposed to tobacco only during the postpartum period, ORs were 2.4 (95 percent CI, 1.49–3.83) for blacks and 2.2 (95 percent CI, 1.29–3.78) for whites. For infants exposed during pregnancy and after delivery, ORs were 2.9 (95 percent CI, 2.12–4.07) for blacks and 4.07 (95 percent CI, 3.03–5.48) for whites (Schoendorf and Kiely 1992).

Table 5.12 Studies on the association between maternal smoking and infant mortality

Study | Study period | Population | Definition of smoking | Key results
Comstock and Lundin 1967 | 1953–1963 | 1,113 infants: 448 live-born infants, 234 still- births, and 431 deaths | Mothers were classified as non- smokers and smokers (smokers included those who abstained during pregnancy) | - Maternal smoking during pregnancy was associated with an increased risk of death for the child; - Findings indicate that some characteristics associated with smoking must be responsible for increased neonatal mortality rates rather than smoking per se; - Many of the increased hazards for children of smoking mothers appeared to be associated with decreased birth weight
Rush and Kass 1972 | 1961–1962 | 3,276 pregnant women | Smoked at least 1 cigarette daily | - Compared with all other groups, African American smokers had a perinatal mortality rate almost double that of white smokers, white nonsmokers, and African American nonsmokers; - African American smokers had an 86% excess mortality rate over African American nonsmokers; white smokers had an excess mortality rate of 11% compared with white nonsmokers; - African American smokers and African American women had infants of lower birth weight; African American women also had shorter gestation periods
Bergman and Wiesner 1976 | January 1970–February 1974 | 142 families: 56 who lost babies to SIDS^*^ and 86 control families | - Smoking habits of both parents were ascertained during and after pregnancy; - Maternal cigarette use was classified as none, <10, 10–19, or ≥20 cigarettes/day | - A higher proportion of mothers who lost their children to SIDS had smoked both during pregnancy (61 vs. 42%) and after their babies were born (59 vs. 37%) compared with mothers who did not smoke; - SIDS mothers smoked a significantly greater number of cigarettes than controls; - Exposure of infants to cigarette smoke (passive smoking) appears to enhance the risk of SIDS for reasons not known
Meyer and Tonascia 1977 | 1960–1961 | 51,490 singletons in 10 hospitals | None, <1 pack, or ≥1 pack/day | - Increases in smoking levels were associated with increases in the frequency of early fetal death and of neonatal deaths due to premature delivery; - These deaths were associated with smoking-related increases in the incidence of bleeding during pregnancy, abruptio placentae, placenta previa, and premature rupture of membranes
Cnattingius et al. 1988 | 1983–1985 | 281,808 births to mothers aged 15–44 years | - Nonsmokers (nondaily smokers); - 1–9 cigarettes/day; - ≥10 cigarettes/day | - Smokers aged <35 years had a RR^†^ of late fetal deaths ranging from 1.1 to 1.6, while the risk doubled if the mothers were aged ≥35 years and smoked; - Late fetal death rates would be reduced by 11% and early neonatal mortality by 5% if smoking could be eliminated from the pregnant population; - Smoking may be the most important preventable risk factor for late fetal deaths
Malloy et al. 1988 | 1979–1983 | 305,730 white live-born singletons, including 2,720 infant deaths | Maternal smoking status during pregnancy was classified as nonsmokers, smoked <1 pack/day or ≥1 pack/day | - The association of smoking was higher with postneonatal deaths than with neonatal deaths (adjusted OR^‡^ = 1.61 vs. 1.17); - The association with smoking varied by cause of death and was particularly high for respiratory diseases (OR = 3.4) and SIDS (OR = 1.9); - Findings indicate that respiratory deaths and SIDS deaths may be related to the effects on the infant of passive exposure to tobacco smoke after birth
Kraus et al. 1989 | 1959–1966 | 2,132 infants: 202 cases of SIDS^*^ and 1,930 controls who survived the first year of life | - Nonsmokers; - >10 cigarettes/day | - Maternal smoking, maternal aemia during pregnancy, and lack of early prenatal care were all positively associated with SIDS; - A positive trend in SIDS risks with increasing numbers of cigarettes smoked during pregnancy remained after adjusting for birth weights; - The unadjusted OR for maternal cigarette smoking during pregnancy was 1.6 (95% CI^§^, 1.1–2.5) for >10 cigarettes/day vs. nonsmoking; cigarette smoking was stratified under different categories for different analyses
McGlashan 1989 | 1980–1986 | 49,435 live infants | Maternal smoking classified as 0, <10 cigarettes/day, 11–20 cigarettes/day, and >20 cigarettes/day for each of the three categories: whether the mother was normally a smoker, whether she smoked during pregnancy, and whether she smoked during the baby’s first year of life | - Cigarette smoking by parents leading to passive exposures of the baby carried a high RR of SIDS (RR = 3.0); - If the mother was a habitual smoker, the risk of SIDS was very high (RR = 2.98); the risk was also very high if the mother smoked during pregnancy (RR = 3.32); - A dose-response relationship between cigarette smoking and increases in the risk of SIDS is suggested
Bulterys et al. 1990 | 1959–1966 | 2,123 infants: 193 cases of SIDS and 1,930 controls | Women were classified by the number of cigarettes/day during pregnancy (0, <10, or ≥10) | - Infants born to mothers who smoked ≥10 cigarettes/day and who were anemic during pregnancy were at a higher risk of SIDS than infants born to mothers who did not smoke and were not anemic (OR = 4.0 [95% CI, 2.1–7.4]); - Smoking ≥10 cigarettes/day vs. none increased the risk of SIDS by 70% among women with hematocrits >30%, but the risk increased threefold among women with hematocrits <30%; - A low hematocrit was not a risk factor for SIDS among nonsmokers, but became an important predictor among heavy smokers
Haglund and Cnattingius 1990 | 1983–1985 | 279,938 infants surviving the first week of life | - Nonsmokers: nondaily smokers; - Moderate smokers: 1–9 cigarettes/day; - Heavy smokers: ≥10 cigarettes/day | - Maternal smoking was strongly related to SIDS even while controlling for other risk factors; - Smoking ≤9 cigarettes/day doubled the risk of SIDS, and smoking ≥10 cigarettes/day tripled the risk of SIDS, compared with nonsmokers; - Early SIDS: 7 to 67 days; late SIDS: 68 to 145 days. Logistic regression of the difference between early and late SIDS (based only on SIDS cases) showed that moderate maternal smoking was strongly associated with an increased risk of early SIDS (RR = 1.7 [95% CI, 1.2–2.1])
Mitchell et al. 1991 | November 1987–October 1988 | 631 infants: 128 cases of SIDS and 503 controls | Maternal smoking was assessed by (1) obstetric records, where any amount of smoking was recorded as “yes,” and (2) parental interview that recorded whether the mother had smoked cigarettes in the last 2 weeks and if “yes,” the number of cigarettes/day | - Three risk factors were significantly associated with SIDS: maternal smoking, prone sleeping position of baby, and breastfeeding; - The ORs associated with maternal cigarette smoking, compared with no maternal smoking, were as follows: 1–9 cigarettes/day, OR = 1.87 (95% CI, 0.98–3.54); 10–19 cigarettes/day, OR = 2.64 (95% CI, 1.47–4.74); ≥20 cigarettes/day, OR = 5.06 (95% CI, 2.86–8.95); - These three risk factors may account for an estimated 79% of SIDS deaths
Cnattingius et al. 1992 | 1983–1987 | 173,715 nulliparous Nordic women aged ≥20 years who delivered singletons | - No smoking; - 1–9 cigarettes/day; - >9 cigarettes/day | - Women who were nonsmokers and those who had cohabited with the infant’s father had the lowest rates of late fetal and early neonatal deaths; - Delayed childbearing among nulliparous women with uncomplicated pregnancies was associated with increased risks of poor pregnancy outcomes
Malloy et al. 1992 | 1980–1985 | 2,271 infants: 757 cases of SIDS^*^ and 1,514 living controls | Packs of cigarettes/day | - In the Missouri study population, there was evidence of a dose-response relationship between smoking during pregnancy and the incidence of SIDS^*^; - Data from the National Institute of Child Health and Human Development did not support a dose- response relationship; - Neither data set supported a relationship between the age of occurrence of SIDS and smoking during pregnancy; - The benefits of promoting smoking reduction as a means of reducing the occurrence of SIDS remains to be determined
Schoendorf and Kiely 1992 | 1988 | 10,000 births and 6,000 infant deaths from a national maternal and infant health survey | - Nonexposed group: infants whose mothers did not report cigarette smoking either during pregnancy or at the time of the survey; - Passive exposure group: infants whose mothers reported smoking at the time of the survey but not during pregnancy; - Combined exposure group: infants whose mothers reported smoking at the time of the survey and during pregnancy | - Infants who died of SIDS were more likely to be exposed to maternal cigarette smoke than were surviving infants; - After adjusting for demographic risk factors, the OR for SIDS among normal birth weight infants was approximately 2 for passive exposure and 3 for combined exposures for both black and white infants; - The results suggest that both intrauterine and passive tobacco smoke exposures are associated with an increased risk of SIDS, and are further inducements to encourage smoking cessation among pregnant women and families with children
Little and Weinberg 1993 | 1980 | 4,667 births: 2,832 live- born infants and 1,835 stillbirths | Daily cigarette smoking during pregnancy (none, 1–19, 20–29, ≥30) | - Factors for mothers that appeared to increase the risks of a stillbirth were age ≥35 years, black race, smoking up to 29 cigarettes daily, first delivery, and high body mass; - Smoking 1–29 cigarettes was associated with an increased risk of stillbirth, but smoking ≥30 cigarettes/day appeared to be protective; - One possible explanation for the protective effect of heavy smoking could be that heavily exposed and susceptible fetuses die earlier and are lost before 28 weeks
Raymond et al. 1994 | 1983–1989 | 638,242 pregnancies >28 weeks of gestation in Nordic citizens aged >20 years | Women were nonsmokers, smoked 1–9 cigarettes/day, and ≥10 cigarettes/day | - Older women (aged ≥35 years), smokers, and nulliparous women had elevated risks of stillbirths; - There was a dose-response relationship between smoking and the risk of stillbirth, with the risk increasing with the number of cigarettes/day (1–9 cigarettes: OR = 1.2 [95% CI, 1.02–1.4]; ≥10 cigarettes: OR = 1.6 [95% CI, 1.4–1.8]); - The association between smoking and stillbirths is explained entirely by the higher incidence of growth retardation and placental complications in smokers
Klonoff-Cohen et al. 1995 | 1989–1992 | 400 parents of infants: 200 whose infants died of SIDS and 200 controls who delivered healthy infants | Smoking status of both parents and other live-in adults during pregnancy and after childbirth was ascertained to determine a child’s exposure to tobacco smoke | - Infants who died from SIDS were significantly more likely to be exposed to passive smoke from the mother (OR = 2.28), father (OR = 3.46), or other live-in adults (OR = 2.18) than were control infants; - A dose-response relationship was observed indicating an increase in the risk of SIDS associated with an increase in the child’s exposure to tobacco smoke in the first year of life; - Breastfeeding was protective against SIDS among nonsmokers (OR = 0.37) but not smokers (OR = 1.38)
Stick et al. 1996 | Data were not reported | 500 healthy infants of mothers participating in a cohort study | Mothers were never smokers, smoked <10 cigarettes/day, and ≥10 cigarettes/day | - In utero smoke exposure, a family history of asthma, and maternal hypertension during pregnancy were associated with reduced respiratory function after birth; - There was a significant dose-response relationship of maternal smoking on tPTEF/tEΔ; infants of mothers who smoked ≥10 cigarettes/day had the lowest mean tPTEF/tE, and infants of nonsmoking mothers had the highest
MacDorman et al. 1997 | United States: 1990–1991 Sweden: 1983–1992 | Linked birth and death records for more than 1 million infants | - Nonsmokers: nondaily smokers; - Moderate smokers: 1–9 cigarettes/day; - Heavy smokers: ≥10 cigarettes/day | - There was a strong association between maternal smoking and SIDS^*^ for mothers who smoked 1–9 cigarettes/day during pregnancy compared with nonsmokers (adjusted OR = 1.6–2.5), and for mothers who smoked ≥10 cigarettes/day during pregnancy (adjusted OR = 2.3–3.8); - SIDS rates increased with the amount smoked for all U.S. and Swedish racial and ethnic groups; - Smoking is one of the most important preventable risk factors for SIDS, and smoking prevention programs have the potential to substantially lower SIDS rates
Schramm 1997 | 1978–1990 | 176,843 women | Women were asked if they used tobacco during pregnancy (yes/no) and the number of cigarettes/day (0, <1 pack, ≥1 pack) | - The RR of low birth weight in the second pregnancy compared with not smoking during either pregnancy was 1.82 for those who smoked during the second pregnancy only and 1.87 for those who smoked during both pregnancies; - The highest risk of fetal mortality (RR = 1.79) occurred among mothers who did not smoke during the first pregnancy, but who smoked ≥1 pack/day during the second pregnancy; - Women with the highest RR (1.65) for neonatal deaths were those who reduced their smoking during the second pregnancy but did not stop

* SIDS = Sudden infant death syndrome.

† RR = Relative risk.

‡ OR = Odds ratio.

§ CI = Confidence interval.

Δ tPTEF/tE = Time to peak tidal expiratory flow as a proportion of expiratory time.

In a study containing more information about passive exposure to tobacco smoke, Klonoff-Cohen (1997) reported a dose-response relationship for post-partum smoking exposures even after adjusting for prenatal smoking levels of the mother. With one person smoking in the infant’s room, the OR for SIDS was 3.67 (95 percent CI, 1.66–8.13); two to four persons smoking in the infant’s room yielded an OR of 20.91 (95 percent CI, 4.02–108.7). These ORs should be interpreted cautiously given the wide CIs. A dose-response relationship was also demonstrated in this study for the number of cigarettes per day that the infant was exposed to during the postpartum period.

#### Child Physical and Cognitive Development

Strong associations between maternal smoking during pregnancy and adverse outcomes such as lowered birth weight and IUGR have prompted researchers to investigate the longer-term consequences of smoking during pregnancy on the physical growth and cognitive development of infants, children, and young adults. These studies are difficult to conduct, in part because of the need to consider multiple potential confounding factors that can intervene between pregnancy and the outcome of interest (e.g., family or environmental circumstances). Of particular concern is the effect of a continued exposure to passive smoking in the household on the developing infant or child. Although rates of reducing and quitting smoking during pregnancy are substantial, many women (approximately 70 percent) resume smoking once their infant is delivered (USDHHS 2001). Overpeck and Moss (1991) studied maternal smoking during pregnancy and the exposure to secondhand smoke of children aged five years and younger by mothers and other household members, and found that only 1.2 percent of children were exposed to tobacco smoke prenatally but not postpartum. Thus, a comparison group of infants who had been exposed to smoking during pregnancy but not after delivery is rarely available, making it difficult to attribute any observed effects to prenatal smoking alone.

The mechanisms by which maternal smoking during pregnancy may lead to compromised physical and cognitive development are not clear. However, regarding cognitive development, effects of smoking, and nicotine in particular, on central nervous system development have been proposed. Alterations in the peripheral autonomic pathways, mentioned earlier, may lead to an increased susceptibility to hypoxia-induced short-term and long-term brain damage (Slotkin 1998).

Several studies have examined the association between prenatal maternal smoking and subsequent physical growth of the infant or child, with mixed findings (Goldstein 1971; Rantakallio 1983; Barr et al. 1984; Fogelman and Manor 1988; Eskenazi and Bergman 1995) (Table 5.13). Goldstein (1971) observed the growth of approximately 15,000 seven-year-olds and reported that maternal smoking during pregnancy resulted in a 0.6 cm reduction in height after accounting for social class, birth weight, and gender. In a large birth cohort, Rantakallio (1983) observed a 0.4 to 0.6 cm reduction in height at 14 years of age in children of mothers who smoked compared with children whose mothers were nonsmokers. Neither study adjusted for postpartum smoking. Barr and colleagues (1984) examined associations between maternal smoking during pregnancy and infant size at eight months (weight, length, and head circumference) and reported no differences between infants of smokers and infants of nonsmokers. Fox and colleagues (1990) examined the growth of children at three years of age in relation to prenatal smoking; after adjusting for multiple confounders including postpartum smoking, they found no differences in height and weight. In a study of 2,622 children, Eskenazi and Bergman (1995) found that pregnancy serum cotinine levels when divided into low, medium, and high tertiles were associated with a −3 cm, −3 cm, and −8 cm reduction in the heights, respectively, of children of mothers who had smoked during pregnancy compared with children of non-smoking mothers. These authors reported that this effect was largely due to a prenatal exposure rather than to a postpartum secondhand smoke exposure.

Table 5.13 Studies on the association between maternal smoking and cognitive development, behavioral problems, and growth in children

Study | Study period | Population | Definition of smoking | Key results
Goldstein 1971 | 1958–1965 | 14,848 children aged 7 years | Smoking status after the fourth month of pregnancy:; - None; - Medium: 1–10 cigarettes/day; - Heavy: >10 cigarettes/day | - Nonsmoking mothers had children 0.6 cm taller than those of heavy smoking women; - If birth weight is excluded from the analysis, the difference in height between the two groups rises to 1.0 cm; - Smoking during pregnancy influences height partly by lowering the birth weight, and partly by an effect over and above its effect on birth weight
Rantakallio 1983 | 1966–1981 | 3,688 children: 1,844 had mothers who smoked during pregnancy and 1,844 controls | - Light smokers: smoked <10 cigarettes/day; - Heavy smokers: smoked ≥10 cigarettes/day at the end of the second month of pregnancy | - Children of smokers were more prone to respiratory diseases, were shorter, and did not perform as well in school compared with controls; - Smoking mothers differed from controls in social class and health status and were more often unemployed and without families. Even when these factors were taken into account, maternal smoking had an effect on the children’s physical and mental development
Barr et al. 1984 | NR^*^ | 453 infants 8 months of age | Average nicotine use was calculated by multiplying the number of cigarettes/day by nicotine content of the brand used by each woman | - Maternal smoking during pregnancy was not significantly related to infant size at 8 months; - At birth, nicotine exposure was more strongly associated with infant size than was alcohol exposure, but by 8 months most of the nicotine effects had dissipated and alcohol, not nicotine, remained significantly related to infant size at 8 months
Naeye and Peters 1984 | 1959–1976 | 9,024 children | - Nonsmokers; - Light smokers: 1–19 cigarettes/ day; - Heavy smokers: ≥20 cigarettes/ day | - Hyperactivity, short attention span, and lower scores on spelling and reading tests were more frequent for children whose mothers had smoked throughout pregnancy; - Cognitive abnormalities were mild, with achievement test scores only 2 to 4% lower in children whose mothers smoked during pregnancy; - Fetal hypoxemia may contribute to behavioral abnormalities in children of smokers
Fogelman and Manor 1988 | 1958–1981 | 8,200 young adults aged 23 years | Number of cigarettes/day smoked after the fourth month of pregnancy (0, 1–9, 10–19, ≥20) | - There was weak evidence for a relationship between smoking during pregnancy and self-reported heights of the offspring after several confounding variables were controlled for, but the article does not specify if the offspring are shorter or taller; - The average difference in height between children whose mothers smoked ≥20 cigarettes/day during the second half of pregnancy and those whose mothers did not was 0.93 cm in males and 1.83 cm in females; - The relation of smoking during pregnancy with educational achievements of the offspring, measured by the highest qualification achieved, was strong after controlling for confounding factors
Sexton et al. 1990 | NR | 364 children 3 years of age | - Women who smoked >10 cigarettes/day at the beginning of pregnancy were recruited and followed. At the eighth month, they were classified either as quitters or smokers; - Quitters quit smoking during the pregnancy; - Smokers smoked throughout the pregnancy | - Children whose mothers quit smoking compared with those whose mothers continued to smoke performed at a statistically significant higher level on cognitive tests; - Statistical adjustments for environmental factors, characteristics of the child, and fetal maturity did not account for these observed differences; - Findings suggest that quitting smoking after becoming pregnant may prevent some cognitive damage to the fetus
Bauman et al. 1991 | 1960–1967 | 19,044 children born to women enrolled in a health plan | - Whether the mother or her husband smoked cigarettes at the time of the examination; - Average number of cigarettes/ day by both parents | - Parental smoking was associated with children’s performance on at least one cognitive measure, and the effect persisted after the inclusion of controls; - Children of parents who were smokers but had quit by the time of the examination performed better than children whose smoking parents continued to smoke; - There was a dose-response relationship between parental smoking and cognitive performance
Fergusson and Lloyd 1991 | NR | A birth cohort of children followed for 12 years (1,265 at birth, reduced to 1,020 at 12 years due to attrition) | Maternal cigarette smoking during pregnancy was measured by an estimated typical daily cigarette use for each trimester (0, 1–10, 11–20, >20) | - Children whose mothers smoked during pregnancy scored significantly lower on standardized tests of intelligence, reading, and mathematical ability than children whose mothers did not smoke; - After adjusting for confounding covariates, there was no detectable relationship between maternal smoking and her child’s cognitive ability; - Results suggest that smoking does not have a causal effect on children’s cognitive ability, which may be influenced by the disadvantaged home environment from which these children come
Baghurst et al. 1992 | May 1979– May 1982 | 548 children from a cohort study | Nonsmokers had never smoked, or had smoked no more than five cigarettes during the pregnancy | - Differences in mean developmental test scores between children whose mothers smoked and those whose mothers did not smoke differed slightly; - The results were not statistically significant when adjusted for socioeconomic status, quality of home environment, and the mother’s intelligence, suggesting that social and environmental factors are major confounders of the association between exposure to maternal smoking and neuropsychological development in childhood
Weitzman et al. 1992 | 1979–1986 | NR | - Maternal smoking status: <1 pack/day or ≥1 pack/day; - Children’s exposure: prenatal only (mother smoked only during pregnancy); - Passive only (mother smoked only after pregnancy); - Prenatal plus passive | - Children’s behavior problems were associated with exposures to maternal cigarette smoking, with evidence suggesting a dose-response relationship; - Children whose mothers smoked both during and after pregnancy had 1.17 additional problems associated with smoking <1 pack/day and 2.04 additional problems associated with smoking ≥1 pack/day; - Children whose mothers smoked <1 pack/day were 1.41 times as likely to have extreme behavior problem scores and 1.54 times as likely if their mothers smoked ≥1 pack/day both during and after pregnancy
Fergusson et al. 1993 | 1977–1992 | 1,265 children | - During pregnancy: mean number of cigarettes/day during each trimester; - After pregnancy: estimated average daily cigarette use of the mother from the child’s birth to 5 years of age | - Children whose mothers smoked >20 cigarettes/day had mean problem behavior scores between 0.16 and 0.56 standard deviations higher than those of children whose mothers were nonsmokers; - Smoking after pregnancy was not significantly associated with increased rates of childhood problem behaviors; - Smoking during pregnancy may be associated with small but detectable increases in the risks of problem behaviors in childhood
Olds et al. 1994 | April 1978– September 1980 | 400 families: mothers and their children | Maternal prenatal smoking classified by cigarettes smoked/ day (0, 1–9, ≥10) | - Children whose mothers smoked ≥10 cigarettes/day during pregnancy had intellectual test scores that were 4.35 points lower (95% CI^†^, 0.02–8.68) than scores of children whose mothers did not smoke during pregnancy; - The greatest difference in children’s intellectual functioning was found in cigarette smoking measured at the end of pregnancy; - Maternal cigarette smoking during pregnancy poses a unique risk for neurodevelopmental impairment among children
Eskenazi and Bergmann 1995 | 1964–1967 | 2,622 women enrolled in a children’s health and development study | - Nonsmokers: women who had never smoked or had quit before pregnancy; - Smokers: number of cigarettes/ day (0, 1–9, 10–19, 20–29, ≥30) | - Children of mothers who were heavy smokers during pregnancy were shorter at 5 years of age than children of nonsmokers; - The effect appears to be attributable to in utero exposure rather than postnatal secondhand smoke exposure during early childhood; - The study was not able to demonstrate whether women who quit smoking during pregnancy can prevent long-term sequelae on growth
Eskenazi and Trupin 1995 | 1964–1967 | 2,124 children aged 5 years from a children’s health and development study | NR | - Children whose mothers smoked during pregnancy had somewhat higher adjusted Raven and PPVT (child cognitive development) scores than children of nonsmokers, although they did not differ in activity level; - Children who were exposed to tobacco smoke during childhood had lower adjusted Raven and PPVT scores and were rated more active by their mothers; the differences may be attributed to uncontrolled confounding of sociobehavioral factors; - The possibility that secondhand smoke smoke exposure during childhood may be more hazardous to neurodevelopment than prenatal exposure cannot be ruled out
Fried et al. 1997 | 1978 | 131 children aged 9–12 years with ascertained prenatal exposures to marijuana and cigarettes | - Smoking during pregnancy was measured by nicotine scores (average number of cigarettes/ day multiplied by the nicotine content of the specified brand); - Categorized as nonsmoking, light, or heavy (0 mg nicotine/ day, >0 but <16 mg nicotine/ day, and ≥16 mg nicotine/day; ≥16 mg nicotine/day = approximately 1 pack of cigarettes of average strength) | - There was a dose-dependent relationship between prenatal cigarette exposure and lower language and reading scores of the children; - Maternal exposure to secondhand smoke during pregnancy had no effect on either reading or language outcomes, whereas the child’s exposure to secondhand smoke adversely affected language but not reading
Obel et al. 1998 | 1991–1992 | 2,302 singletons without any disability born at a hospital in a 1-year period | - Nonsmoking; - 1–9 cigarettes/day; - 10–19 cigarettes/day; - ≥20 cigarettes/day | - There was a dose-response association between the number of cigarettes/day during pregnancy and babbling abilities of infants; - Smoking ≥10 cigarettes/day during pregnancy almost doubled the risk (OR^‡^ = 2.0 [95% CI, 1.1–3.6]) of the infant’s being a nonbabbler at 8 months of age; the risk was higher for children who were breastfed for less than 4 months (OR = 2.7 [95% CI, 1.3–5.8])
Kelmanson et al. 2002 | 1999–2000 | 250 singletons aged 2–4 months born during study period | - Maternal smoking during pregnancy (yes/no); - Maternal exposure during pregnancy to others who smoked (yes/no) | - Infants born to smoking mothers had a higher frequency of low birth weight (p = 0.031); - Smoking during pregnancy was significantly associated with the infant’s intensity of reactions (p = 0.0039); - There was no significant association between smoking during pregnancy and infant activity, rhythmicity, approachability, adaptability, mood, persistence, distractibility, and threshold

* NR = Data were not reported.

† CI = Confidence interval.

‡ OR = Odds ratio.

Studies examining associations between maternal smoking during pregnancy and the child’s cognitive development also have reported mixed results. Several studies reported associations with smoking during pregnancy and subsequent cognitive development, behavioral outcomes, and educational achievements of infants and children of varying ages (Rantakallio 1983; Naeye and Peters 1984; Sexton et al. 1990) (Table 5.13). Many studies adjusted for several potentially important confounders, and six reported a dose-response relationship (Fogelman and Manor 1988; Weitzman et al. 1992; McCartney et al. 1994; Fried et al. 1997, 1998; Obel et al. 1998) (Table 5.13). The outcomes examined in these studies were babbling abilities in eight-month-old infants, performances on standardized tests of cognitive abilities in school-age children, auditory processing in school-age children, behavioral problems as reported by parents and teachers, and educational achievements of young adults. A few studies had information on both pre-natal and postpartum smoking by mothers and parents; two of these studies reported that a prenatal but not a postpartum secondhand smoke exposure was associated with adverse outcomes (Weitzman et al. 1992; McCartney et al. 1994). Yet, in both studies, prenatal and postpartum smoking was significantly associated with adverse developmental outcomes. Many studies examined multiple outcomes, and not all were significantly associated with smoking during pregnancy. Overall, observed differences between smokers and nonsmokers were relatively small.

Three studies reported no association between maternal smoking during pregnancy and adverse cognitive or behavioral outcomes (Fergusson and Lloyd 1991; Baghurst et al. 1992; Eskenazi and Trupin 1995). Fergusson and Lloyd (1991) studied children aged 12 years and adjusted for several potential confounders, including postpartum smoke exposure. Once confounders were accounted for, no differences between children of mothers who smoked and children of mothers who did not smoke during their pregnancies were observed. In a study of more than 2,000 five-year-old children, Eskenazi and Trupin (1995) found that active smoking during pregnancy did not result in cognitive deficits in children according to results from the Raven Coloured Progressive Matrices Test and the Peabody Picture Vocabulary Test at five years of age. Thus, studies on cognitive development and behavioral problems report small or no differences among children of pregnant smokers compared with children of pregnant nonsmokers. Confounding by unmeasured factors cannot be ruled out as an explanation for the small differences, which may not be clinically meaningful.

### Evidence Synthesis

The evidence on the relationship between maternal smoking during pregnancy and congenital malformations is mixed. Most studies report no association between maternal smoking and congenital malformations as a whole. This finding is not unexpected, as it is unlikely that smoking during pregnancy would be linked to all of the multiple etiologic pathways involved in the various malformations.

For selected malformations, oral clefts in particular, several studies have reported positive associations with smoking. The biologic evidence on the etiology in general for oral clefts is scant, therefore making it difficult to establish a causal role of smoking. Recent studies on interactions between genes and the environment are contributing further to understanding the etiology of oral clefts and the role of smoking, but much work is still needed.

The data on maternal smoking and elevated rates of SIDS are abundant and consistent in the literature. However, evidence is not available to determine whether prenatal smoking alone is causally related to SIDS. Studies have demonstrated that prenatal smoking combined with postpartum passive exposure elevates the risk beyond that for a passive exposure to smoking alone. Some data on biologic plausibility are emerging. One hypothesized mechanism is that exposure to cigarette smoke during pregnancy has effects on the fetal respiratory system and the brain that may, in turn, contribute to SIDS.

Studies examining relationships between maternal smoking during pregnancy and subsequent physical growth of the child report mixed findings. Moreover, the magnitude of reported differences between children of smokers and nonsmokers, especially for physical growth, is extremely small. Information on the mechanisms by which the physical and cognitive development of children are affected by exposures to prenatal smoking is not available and potential confounding is a concern.

### Conclusions

1. The evidence is inadequate to infer the presence or absence of a causal relationship between maternal smoking and congenital malformations in general.
2. The evidence is suggestive but not sufficient to infer a causal relationship between maternal smoking and oral clefts.
3. The evidence is sufficient to infer a causal relationship between sudden infant death syndrome and maternal smoking during and after pregnancy.
4. The evidence is inadequate to infer the presence or absence of a causal relationship between maternal smoking and physical growth and neuro-cognitive development of children.

### Implications

Mothers who smoke increase their children’s risk of SIDS substantially; smoking during pregnancy and after the child’s birth should be a target for forceful and effective interventions. Future studies of smoking and congenital malformations should selectively build on the accumulating evidence of the few malformations for which there are elevated risks. Although further studies may elucidate the relationship between prenatal smoking and the risk of SIDS, and subsequent physical and cognitive development, study design issues may be too challenging to overcome. Specifically, the challenges are the identification of a sizable group of infants who are only exposed prenatally and the ability to adjust for the multiple confounders that may intervene between pregnancy and infant or child outcomes.

## Conclusions

Fertility

1. The evidence is inadequate to infer the presence or absence of a causal relationship between active smoking and sperm quality.

2. The evidence is sufficient to infer a causal relationship between smoking and reduced fertility in women.

Pregnancy and Pregnancy Outcomes

3. The evidence is suggestive but not sufficient to infer a causal relationship between maternal active smoking and ectopic pregnancy.

4. The evidence is suggestive but not sufficient to infer a causal relationship between maternal active smoking and spontaneous abortion.

5. The evidence is sufficient to infer a causal relationship between maternal active smoking and premature rupture of the membranes, placenta previa, and placental abruption.

6. The evidence is sufficient to infer a causal relationship between maternal active smoking and a reduced risk for preeclampsia.

7. The evidence is sufficient to infer a causal relationship between maternal active smoking and preterm delivery and shortened gestation.

8. The evidence is sufficient to infer a causal relationship between maternal active smoking and fetal growth restriction and low birth weight.

Congenital Malformations, Infant Mortality, and Child Physical and Cognitive Development

9. The evidence is inadequate to infer the presence or absence of a causal relationship between maternal smoking and congenital malformations in general.

10. The evidence is suggestive but not sufficient to infer a causal relationship between maternal smoking and oral clefts.

11. The evidence is sufficient to infer a causal relationship between sudden infant death syndrome and maternal smoking during and after pregnancy.

12. The evidence is inadequate to infer the presence or absence of a causal relationship between maternal smoking and physical growth and neuro-cognitive development of children.

## References

Alameda County Low Birth Weight Study Group. Cigarette smoking and the risk of low birth weight: a comparison in black and white women. Epidemiology. 1990;1(3):201-5. [pmid: 2081253].
Alderete E, Eskenazi B, Sholtz R. Effect of cigarette smoking and coffee drinking on time to conception. Epidemiology. 1995;6(4):403-8. [pmid: 7548349].
Ananth CV, Savitz DA, Luther ER. Maternal cigarette smoking as a risk factor for placental abruption, placenta previa, and uterine bleeding in pregnancy. American Journal of Epidemiology. 1996;144(9):881-9. [pmid: 8890666].
Andersen AN, Semczuk M, Tabor A. Prolactin and pituitary-gonadal function in cigarette smoking infertile patients. Andrologia. 1984;16(5):391-6. [pmid: 6437279].
Armstrong BG, McDonald AD, Sloan M. Cigarette, alcohol, and coffee consumption and spontaneous abortion. American Journal of Public Health. 1992;82(1):85-7. [pmid: 1536340].
Backe B. Maternal smoking and age: effect on birth-weight and risk for small-for-gestational-age births. Acta Obstetricia et Gynecologica Scandinavica. 1993;72(3):172-6. [pmid: 8385851].
Baghurst PA, Tong SL, Woodward A, McMichael AJ. Effects of maternal smoking upon neuropsychological development in early childhood: importance of taking account of social and environmental factors. Paediatric and Perinatal Epidemiology. 1992;6(4):403-15. [pmid: 1282258].
Baird DD, Wilcox AJ. Cigarette smoking associated with delayed conception. Journal of the American Medical Association. 1985;253(20):2979-83. [pmid: 3999259].
Bakketeig LS, Jacobsen G, Hoffman HJ, Lindmark G, Bergsjo P, Molne K, Rodsten J. Pre-pregnancy risk factors of small-for-gestational-age births among parous women in Scandinavia. Acta Obstetricia et Gynecologica Scandinavica. 1993;72(4):273-9. [pmid: 8389514].
Bardy AH, Seppälä T, Lillsunde P, Kataja JM, Koskela P, Pikkarainen J, Hiilesmaa VK. Objectively measured tobacco exposure during pregnancy: neonatal effects and relation to maternal smoking. British Journal of Obstetrics and Gynaecology. 1993;100(8):721-6. [pmid: 8399009].
Barr HM, Streissguth AP, Martin DC, Herman CS. Infant size at 8 months of age: relationship to maternal use of alcohol, nicotine, and caffeine during pregnancy. Pediatrics. 1984;74(3):336-41. [pmid: 6472964].
Barrett-Connor E, Khaw K-T. Cigarette smoking and increased endogenous estrogen levels in men. American Journal of Epidemiology. 1987;126(2):187-92. [pmid: 3605047].
Bauman KE, Flewelling RL, La Prelle J. Parental cigarette smoking and cognitive performance of children. Health Psychology. 1991;10(4):282-8. [pmid: 1915215].
Bergman AB, Wiesner LA. Relationship of passive cigarette-smoking to sudden infant death syndrome. Pediatrics. 1976;58(5):665-8. [pmid: 980599].
Bolumar F, Olsen J, Boldsen J. Smoking reduces fecundity: a European multicenter study on infertility and subfecundity. The European Study Group on Infertility and Subfecundity. American Journal of Epidemiology. 1996;143(6):578-87. [pmid: 8610675].
Bruner JP, Forouzan I. Smoking and buccally administered nicotine: acute effect on uterine and umbilical artery Doppler flow velocity waveforms. Journal of Reproductive Medicine. 1991;36(6):435-40. [pmid: 1865399].
Bulterys MG, Greenland S, Kraus JF. Chronic fetal hypoxia and sudden infant death syndrome: interaction between maternal smoking and low hematocrit during pregnancy. Pediatrics. 1990;86(4):535-40. [pmid: 2216618].
Butler NR, Goldstein H, Ross EM. Cigarette smoking in pregnancy: its influence on birth weight and perinatal mortality. British Medical Journal. 1972;2:127-30. [pmid: 5017304].
Chatterjee MS, Abdel-Rahman M, Bhandal A, Klein P, Bogden J. Amniotic fluid cadmium and thiocyanate in pregnant women who smoke. Journal of Reproductive Medicine. 1988;33(5):417-20. [pmid: 3385695].
Chelmow D, Andrew DE, Baker ER. Maternal cigarette smoking and placenta previa. Obstetrics and Gynecology. 1996;87(5 Pt 1):703-6. [pmid: 8677070].
Chia SE, Ong CN, Tsakok FMH. Effects of cigarette smoking on human semen quality. Archives of Andrology. 1994;33(3):163-8. [pmid: 7857167].
Close CE, Roberts PL, Berger RE. Cigarettes, alcohol and marijuana are related to pyospermia in infertile men. Journal of Urology. 1990;144(4):900-3. [pmid: 2398564].
Cnattingius S. Does age potentiate the smoking-related risk of fetal growth retardation?. Early Human Development. 1989;20(3–4):203-11. [pmid: 2606056].
Cnattingius S. Smoking during pregnancy: pregnancy risks and socio-demographic characteristics among pregnant smokers. International Journal of Technology Assessment in Health Care. 1992;88:91-5. [pmid: 1428652].
Cnattingius S, Forman MR, Berendes HW, Graubard BI, Isotalo L. Effect of age, parity, and smoking on pregnancy outcome: a population-based study. American Journal of Obstetrics and Gynecology. 1993;168(1 Pt 1):16-21. [pmid: 8420320].
Cnattingius S, Forman MR, Berendes HW, Isotalo L. Delayed childbearing and risk of adverse perinatal outcome: a population-based study. Journal of the American Medical Association. 1992;268(7):886-90. [pmid: 1640617].
Cnattingius S, Haglund B, Meirik O. Cigarette smoking as risk factor for late fetal and early neonatal death. British Medical Journal. 1988;297(6643):258-61. [pmid: 3416144].
Cnattingius S, Mills JL, Yuen J, Eriksson O, Salonen H. The paradoxical effect of smoking in preeclamptic pregnancies: smoking reduces the incidence but increases the rates of perinatal mortality, abruptio placentae, and intrauterine growth restriction. American Journal of Obstetrics and Gynecology. 1997;177(1):156-61. [pmid: 9240600].
Comstock GW, Lundin FE Jr. Parental smoking and perinatal mortality. American Journal of Obstetrics and Gynecology. 1967;98(5):708-18. [pmid: 6027701].
Coste J, Job-Spira N, Fernandez H. Increased risk of ectopic pregnancy with maternal cigarette smoking. American Journal of Public Health. 1991;81(2):199-201. [pmid: 1990859].
Cuckle HS, Alberman E, Wald NJ, Royston P, Knight G. Maternal smoking habits and Down’s syndrome. Prenatal Diagnosis. 1990a;10(9):561-7. [pmid: 2148372].
Cuckle HS, Wald NJ, Densem JW, Royston P, Knight GJ, Haddow JE, Palomaki GE, Canick JA. The effect of smoking in pregnancy on maternal serum alpha-fetoprotein, unconjugated oestriol, human chorionic gonandotrophin, progesterone and dehydro-pepiandrosterone sulphate levels. British Journal of Obstetrics and Gynaecology. 1990b;97:272-6. [pmid: 1692234].
Curtis KM, Savitz DA, Arbuckle TE. Effects of cigarette smoking, caffeine consumption, and alcohol intake on fecundability. American Journal of Epidemiology. 1997;146(1):32-41. [pmid: 9215221].
Dai WS, Gutai JP, Kuller LH, Cauley JA. Cigarette smoking and serum sex hormones in men. American Journal of Epidemiology. 1988;128(4):796-805. [pmid: 3421245].
Daling J, Weiss N, Spadoni L, Moore DE, Voigt L. Cigarette smoking and primary tubal infertility. Rosenberg MJ, editor. Smoking and Reproductive Health. Littleton (MA). PSG Publishing Company. 1987:40-6.
Davies JM, Latto IP, Jones JG, Veale A, Wardrop CAJ. Effects of stopping smoking for 48 hours on oxygen availability from the blood: a study on pregnant women. British Medical Journal. 1979;2:355-6. [pmid: 486931].
de Mouzon J, Spira A, Schwartz D. A prospective study of the relation between smoking and fertility. International Journal of Epidemiology. 1988;17(2):378-84. [pmid: 3403134].
DiFranza JR, Lew RA. Effect of maternal cigarette smoking on pregnancy complications and sudden infant death syndrome. Journal of Family Practice. 1995;40(4):385-94. [pmid: 7699353].
Dikshit RK, Buch JG, Mansuri SM. Effect of tobacco consumption on semen quality of a population of hypofertile males. Fertility and Sterility. 1987;48(2):334-6. [pmid: 3609347].
Dominguez-Rojas V, de Juanes-Pardo JR, Astasio-Arbiza P, Ortega-Molina P, Gordillo-Florencio E. Spontaneous abortion in a hospital population: are tobacco and coffee intake risk factors?. European Journal of Epidemiology. 1994;10(6):665-8. [pmid: 7672044].
D’Souza SW, Black P, Richards B. Smoking in pregnancy: associations with skinfold thickness, maternal weight gain, and fetal size at birth. British Medical Journal. 1981;282(6277):1661-3. [pmid: 6786420].
Elenbogen A, Lipitz S, Mashiach S, Dor J, Levran D, Ben-Rafael Z. The effect of smoking on the outcome of in-vitro fertilization—embryo transfer. Human Reproduction. 1991;6(2):242-4. [pmid: 2056020].
Ellard GA, Johnstone FD, Prescott RJ, Ji-Xian W, Jian-Hua M. Smoking during pregnancy: the dose dependence of birthweight deficits. British Journal of Obstetrics and Gynaecology. 1996;103(8):806-13. [pmid: 8760712].
El-Nemr A, Al-Shawaf T, Sabatini L, Wilson C, Lower AM, Grudzinskas JG. Effect of smoking on ovarian reserve and ovarian stimulation in in-vitro fertilization and embryo transfer. Human Reproduction. 1998;13(8):2192-8. [pmid: 9756295].
English P, Eskenazi B, Christianson RE. Black-white differences in serum cotinine levels among pregnant women and subsequent effects on infant birth-weight. American Journal of Public Health. 1994;84(9):1439-43. [pmid: 8092368].
Eskenazi B, Bergmann JJ. Passive and active maternal smoking during pregnancy, as measured by serum cotinine, and postnatal smoke exposure. I: effects on physical growth at age 5 years. American Journal of Epidemiology. 1995;142(9 Suppl):S10-S18.
Eskenazi B, Fenster L, Sidney S. A multivariate analysis of risk factors for preeclampsia. Journal of the American Medical Association. 1991;266(2):237-41. [pmid: 2056625].
Eskenazi B, Gold EB, Lasley BL, Samuels SJ, Hammond SK, Wight S, O’Neill Rasor M, Hines CJ, Schenker MB. Prospective monitoring of early fetal loss and clinical spontaneous abortion among female semiconductor workers. American Journal of Industrial Medicine. 1995a;28(6):833-46. [pmid: 8588567].
Eskenazi B, Prehn AW, Christianson RE. Passive and active maternal smoking as measured by serum cotinine: the effect on birthweight. American Journal of Public Health. 1995b;85(3):395-8. [pmid: 7892926].
Eskenazi B, Trupin LS. Passive and active maternal smoking during pregnancy, as measured by serum cotinine, and postnatal smoke exposure. II: effects on neurodevelopment at age 5 years. American Journal of Epidemiology. 1995;142(9 Suppl):S19-S29.
Evans HJ, Fletcher J, Torrance M, Hargreave TB. Sperm abnormalities and cigarette smoking. Lancet. 1981;1(8221):627-9. [pmid: 6110860].
Fergusson DM, Horwood LJ, Lynskey MT. Maternal smoking before and after pregnancy: effects on behavioral outcomes in middle childhood. Pediatrics. 1993;92(6):815-22. [pmid: 8233743].
Fergusson DM, Lloyd M. Smoking during pregnancy and its effects on child cognitive ability from the ages of 8 to 12 years. Paediatric and Perinatal Epidemiology. 1991;5(2):189-200. [pmid: 2052481].
Ferraz EM, Gray RH, Cunha TM. Determinants of preterm delivery and intrauterine growth retardation in north-east Brazil. International Journal of Epidemiology. 1990;19(1):101-8. [pmid: 2351503].
Field AE, Colditz GA, Willett WC, Longcope C, McKinlay JB. The relation of smoking, age, relative weight, and dietary intake to serum adrenal steroids, sex hormones, and sex hormone-binding globulin in middle-aged men. Journal of Clinical Endocrinology and Metabolism. 1994;79(5):1310-6. [pmid: 7962322].
Floyd RL, Rimer BK, Giovino GA, Mullen PD, Sullivan SE. A review of smoking in pregnancy: effects on pregnancy outcomes and cessation efforts. Annual Review of Public Health. 1993;14:379-411.
Fogelman KR, Manor O. Smoking in pregnancy and development into early adulthood. British Medical Journal. 1988;297(6658):1233-6. [pmid: 3145063].
Fox NL, Sexton M, Hebel JR. Prenatal exposure to tobacco. I: effects on physical growth at age three. International Journal of Epidemiology. 1990;19(1):66-71. [pmid: 2351526].
Franco P, Groswasser J, Hassid S, Lanquart JP, Scaillet S, Kahn A. Prenatal exposure to cigarette smoking is associated with a decrease in arousal in infants. Journal of Pediatrics. 1999;135(1):34-8. [pmid: 10393601].
French JI, McGregor JA. The pathobiology of premature rupture of membranes. Seminars in Perinatology. 1996;20(5):344-68. [pmid: 8912989].
Fried PA, Watkinson B, Gray R. Differential effects on cognitive functioning in 9- to 12-year olds prenatally exposed to cigarettes and marihuana. Neuro-toxicology and Teratology. 1998;20(3):293-306.
Fried PA, Watkinson B, Siegel LS. Reading and language in 9- to 12-year olds prenatally exposed to cigarettes and marijuana. Neurotoxicology and Teratology. 1997;19(3):171-83. [pmid: 9200137].
Godfrey B. Sperm morphology in smokers [letter]. Lancet. 1981;1(8226):948. [pmid: 6112354].
Goldstein H. Factors influencing the height of seven year old children—results from the National Child Development Study. Human Biology. 1971;43(1):92-111. [pmid: 5090319].
Guyer B, Freedman MA, Strobino DM, Sondik EJ. Annual summary of vital statistics: trends in the health of Americans during the 20th century. Pediatrics. 2000;106(6):1307-17. [pmid: 11099582].
Guyer B, Hoyert DL, Martin JA, Ventura SJ, Mac-Dorman MF, Strobino DM. Annual summary of vital statistics—1998. Pediatrics. 1999;104(6):1229-46. [pmid: 10585972].
Haddow JE, Knight GJ, Palomaki GE, Kloza EM, Wald NJ. Cigarette consumption and serum cotinine in relation to birthweight. British Journal of Obstetrics and Gynaecology. 1987;94(7):678-81. [pmid: 3620415].
Haddow JE, Palomaki GE, Holman MS. Young maternal age and smoking during pregnancy as risk factors for gastroschisis. Teratology. 1993;47(3):225-8. [pmid: 8475465].
Haglund B, Cnattingius S. Cigarette smoking as a risk factor for sudden infant death syndrome: a population-based study. American Journal of Public Health. 1990;80(1):29-32. [See also erratum in American Journal of Public Health 1992;82(11):1489.]. [pmid: 2293799].
Handelsman DJ, Conway AJ, Boylan LM, Turtle JR. Testicular function in potential sperm donors: normal ranges and the effects of smoking and varicocele. International Journal of Andrology. 1984;7(5):369-82. [pmid: 6441782].
Handler A, Davis F, Ferre C, Yeko T. The relationship of smoking and ectopic pregnancy. American Journal of Public Health. 1989;79(9):1239-42. [pmid: 2764200].
Handler AS, Mason ED, Rosenberg DL, Davis FG. The relationship between exposure during pregnancy to cigarette smoking and cocaine use and placenta previa. American Journal of Obstetrics and Gynecology. 1994;170(3):884-9. [pmid: 8141221].
Harger JH, Hsing AW, Tuomala RE, Gibbs RS, Mead PB, Eschenbach DA, Knox GE, Polk BF. Risk factors for preterm premature rupture of fetal membranes: a multicenter case-control study. American Journal of Obstetrics and Gynecology. 1990;163(1 Pt 1):130-7. [pmid: 2197863].
Harrison GG, Branson RS, Vaucher YE. Association of maternal smoking with body composition of the newborn. American Journal of Clinical Nutrition. 1983;38(5):757-62. [pmid: 6637868].
Hemminki K, Matanen P, Saloniemi I. Smoking and the occurrence of congenital malformations and spontaneous abortions: multivariate analysis. American Journal of Obstetrics and Gynecology. 1983;145(1):61-6. [pmid: 6849345].
Holt PG. Immune and inflammatory function in cigarette smokers. Thorax. 1987;42(4):241-9. [pmid: 3303428].
Holzki G, Gall H, Hermann J. Cigarette smoking and sperm quality. Andrologia. 1991;23(2):141-4. [pmid: 1952119].
Hook EB, Cross PK. Cigarette smoking and Down syndrome. American Journal of Human Genetics. 1985;37(6):1216-24. [pmid: 2934980].
Hopkins RS, Tyler LE, Mortensen BK. Effects of maternal cigarette smoking on birth weight and preterm birth—Ohio, 1989. Morbidity and Mortality Weekly Report. 1990;39(38):662-5. [pmid: 2118982].
Howe G, Westhoff C, Vessey M, Yeates D. Effects of age, cigarette smoking, and other factors on fertility: findings in a large prospective study. British Medical Journal (Clinical Research Edition). 1985;290(6483):1697-700.
Hoyme HE, Jones MC, Jones KL. Gastroschisis: abdominal wall disruption secondary to early gestational interruption of the omphalomesenteric artery. Seminars in Perinatology. 1983;7(4):294-8. [pmid: 6229032].
Hughes E, Brennan BG. Does cigarette smoking impair natural or assisted fecundity?. Fertility and Sterility. 1996;66(5):679-89. [pmid: 8893667].
Hughes EG, YoungLai EV, Ward SM. Cigarette smoking and outcomes of in-vitro fertilization and embryo transfer: a prospective cohort study. Human Reproduction. 1992;7(3):358-61. [pmid: 1587943].
Hull MGR, North K, Taylor H, Farrow A, Ford WCL. Avon Longitudinal Study of Pregnancy and Childhood Study Team. Delayed conception and active and passive smoking. Fertility and Sterility. 2000;74(4):725-33. [pmid: 11020514].
Hwang S, Beaty TH, Panny SR, Street NA, Joseph JM, Gordon S, McIntosh I, Franceomano CA. Association study of transforming growth factors alpha (TGF alpha) TaqI polymorphism and oral clefts: indication of gene-environment interaction in a population-based sample of infants with birth defects. American Journal of Epidemiology. 1995;141(7):629-36. [pmid: 7702037].
Joesbury KA, Edirisinghe WR, Phillips MR, Yovich JL. Evidence that male smoking affects the likelihood of a pregnancy following IVF treatment: application of the modified cumulative embryo score. Human Reproduction. 1998;13(6):1506-13. [pmid: 9688383].
Joffe M, Li Z. Male and female factors in fertility. American Journal of Epidemiology. 1994;140(10):921-9. [pmid: 7977279].
Kalandidi A, Doulgerakis M, Tzonou A, Hsieh CC, Aravandinos D, Trichopoulos D. Induced abortions, contraceptive practices, and tobacco smoking as risk factors for ectopic pregnancy in Athens, Greece. British Journal of Obstetrics and Gynaecology. 1991;98(2):207-13. [pmid: 2004058].
Källén K. Down’s syndrome and maternal smoking in early pregnancy. Genetic Epidemiology. 1997a;14(1):77-84. [pmid: 9055063].
Källén K. Maternal smoking and orofacial clefts. Cleft Palate-Craniofacial Journal. 1997b;34(1):11-16. [pmid: 9003906].
Källén K. Maternal smoking, body mass index and neural tube defects. American Journal of Epidemiology. 1998;147(12):1103-11. [pmid: 9645788].
Kelmanson IA, Erman LV, Litvina SV. Maternal smoking during pregnancy and behavioural characteristics in 2–4-month-old infants. Klinische Pädiatrie. 2002;214(6):359-64.
Kelsey JL, Dwyer T, Holford TR, Bracken MB. Maternal smoking and congenital malformations: an epidemiological study. Journal of Epidemiology and Community Health. 1978;32(2):102-7. [pmid: 355285].
Khoury MJ, Weinstein A, Panny S, Holtzman NA, Lindsay PK, Farrel K, Eisenberg M. Maternal cigarette smoking and oral clefts: a population-based study. American Journal of Public Health. 1987;77(5):623-5. [pmid: 3565662].
Kiely JL, Paneth N, Susser M. An assessment of the effects of maternal age and parity in different components of perinatal mortality. American Journal of Epidemiology. 1986;123(3):444-54. [pmid: 3946390].
Klaiber EL, Broverman DM. Dynamics of estradiol and testosterone and seminal fluid indexes in smokers and nonsmokers. Fertility and Sterility. 1988;50(4):630-4. [pmid: 3169284].
Kline J, Levin B, Kinney A, Stein Z, Susser M, Warburton D. Cigarette smoking and spontaneous abortion of known karyotype: precise data but uncertain inferences. American Journal of Epidemiology. 1995;141(5):417-27. [pmid: 7879786].
Kline J, Stein ZA, Susser M, Warburton D. Smoking: a risk factor for spontaneous abortion. New England Journal of Medicine. 1977;297(15):793-6. [pmid: 895818].
Klonoff-Cohen H. Sleep position and sudden infant death syndrome in the United States. Epidemiology. 1997;8(3):327-9. [pmid: 9115033].
Klonoff-Cohen H, Edelstein S, Savitz D. Cigarette smoking and preeclampsia. Obstetrics and Gynecology. 1993;81(4):541-4. [pmid: 8459962].
Klonoff-Cohen HS, Edelstein SL, Lefkowitz ES, Srinivasan IP, Kaegi D, Chang JC, Wiley KJ. The effect of passive smoking and tobacco exposure through breast milk on sudden infant death syndrome. Journal of the American Medical Association. 1995;273(10):795-8. [pmid: 7861574].
Kramer MD, Taylor V, Hickok DE, Daling JR, Vaughan TL, Hollenbach KA. Maternal smoking and placenta previa. Epidemiology. 1991;2(3):221-3. [pmid: 2054407].
Kraus JF, Greenland S, Bulterys M. Risk factors for sudden infant death syndrome in the US Collaborative Perinatal Project. International Journal of Epidemiology. 1989;18(1):113-20. [pmid: 2722353].
Kulikauskas V, Blaustein D, Ablin RJ. Cigarette smoking and its possible effects on sperm. Fertility and Sterility. 1985;44(4):526-8. [pmid: 4054326].
Lambers DS, Clark KE. The maternal and fetal physiologic effects of nicotine. Seminars in Perinatology. 1996;20(2):115-26. [pmid: 8857697].
Laurent SL, Thompson SJ, Addy C, Garrison CZ, Moore EE. An epidemiologic study of smoking and primary infertility in women. Fertility and Sterility. 1992;57(3):565-72. [pmid: 1740199].
Lehtovirta P, Forss M. The acute effect of smoking on intervillous blood flow of the placenta. British Journal of Obstetrics and Gynaecology. 1978;85:729-31. [pmid: 708655].
Lewin A, Gonen O, Orvieto R, Schenker JG. Effect of smoking on concentration, motility and zona-free hamster test on human sperm. Archives of Andrology. 1991;27(1):51-4. [pmid: 1772308].
Li CQ, Windsor RA, Perkins L, Goldenberg RL, Lowe JB. The impact on infant birth weight and gestational age of cotinine-validated smoking reduction during pregnancy. Journal of the American Medical Association. 1993;269(12):1519-24. [pmid: 8445814].
Li DK, Mueller BA, Hickok DE, Daling JR, Fantel AG, Checkoway HW, Weiss NS. Maternal smoking during pregnancy and the risk of congenital urinary tract anomalies. American Journal of Public Health. 1996;86(2):249-53. [pmid: 8633746].
Lieberman E, Gremy I, Lang JM, Cohen AP. Low birth-weight at term and the timing of fetal exposure to maternal smoking. American Journal of Public Health. 1994;84(7):1127-31. [pmid: 8017537].
Little RE, Weinberg CR. Risk factors for antepartum and intrapartum stillbirth. American Journal of Epidemiology. 1993;137(11):1177-89. [pmid: 8322759].
Longo FJ, Anderson E. The effects of nicotine on fertilization in the sea urchin, Arbacia punctulata. Journal of Cell Biology. 1970;46(2):308-25. [pmid: 4915452].
Lumley J. Stopping smoking. British Journal of Obstetrics and Gynaecology. 1987;94(4):289-92. [pmid: 3580311].
MacDorman MF, Cnattingius S, Hoffman HJ, Kramer MS, Haglund B. Sudden infant death syndrome and smoking in the United States and Sweden. American Journal of Epidemiology. 1997;146(3):249-57. [pmid: 9247009].
Mainous AG 3rd, Hueston WJ. The effect of smoking cessation during pregnancy on preterm delivery and low birthweight. Journal of Family Practice. 1994;38(3):262-6. [pmid: 8126407].
Malloy MH, Hoffman HJ, Peterson DR. Sudden infant death syndrome and maternal smoking. American Journal of Public Health. 1992;82(10):1380-2. [pmid: 1415865].
Malloy MH, Kleinman JC, Bakewell JM, Schramm WF, Land GH. Maternal smoking during pregnancy: no association with congenital malformations in Missouri 1980–83. American Journal of Public Health. 1989;79(9):1243-6. [pmid: 2764201].
Malloy MH, Kleinman JC, Land GH, Schramm WF. The association of maternal smoking with age and cause of infant death. American Journal of Epidemiology. 1988;128(1):46-55. [pmid: 3381835].
Marchbanks PA, Lee NC, Peterson HB. Cigarette smoking as a risk factor for pelvic inflammatory disease. American Journal of Obstetrics and Gynecology. 1990;162(3):639-44. [pmid: 2316564].
Marcoux S, Brisson J, Fabia J. The effect of cigarette smoking on the risk of preeclampsia and gestational hypertension. American Journal of Epidemiology. 1989;130(5):950-7. [pmid: 2816902].
Marshburn PB, Sloan CS, Hammond MG. Semen quality and association with coffee drinking, cigarette smoking, and ethanol consumption. Fertility and Sterility. 1989;52(1):162-5. [pmid: 2744185].
Martin JA, Hamilton BE, Ventura SJ, Menacker F, Park MM, Sutton PD. Births: final data for 2001. National Vital Statistics Report. 2002;51(2):1-103.
Martin TR, Bracken MB. Association of low birth weight with passive smoke exposure in pregnancy. American Journal of Epidemiology. 1986;124(4):633-42. [pmid: 3752056].
Matsunaga E, Shiota K. Ectopic pregnancy and myoma uteri: teratogenic effects and maternal characteristics. Teratology. 1980;21(1):61-9. [pmid: 7385056].
Mattison DR. The effects of smoking on fertility from gametogenesis to implantation. Environmental Research. 1982;28(2):410-33. [pmid: 6749489].
Mattison DR, Plowchalk DR, Meadows MJ, Miller MM, Malek A, London S. The effect of smoking on oogenesis, fertilization and implantation. Seminars in Reproductive Endocrinology. 1989;7(4):291-304.
McCartney JS, Fried PA, Watkinson B. Central auditory processing in school-age children prenatally exposed to cigarette smoke. Neurotoxicology and Teratology. 1994;16(3):269-76. [pmid: 7935260].
McDonald AD, Armstrong BG, Sloan M. Cigarette, alcohol, and coffee consumption and prematurity. American Journal of Public Health. 1992;82(1):87-90. [pmid: 1536341].
McGlashan ND. Sudden infant deaths in Tasmania, 1980–1986: a seven year prospective study. Social Science and Medicine. 1989;29(8):1015-26. [pmid: 2814572].
Meyer MB, Tonascia JA. Maternal smoking, pregnancy complications, and perinatal mortality. American Journal of Obstetrics and Gynecology. 1977;128(5):494-502. [pmid: 560121].
Mitchell EA, Scragg R, Stewart AW, Becroft DM, Taylor BJ, Ford RP, Hassall IB, Barry DM, Allen EM, Roberts AP. Results from the first year of the New Zealand cot death study. New Zealand Medical Journal. 1991;104(906):70-6.
Monica G, Lilja B. Placenta previa, maternal smoking and recurrence risk. Acta Obstetricia et Gynecologica Scandinavica. 1995;74(5):341-5. [pmid: 7778424].
Muscati SK, Koski KG, Gray-Donald K. Increased energy intake in pregnant smokers does not prevent human fetal growth retardation. Journal of Nutrition. 1996;126(12):2984-9. [pmid: 9001365].
Naeye RL, Peters EC. Mental development of children whose mothers smoked during pregnancy. Obstetrics and Gynecology. 1984;64(5):601-7. [pmid: 6493652].
O’Campo P, Davis MV, Gielen AC. Smoking cessation interventions for pregnant women: review and future directions. Seminars in Perinatology. 1995;19(4):279-85. [pmid: 8560293].
Obel C, Henriksen TB, Hedegaard M, Secher NJ, Ostergaard J. Smoking during pregnancy and babbling abilities of the 8-month-old infant. Paediatric and Perinatal Epidemiology. 1998;12(1):37-48. [pmid: 9483616].
Oldereid NB, Rui H, Clausen OPF, Purvis K. Cigarette smoking and human sperm quality assessed by laser–Doppler spectroscopy and DNA flow cytometry. Journal of Reproduction and Fertility. 1989;86(2):731-6. [pmid: 2760898].
Olds DL, Henderson CR Jr, Tatelbaum R. Intellectual impairment in children of women who smoke cigarettes during pregnancy. Pediatrics. 1994;93(2):221-7. [pmid: 8121734].
Overpeck MD, Moss AJ. Children’s exposure to environmental cigarette smoke before and after birth: health of our Nation’s children, United States, 1988. Advance Data. 1991;202:1-11. [pmid: 10111692].
Pattinson HA, Taylor PJ, Pattinson MH. The effect of cigarette smoking on ovarian function and early pregnancy outcome of in vitro fertilization treatment. Fertility and Sterility. 1991;55(4):780-3. [pmid: 2010004].
Peacock JL, Cook DG, Carey IM, Jarvis MJ, Bryant AE, Anderson HR, Bland JM. Maternal cotinine level during pregnancy and birthweight for gestational age. International Journal of Epidemiology. 1998;27(4):647-56. [pmid: 9758120].
Phillips RS, Tuomala RE, Feldblum PJ, Schachter J, Rosenberg MJ, Aronson MD. The effect of cigarette smoking, Chlamydia trachomatis infection, and vaginal douching on ectopic pregnancy. Obstetrics and Gynecology. 1992;79(1):85-90. [pmid: 1727593].
Rantakallio P. A follow-up study up to the age of 14 of children whose mothers smoked during pregnancy. Acta Paediatrica Scandinavica. 1983;72(5):747-53. [pmid: 6637474].
Ravenholt RT. Radioactivity in cigarette smoke [letter]. New England Journal of Medicine. 1982;307(5):312.
Raymond EG, Cnattingius S, Kiely JL. Effects of maternal age, parity, and smoking on the risk of stillbirth. British Journal of Obstetrics and Gynaecology. 1994;101(4):301-6. [pmid: 8199075].
Raymond EG, Mills JL. Placental abruption: maternal risk factors and associated fetal conditions. Acta Obstetricia et Gynecologica Scandinavica. 1993;72(8):633-9. [pmid: 8259750].
Rosevear SK, Holt DW, Lee TD, Ford WC, Wardle PG, Hull MG. Smoking and decreased fertilisation rates in vitro. Lancet. 1992;340(8829):1195-6. [pmid: 1359264].
Rowlands DJ, McDermott A, Hull MG. Smoking and decreased fertilisation rates in vitro. Lancet. 1992;340(8832):1409-10. [pmid: 1360109].
Rush D, Kass EH. Maternal smoking: a reassessment of the association with perinatal mortality. American Journal of Epidemiology. 1972;96(3):183-96. [pmid: 5070028].
Saaranen M, Suonio S, Kauhanen O, Saarikoski S. Cigarette smoking and semen quality in men of reproductive age. Andrologia. 1987;19(6):670-6. [pmid: 3434857].
Salafia C, Sheverick K. Cigarette smoking and pregnancy II: vascular effects. Placenta. 1999;20(4):273-9. [pmid: 10329347].
Sandahl B. Smoking habits and spontaneous abortion. European Journal of Obstetrics, Gynecology, and Reproductive Biology. 1989;31(1):23-31.
Saxen I. Cleft lip and palate in Finland: parental histories, course of pregnancy and selected environmental factors. International Journal of Epidemiology. 1974;3(3):263-70. [pmid: 4412458].
Schoendorf KC, Kiely JL. Relationship of sudden infant death syndrome to maternal smoking during and after pregnancy. Pediatrics. 1992;90(6):905-8. [pmid: 1437432].
Schramm WF. Smoking during pregnancy: Missouri longitudinal study. Paediatric and Perinatal Epidemiology. 1997;11(Suppl 1):73-83. [pmid: 9018717].
Seidman DS, Ever-Hadani P, Gale R. Effect of maternal smoking and age on congenital anomalies. Obstetrics and Gynecology. 1990;76(6):1046-50. [pmid: 2234712].
Sexton M, Fox NL, Hebel JR. Prenatal exposure to tobacco: II. Effects on cognitive functioning at age three. International Journal of Epidemiology. 1990;19(1):72-7. [pmid: 2351527].
Sexton M, Hebel JR. A clinical trial of change in maternal smoking and its effect on birth weight. Journal of the American Medical Association. 1984;251(7):911-5. [pmid: 6363731].
Shah NR, Bracken MB. A systematic review and meta-analysis of prospective studies on the association between maternal cigarette smoking and preterm delivery. American Journal of Obstetrics and Gynecology. 2000;182(2):465-72. [pmid: 10694353].
Sharara FI, Beatse SN, Leonardi MR, Navot D, Scott RT Jr. Cigarette smoking accelerates the development of diminished ovarian reserve as evidenced by the clomiphene citrate challenge test. Fertility and Sterility. 1994;62(2):257-62. [pmid: 8034069].
Shaw GM, Wasserman CR, Lammer EJ, O’Malley CD, Murray JC, Basart AM, Tolarova MM. Orofacial clefts, parental cigarette smoking, and transforming growth factor-alpha gene variants. American Journal of Human Genetics. 1996;58(3):551-61. [pmid: 8644715].
Shiono PH, Behrman RE. Low birth weight: analysis and recommendations. Future of Children. 1995;5(1):4-18. [pmid: 7633867].
Shiono PH, Klebanoff MA, Berendes HW. Congenital malformations and maternal smoking during pregnancy. Teratology. 1986a;34(1):65-71. [pmid: 3764779].
Shiono PH, Klebanoff MA, Rhoads GG. Smoking and drinking during pregnancy: their effects on preterm birth. Journal of the American Medical Association. 1986b;255(1):82-4. [pmid: 3940309].
Sibai BM, Gordon T, Thom E, Caritis SN, Klebanoff M, McNellis D, Paul RH. Risk factors for preeclampsia in healthy nulliparous women: a prospective multicenter study. The National Institute of Child Health and Human Development Network of Maternal-Fetal Medicine Units. American Journal of Obstetrics and Gynecology. 1995;172(2 Pt 1):642-8. [pmid: 7856699].
Sikorski R, Radomański T, Paszkowski T, Skoda J. Smoking during pregnancy and the perinatal cadmium burden. Journal of Perinatal Medicine. 1988;16(3):225-31. [pmid: 3210108].
Simon D, Preziosi P, Barrett-Connor E, Roger M, Saint-Paul M, Nahoul K, Papoz L. The influence of aging on plasma sex hormones in men: the Telecom Study. American Journal of Epidemiology. 1992;135(7):783-91. [pmid: 1595678].
Simpson WJ. A preliminary report on cigarette smoking and the incidence of prematurity. American Journal of Obstetrics and Gynecology. 1957;73(4):808-15.
Slotkin TA. Fetal nicotine or cocaine exposure: which one is worse?. Journal of Pharmacology and Experimental Therapeutics. 1998;285(3):931-45. [pmid: 9618392].
Spinillo A, Capuzzo E, Colonna L, Solerte L, Nicola S, Guaschino S. Factors associated with abruptio placentae in preterm deliveries. Acta Obstetricia et Gynecologica Scandinavica. 1994a;73(4):307-12. [pmid: 8160536].
Spinillo A, Capuzzo E, Egbe TO, Nicola S, Piazzi G, Baltaro F. Cigarette smoking in pregnancy and risk of pre-eclampsia. Journal of Human Hypertension. 1994b;8(10):771-5. [pmid: 7837214].
Spinillo A, Capuzzo E, Nicola SE, Colonna L, Egbe TO, Zara C. Factors potentiating the smoking-related risk of fetal growth retardation. British Journal of Obstetrics and Gynaecology. 1994c;101(11):954-8. [pmid: 7999725].
Spinillo A, Nicola S, Piazzi G, Ghazal K, Colonna L, Baltaro F. Epidemiological correlates of preterm premature rupture of membranes. International Journal of Gynaecology and Obstetrics. 1994d;47(1):7-15. [pmid: 7813758].
Stein Z, Kline J, Levin B, Susser M, Warburton D. Epidemiologic studies of environmental exposures in human reproduction. Berge CG, Maillie HD, editors. Measurement of Risks. New York. Plenum Press. 1981:163-83.
Stergachis A, Scholes D, Daling JR, Weiss NS, Chu J. Maternal cigarette smoking and the risk of tubal pregnancy. American Journal of Epidemiology. 1991;133(4):332-7. [pmid: 1822668].
Sterzik K, Strehler E, De Santo M, Trumpp N, Abt M, Rosenbusch B, Schneider A. Influence of smoking on fertility in women attending an in vitro fertilization program. Fertility and Sterility. 1996;65(4):810-4. [pmid: 8654644].
Stick SM, Burton PR, Gurrin L, Sly PD, LeSouëf PN. Effects of maternal smoking during pregnancy and a family history of asthma on respiratory function in newborn infants. Lancet. 1996;348(9034):1060-4. [pmid: 8874457].
Strobino D. Effects of smoking on women’s health. Grason HA, Hutchins JE, Silver GB, editors. Charting a Course for the Future of Women’s and Perinatal Health: Volume II—Reviews of Key Issues. Baltimore (MD). Johns Hopkins, School of Public Health, Women’s and Children’s Health Policy Center. 1999:253-69.
Substance Abuse and Mental Health Services Administration, Office of Applied Services. Year-End 2000 Emergency Department Data from the Drug Abuse Warning Network. DAWN Series D-18. Rockville (MD). U.S. Department of Health and Human Services, Substance Abuse and Mental Health Services Administration, Office of Applied Services. 2001. DHHS Publication No. (SMA) 01–3532.
Suonio S, Saarikoski S, Kauhanen O, Metsäpelto A, Terho J, Vohlonen I. Smoking does affect fecundity. European Journal of Obstetrics, Gynecology, and Reproductive Biology. 1990;34(1–2):89-95.
Tokuhata GK. Smoking in relation to infertility and fetal loss. Archives of Environmental Health. 1968;17(3):353-9. [pmid: 5673907].
Torfs CP, Velie EM, Oechsli FW, Bateson TF, Curry CJ. A population-based study of gastroschisis: demographic, pregnancy, and lifestyle risk factors. Teratology. 1994;50(1):44-53. [pmid: 7974254].
Trapp M, Kemeter P, Feichtinger W. Smoking and in-vitro fertilization. Human Reproduction. 1986;1(6):357-8. [pmid: 3558781].
Tuomivaara L, Ronnberg L. Ectopic pregnancy and infertility following treatment of infertile couples: a follow-up of 929 cases. European Journal of Obstetrics, Gynecology, and Reproductive Biology. 1991;42(1):33-8.
US Department of Health and Human Services. The Health Consequences of Smoking for Women A Report of the Surgeon General. Washington. U.S. Department of Health and Human Services, Public Health Service, Office of the Assistant Secretary for Health, Office on Smoking and Health. 1980.
US Department of Health and Human Services. Reducing the Health Consequences of Smoking: 25 Years of Progress A Report of the Surgeon General. Atlanta. U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, Center for Health Promotion and Education, Office on Smoking and Health. 1989. DHHS Publication No. (CDC) 89–8411.
US Department of Health and Human Services. The Health Benefits of Smoking Cessation A Report of the Surgeon General. Atlanta. U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health. 1990. DHHS Publication No. (CDC) 90–8416.
US Department of Health and Human Services. Women and Smoking A Report of the Surgeon General. Rockville (MD). U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health. 2001.
US Department of Health, Education, and Welfare. Smoking and Health: Report of the Advisory Committee to the Surgeon General of the Public Health Service. Washington. U.S. Department of Health, Education, and Welfare, Public Health Service. 1964. PHS Publication No. 1103.
US Department of Health, Education, and Welfare. The Health Consequences of Smoking 1969 Supplement to the 1967 Public Health Service Review. Washington. U.S. Department of Health, Education, and Welfare, Public Health Service. 1969.
US Department of Health, Education, and Welfare. The Health Consequences of Smoking A Report of the Surgeon General: 1971. Washington. U.S. Department of Health, Education, and Welfare, Public Health Service and Mental Health Administration. 1971. DHEW Publication No. (HSM) 71–7513.
US Department of Health, Education, and Welfare. The Health Consequences of Smoking A Report to the Surgeon General, 1973. Washington. U.S. Department of Health, Education, and Welfare, Public Health Service. 1973.
U.S. Department of Health, Education, and Welfare. The Health Consequences of Smoking 1977–1978. Rockville (MD). U.S. Department of Health, Education, and Welfare, Public Health Service, Office of the Assistant Secretary for Health, Office on Smoking and Health. 1978. DHEW Publication No. (PHS) 79–50065.
US Department of Health, Education, and Welfare. Smoking and Health A Report of the Surgeon General. Washington. U.S. Department of Health, Education, and Welfare, Public Health Service, Office of the Assistant Secretary for Health, Office on Smoking and Health. 1979. DHEW Publication No. (PHS) 79–50066.
Van den Eeden SK, Karagas MR, Daling JR, Vaughan TL. A case-control study of maternal smoking and congenital malformations. Paediatric and Perinatal Epidemiology. 1990;4(2):147-55. [pmid: 2362871].
Van Voorhis BJ, Dawson JD, Stovall DW, Sparks AE, Syrop CH. The effects of smoking on ovarian function and fertility during assisted reproduction cycles. Obstetrics and Gynecology. 1996;88(5):785-91. [pmid: 8885914].
Ventura SJ, Mosher WD, Curtin SC, Abma JC, Henshaw S. Trends in pregnancies and pregnancy rates by outcome: estimates for the United States, 1976–96. Vital and Health Statistics. 2000;21(56):1-47. [pmid: 10740440].
Vine MF. Smoking and male reproduction: a review. International Journal of Andrology. 1996;19(6):323-37. [pmid: 9051418].
Vine MF, Margolin BH, Morrison HI, Hulka BS. Cigarette smoking and sperm density: a meta-analysis. Fertility and Sterility. 1994;61(1):35-43. [pmid: 8293842].
Vogel W, Broverman DM, Klaiber EL. Gonadal, behavioral and electroencephalographic correlates of smoking. Remond A, Izard C, editors. Electro-physiological Effects of Nicotine. Amsterdam. Elsevier/North-Holland Biomedical Press. 1979:201-14.
Voigt LF, Hollenbach KA, Krohn MA, Daling JR, Hickok DE. The relationship of abruptio placentae with maternal smoking and small for gestational age infants. Obstetrics and Gynecology. 1990;75(5):771-4. [pmid: 2325962].
Wasserman CR, Shaw GM, O’Malley CD, Tolarova MM, Lammer EJ. Parental cigarette smoking and risk for congenital anomalies of the heart, neural tube, or limb. Teratology. 1996;53(4):261-7. [pmid: 8864168].
Weitzman M, Gortmaker S, Sobol A. Maternal smoking and behavior problems of children. Pediatrics. 1992;90(3):342-9. [pmid: 1518686].
Wen SW, Goldenberg RL, Cutter GR, Hoffman HJ, Cliver SP, Davis RO, Du Bard MB. Smoking, maternal age, fetal growth, and gestational age at delivery. American Journal of Obstetrics and Gynecology. 1990;162(1):53-8. [pmid: 2301517].
Werler MM. Teratogen update: smoking and reproductive outcomes. Teratology. 1997;55(5):382-8. [pmid: 9294884].
Werler MM, Lammer EJ, Rosenberg L, Mitchell AA. Maternal cigarette smoking during pregnancy in relation to oral clefts. American Journal of Epidemiology. 1990;132(5):926-32. [pmid: 2239907].
Werler MM, Mitchell AA, Shapiro S. Demographic, reproductive, medical, and environmental factors in relation to gastroschisis. Teratology. 1992;45(4):353-60. [pmid: 1533957].
Wilcox AJ. Birth weight and perinatal mortality: the effect of maternal smoking. American Journal of Epidemiology. 1993;137(10):1098-104. [pmid: 8317439].
Wilcox AJ, Weinberg CR, O’Connor JF, Baird DD, Schlatterer JP, Canfield RE, Armstrong EG, Nisula BC. Incidence of early loss of pregnancy. New Eng-land Journal of Medicine. 1988;319(4):189-94.
Williams MA, Lieberman E, Mittendorf R, Monson RR, Schoenbaum SC. Risk factors for abruptio placentae. American Journal of Epidemiology. 1991a;134(9):965-72. [pmid: 1951294].
Williams MA, Mittendorf R, Lieberman E, Monson RR, Schoenbaum SC, Genest DR. Cigarette smoking during pregnancy in relation to placenta previa. American Journal of Obstetrics and Gynecology. 1991b;165(1):28-32. [pmid: 1853910].
Williams MA, Mittendorf R, Stubblefield PG, Lieberman E, Schoenbaum SC, Monson RR. Cigarettes, coffee, and preterm premature rupture of the membranes. American Journal of Epidemiology. 1992;135(8):895-903. [pmid: 1585902].
Windham GC, Elkin EP, Swan SH, Waller KO, Fenster L. Cigarette smoking and effects on menstrual function. Obstetrics and Gynecology. 1999;93(1):59-65. [pmid: 9916957].
Windsor RA, Lowe JB, Perkins LL, Smith-Yoder D, Artz L, Crawford M, Amburgy K, Boyd NR Jr. Health education for pregnant smokers: its behavioral impact and cost benefit. American Journal of Public Health. 1993;83(2):201-6. [pmid: 8427323].
Wyszynski DF, Duffy DL, Beaty TH. Maternal cigarette smoking and oral clefts: a meta-analysis. Cleft Palate-Craniofacial Journal. 1997;34(3):206-10. [pmid: 9167070].
Zhang J, Fried DB. Relationship of maternal smoking during pregnancy to placenta previa. American Journal of Preventive Medicine. 1992;8(5):278-82. [pmid: 1419126].