# Abbreviations

AAA: abdominal aortic aneurysm
AAI: ankle-arm index
AANL: adult acute nonlymphocytic leukemia
ABI: ankle/brachial blood pressure index
ACS: American Cancer Society
ADT: aerodigestive tract
AF: attributable fraction
AGL: acute granulocytic leukemia
AHA: American Heart Association
AIDS: acquired immunodeficiency syndrome
ALL: acute lymphocytic leukemia
AMD: age-related macular degeneration
AML: acute myelocytic leukemia
ANCOVA: analysis of covariance
ANLL: acute nonlymphocytic leukemia
ANOVA: analysis of variance
AR: attributable risk
ARI: acute respiratory illness
ARIC: Atherosclerosis Risk in Communities Study
AZT: azidothymidine or zidovudine
BMC: bone mineral content
BMD: bone mineral density
BMI: body mass index
BRFSS: Behavioral Risk Factor Surveillance System
BUA: broadband ultrasound attenuation
CABG: coronary artery bypass graft
CAL: clinical attachment level
CDC: Centers for Disease Control and Prevention
CEJ: cemento-enamel junction
CGL: chronic granulocytic leukemia
CHD: coronary heart disease
CHF: congestive heart failure
CHS: Cardiovascular Health Study
CI: confidence interval
CLL: chronic lymphocytic leukemia
cm: centimeter
CML: chronic myelogenous leukemia
COLD: chronic obstructive lung disease
COPD: chronic obstructive pulmonary disease
CPITN: Community Periodontal Index of Treatment Needs
CPS-I: Cancer Prevention Study I
CPS-II: Cancer Prevention Study II
CT: computed tomography
CVD: cardiovascular disease
DALE: disability-adjusted life expectancy
DALYs: disability-adjusted life years
df: degrees of freedom
DFS: decayed or filled surfaces
DFT: decayed or filled teeth
DMF: decayed, missing, or filled teeth
DMFS: decayed, missing, or filled surfaces
DMFT: decayed, missing, or filled teeth
DNA: deoxyribonucleic acid
DR: diabetic retinopathy
DS: decayed surfaces
EBCT: electron beam computed tomography
ED: erectile dysfunction
EF: etiologic fraction
eNOS: endothelial nitric oxide synthase
EPA: Environmental Protection Agency
ER: estrogen receptor
ERT: estrogen replacement therapy
ETS: environmental tobacco smoke
FEF: forced expiratory flow
FEV_1_: forced expiratory volume in one second
FL: Flanders and Rothman model
FS: filled surfaces
FTC: Federal Trade Commission
FVC: forced vital capacity
g: gram
GSTM1: glutathione transferase classes mu
H. pylori: Helicobacter pylori
HBV: hepatitis B virus
HCFA: Health Care Financing Administration
HDL: high-density lipoprotein
Hg: mercury
HI: hemagglutination inhibition
HIV: human immunodeficiency virus
HMO: health maintenance organization
HPV: human papilloma virus
HR: hazard ratio
HRT: hormone replacement therapy
IARC: International Agency for Research on Cancer
ICD: International Classification of Diseases
IDF: incidence density fraction
Ig: immunoglobulin
IHD: ischemic heart disease
IL: interleukin
IMT: intimal-medial thickness
IOM: Institute of Medicine
IPF: idiopathic pulmonary fibrosis
IUGR: intrauterine growth retardation
IVF: in vitro fertilization
kg: kilogram
LBW: low birth weight
LDL: low-density lipoprotein
LL: log-linear model
LOH: loss of heterozygosity
LPA: loss of periodontal attachment
LRI: lower respiratory illness
MD: myelodysplasia
MeSH: Medical Subject Heading
mg: milligram
MI: myocardial infarction
mL: milliliter
mm: millimeter
MRFIT: Multiple Risk Factor Intervention Trial
MRI: magnetic resonance imaging
MS: missing surfaces
N: total population size
n: total sample size
NA: not applicable
NAEC: National Advisory Eye Council
NAT2: N-acetyltransferase 2
NCHS: National Center for Health Statistics
NCI: National Cancer Institute
NEI: National Eye Institute
ng: nanogram
NHANES: National Health and Nutrition Examination Survey
NHIS: National Health Interview Survey
NHLBI: National Heart, Lung, and Blood Institute
NIH: National Institutes of Health
NMES: National Medical Expenditures Survey
NMFS: National Mortality Followback Survey
NNK: nitrosamine 4-(methylnitrosamino)-1-(3-pyridyl)-1-butanone
NPT: nocturnal penile tumescence
NR: data were not reported
NRC: National Research Council
NS: not significant
NSAID: nonsteroidal anti-inflammatory drug
O/E: observed/expected
OR: odds ratio
OTA: Office of Technology Assessment
p: probability
PAH: polyaromatic hydrocarbon
PAR: population attributable risk
PBI: penile-brachial index
PDAY: Pathobiological Determinants of Atherosclerosis in Youth Study
PDR: proliferative diabetic retinopathy
PMN: polymorphonuclear neutrophilic leukocyte
POR: prevalence odds ratio
PPD: probing pocket depth
PR: progesterone receptor
PROM: premature rupture of membranes
PSA: prostate-specific antigen
QALYs: quality-adjusted life years
R^2^: prediction values
RDFS: root decayed or filled surfaces
RDS: respiratory distress syndrome
RDS: root decayed surfaces
REM: rapid eye movement
RH: relative hazard
RR: relative risk
RSV: respiratory syncytial virus
SAF: smoking attributable fraction
SAM: smoking attributable mortality
SAMMEC: Smoking-Attributable Mortality, Morbidity, and Economic Costs
SD: standard deviation
SE: standard error
SEER: Surveillance, Epidemiology, and End Results Program
SES: socioeconomic status
SGA: small for gestational age
SIDS: sudden infant death syndrome
SMR: standardized mortality ratio
SRD: smoking-related disease
SWI: surgical wound infections
TBARS: thiobarbituric acid reactive substances
TGF-: transforming growth factor alpha
Th: T-helper
TNF: tumor necrosis factor
TPA: tissue plasminogen activator
tPTEF/tE: the ratio of time to peak tidal expiratory flow to expiratory time
UC: ulcerative colitis
URI: upper respiratory illness
USDHEW: U.S. Department of Health, Education, and Welfare
USDHHS: U.S. Department of Health and Human Services
VEGF: vascular endothelial growth factor
VLBW: very low birth weight
VLDL: very low-density lipoprotein
V_max_FRC: maximal flow at functional residual capacity
vWF: von Willebrand factor
WHO: World Health Organization
YPLL: years of potential life lost
YRBS: Youth Risk Behavior Survey