# Acknowledgements

This Call to Action was prepared by the U.S. Department of Health and Human Services under the direction of the Office of the Surgeon General, the National Institute on Alcohol Abuse and Alcoholism, and the Substance Abuse and Mental Health Services Administration.

Rear Admiral Kenneth P. Moritsugu, M.D., M.P.H., Acting Surgeon General, United States Public Health Service, Office of the Surgeon General, Office of the Secretary, Department of Health and Human Services, Washington, D.C.

Richard H. Carmona, M.D., M.P.H., F.A.C.S., former Surgeon General, United States Public Health Service, Office of the Surgeon General, Office of the Secretary, Department of Health and Human Services, Washington, D.C.

Commander Karen A. Near, M.D., M.S., United States Public Health Service, Senior Science Advisor, Office of the Surgeon General, Office of the Secretary, Department of Health and Human Services, Washington, D.C.

Ron Schoenfeld, Ph.D., United States Public Health Service, Senior Science Advisor, Office of the Surgeon General, Office of the Secretary, Department of Health and Human Services, Washington, D.C.

Ting-Kai Li, M.D., Director, National Institute on Alcohol Abuse and Alcoholism, National Institutes of Health, Department of Health and Human Services, Bethesda, Maryland.

Rear Admiral Eric B. Broderick, D.D.S., M.P.H., United States Public Health Service, Acting Deputy Administrator, Substance Abuse and Mental Health Services Administration, Department of Health and Human Services, Rockville, Maryland.

## EDITORS OF THE REPORT

Patricia A. Powell, Ph.D., Senior Scientific Editor, Acting Chief, Science Policy Branch, Office of Science Policy and Communications, National Institute on Alcohol Abuse and Alcoholism, National Institutes of Health, Department of Health and Human Services, Bethesda, Maryland.

Vivian B. Faden, Ph.D., Senior Scientific Editor, Deputy Director, Division of Epidemiology and Prevention Research, National Institute on Alcohol Abuse and Alcoholism, National Institutes of Health, Department of Health and Human Services, Bethesda, Maryland.

Stephen Wing, M.S.W., Associate Administrator for Alcohol Policy, Substance Abuse and Mental Health Services Administration, Department of Health and Human Services, Rockville, Maryland.

## SCIENCE WRITER

Hamilton Beazley, Ph.D., Scholar-in-Residence, St. Edward's University, Austin, Texas.

## SCIENTIFIC REVIEWERS

Sandra Brown, Ph.D., Professor of Psychology and Psychiatry, Department of Psychology, University of California, San Diego, La Jolla, California.

Mark Goldman, Ph.D., Distinguished Research Professor and Director, Alcohol and Substance Use Research Institute, Department of Psychology, University of South Florida, Tampa, Florida.

Ralph Hingson, Sc.D., M.P.H., Director, Division of Epidemiology and Prevention Research Epidemiology, National Institute on Alcohol Abuse and Alcoholism, National Institutes of Health, Department of Health and Human Services, Bethesda, Maryland.

Ann Masten, Ph.D., Distinguished McKnight University Professor, Institute of Child Development, University of Minnesota, Minneapolis, Minnesota.

Howard Moss, M.D., Associate Director for Clinical and Translational Research, National Institute on Alcohol Abuse and Alcoholism, National Institutes of Health, Department of Health and Human Services, Bethesda, Maryland.

Mark Willenbring, M.D., Director, Division of Treatment and Recovery Research, National Institute on Alcohol Abuse and Alcoholism, National Institutes of Health, Department of Health and Human Services, Bethesda, Maryland.

## INTERAGENCY COORDINATING COMMITTEE ON THE PREVENTION OF UNDERAGE DRINKING (ICCPUD) REVIEWERS

Department of Education

Office of Safe and Drug-Free Schools

Department of Defense

Office of the Assistant Secretary of Defense (Health Affairs)

Department of Health and Human Services

Administration for Children and Families

Centers for Disease Control and Prevention

Health Resources and Services Administration

Indian Health Service

National Institute on Alcohol Abuse and Alcoholism,

National Institutes of Health

Office of the Assistant Secretary for Planning and Evaluation

Office of the Surgeon General

Substance Abuse and Mental Health Services Administration

Department of Justice

Office of Juvenile Justice and Delinquency Prevention

Department of Labor

Office of the Assistant Secretary for Policy

Department of Transportation

National Highway Traffic Safety Administration

Department of Treasury

Alcohol and Tobacco Tax and Trade Bureau

Office of National Drug Control Policy

Federal Trade Commission

## OTHER CONTRIBUTORS

More than 500 members of the general public who responded to the Surgeon General's request for comment in the Federal Register.