# References

Alcohol Research & Health. Alcohol and Disease Interactions. Vol. 25, No. 4, 2001.
Alcohol Research & Health. Alcohol Development and Youth: A Multidisciplinary Overview. Vol. 28, No. 3, 2004/2005.
American Psychiatric Association (APA). Diagnostic and Statistical Manual of Mental Disorders, 4th Edition. Washington, DC: APA, 1994.
American Psychiatric Association (APA). Diagnostic and Statistical Manual of Mental Disorders, 4th Edition, Text Revision. Washington, DC: APA, 2000.
Barnes G.M, Reifman A.S, Farrell M.P, et al. The effects of parenting on the development of adolescent alcohol misuse: A six-wave latent growth model. Journal of Marriage and Family. 2000;62:175-186.
Barr C.S, Schwandt M.L, Newman T.K, et al. The use of adolescent nonhuman primates to model human alcohol intake: Neurobiological, genetic, and psychological variables. Annals of the New York Academy of Sciences. 2004;1021:221-233. [pmid: 15251892].
Benson P, Leffert N, Scales P, et al. Beyond the “village” rhetoric: Creating healthy communities for children and adolescents. Applied Developmental Science. 1998;2:138-159.
Bogenschneider K, Wu M. Y, Raffaelli M, et al. Parent influences on adolescent peer orientation and substance use: The interface of parenting practices and values. Child Development. 1998;69:1672-1688. [pmid: 9914646].
Bray, R.M., Hourani, L.L., Olmsted, K.L.R., et al. 2005 Department of Defense Survey of Health Related Behaviors Among Military Personnel. Research Triangle Park, NC: RTI International, 2006. Available at http://www.ha.osd.mil/special_reports/2005_Health_ Behaviors_Survey_107.pdf.
Bronfenbrenner, U. The Ecology of Human Development. Cambridge, MA: Harvard University Press, 1979.
Brown, S.A. “A Double-Developmental Model of Adolescent Substance Abuse.” Paper presented at the Annual Scientific Meeting of the Research Society on Alcoholism, Santa Barbara, CA, 1999.
Brown, S.A. Facilitating change for adolescent alcohol problems: A multiple options approach. In: Wagner, E.F., and Waldron, H.B., eds. Innovations in Adolescent Substance Abuse Intervention. New York: Pergamon, 2001. pp. 169–187.
Brown, S.A., and Tapert, S.F. Health consequences of adolescent alcohol involvement. In: National Research Council and Institute of Medicine, Bonnie, R.J., and O'Connell, M.E., eds. Reducing Underage Drinking: A Collective Responsibility. Washington, DC: National Academies Press, 2004. pp. 383–401. Available online at: http://www.nap.edu/books/ 0309089352/html.
Brown S.A, Tapert S.F, Granholm E, et al. Neurocognitive functioning of adolescents: Effects of protracted alcohol use. Alcoholism: Clinical and Experimental Research. 2000;24:164-171.
Castillo Mezzich A, Giancola P.R, Lu S.Y, et al. Adolescent females with a substance use disorder: Affiliations with adult male sexual partners. American Journal on Addictions. 1999;8:190-200. [pmid: 10506900].
Catalano R.F, Haggerty K.P, Oesterle S, et al. The importance of bonding to school for healthy development: Findings from the Social Development Research Group. Journal of School Health. 2004;74:252-261. [pmid: 15493702].
Centers for Disease Control and Prevention (CDC) National Center for Injury Prevention and Control (NCIPC). Web-Based Injury Statistics Query and Reporting System (WISQARS) 2004. Available online at: http://www.cdc.gov/ncipc/wisqars/default.htm.
Chung T, Martin C.S. Classification and course of alcohol problems among adolescents in addictions treatment programs. Alcoholism: Clinical and Experimental Research. 2001;25:1734-1742.
Chung T, Martin C.S. What were they thinking? Adolescents' interpretations of DSMIV alcohol dependence symptom queries and implications for diagnostic validity. Drug and Alcohol Dependence. 2005;80:191-200. [pmid: 15894432].
Chung T, Martin C.S, Grella C.E, et al. Course of alcohol problems in treated adolescents. Alcoholism: Clinical and Experimental Research. 2003;27:253-261.
Chung, T., Martin, C.S., and Winters, K.C. Diagnosis, course, and assessment of alcohol abuse and dependence in adolescents. In: Galanter, M., ed. Recent Developments in Alcoholism, Vol. 17: Alcohol Problems in Adolescents and Young Adults: Epidemiology, Neurobiology, Prevention, Treatment. New York: Springer, 2005. pp. 5–27.
Coate D, Grossman M. Effects of alcoholic beverage prices and legal drinking ages on youth alcohol use. Journal of Law and Economics. 1988;31:145-171.
Colder C.R, Chassin L. The psychosocial characteristics of alcohol users versus problem users: Data from a study of adolescents at risk. Development and Psychopathology. 1999;11:321-348. [pmid: 16506537].
Cooper M.L, Orcutt H.K. Drinking and sexual experience on first dates among adolescents. Journal of Abnormal Psychology. 1997;106:191-202. [pmid: 9131839].
Cooper M.L, Pierce R.S, Huselid R.F. Substance use and sexual risk taking among black adolescents and white adolescents. Health Psychology. 1994;13:251-262. [pmid: 8055860].
Crews F.T, Braun C.J, Hoplight B, et al. Binge ethanol consumption causes differential brain damage in young adolescent rats compared with adult rats. Alcoholism: Clinical and Experimental Research. 2000;24:1712-1723.
Curran P.J, Stice E, Chassin L. The relation between adolescent alcohol use and peer alcohol use: A longitudinal random coefficients model. Journal of Consulting and Clinical Psychology. 1997;65:130-140. [pmid: 9103742].
Dahl R.E. Adolescent brain development: A period of vulnerabilities and opportunities. Keynote address. Annals of the New York Academy of Sciences. 2004;1021:1-22. [pmid: 15251869].
Dahl, R., and Hariri, A. “Frontiers of Research on Adolescent Decision Making— Contributions from the Biological, Behavioral, and Social Sciences.” Background paper prepared for the Planning Meeting on Adolescent Decision Making and Positive Youth Development: Applying Research to Youth Programs and Prevention Strategies, April 2004. National Research Council/Institute of Medicine Board on Children, Youth, and Families, Committee on Adolescent Health and Development.
Davies P.T, Windle M. Interparental discord and adolescent adjustment trajectories: The potentiating and protective role of intrapersonal attributes. Child Development. 2001;72:1161-1178.
De Bellis M.D, Clark D.B, Beers S.R, et al. Hippocampal volume in adolescent-onset alcohol use disorders. American Journal of Psychiatry. 2000;157:737-744. [pmid: 10784466].
DiClemente R.J, Wingood G.M, Crosby R, et al. Parental monitoring: Association with adolescents' risk behaviors. Pediatrics. 2001;107:1363-1368. [pmid: 11389258].
Dishion T.J, Duncan T.E, Eddy J.M, et al. The world of parents and peers: Coercive exchanges and children's social adaptation. Social Development. 1994;3:255-268.
Donovan J.E. Adolescent alcohol initiation: A review of psychosocial risk factors. Journal of Adolescent Health. 2004;35:529e7-529e18. [pmid: 15581536].
Donovan J.E, Leech S.L, Zucker R.A, et al. Really underage drinkers: Alcohol use among elementary students. Alcoholism: Clinical and Experimental Research. 2004;28:341-349.
Doremus T.L, Brunell S.C, Varlinskaya E.I, et al. Anxiogenic effects during withdrawal from acute ethanol in adolescent and adult rats. Pharmacology, Biochemistry, and Behavior. 2003;75:411-418.
Dunn M.E, Goldman M.S. Age and drinking-related differences in the memory organization of alcohol expectancies in 3rd, 6th, 9th, and 12th grade children. Journal of Consulting and Clinical Psychology. 1998;66:579-585. [pmid: 9642899].
Dunn M.E, Goldman M.S. Empirical modeling of an alcohol expectancy memory network in elementary school children as a function of grade. Experimental and Clinical Psychopharmacology. 1996;4:209-217.
Dunn M.E, Yniguez R.M. Experimental demonstration of the influence of alcohol advertising on the activation of alcohol expectancies in memory among fourth- and fifth-grade children. Experimental and Clinical Psychopharmacology. 1999;7:473-483. [pmid: 10609982].
Elliot, D.S., and Menard, S. Delinquent friends and delinquent behaviour: Temporal and developmental patterns. In: Hawkins, J.D., ed. Delinquency and Crime: Current Theories. Cambridge, England: Cambridge University Press, 1996. pp. 28–67.
Faden V.B. Trends in initiation of alcohol use in the United States 1975 to 2003. Alcoholism: Clinical and Experimental Research. 2006;30:1011-1022.
Fergusson D.M, Horwood L.J. The role of adolescent peer affiliations in the continuity between childhood behavioral adjustment and juvenile offending. Journal of Abnormal Child Psychology. 1996;24:205-221. [pmid: 8743245].
Fergusson D.M, Horwood L.J. Prospective childhood predictors of deviant peer affiliations in adolescence. Journal of Child Psychology and Psychiatry, and Allied Disciplines. 1999;40:581-592.
Gabel S, Stallings M.C, Schmitz S, et al. Personality dimensions and substance misuse: Relationships in adolescents, mothers and fathers. American Journal on Addictions. 1999;8:101-113. [pmid: 10365190].
Gauvain, M. The Social Context of Cognitive Development. New York: Guilford, 2001.
George S, Rogers R.D, Duka T. The acute effect of alcohol on decision making in social drinkers. Psychopharmacology. 2005;182:160-169. [pmid: 16032411].
Giedd J. Structural magnetic resonance imaging of the adolescent brain. Annals of the New York Academy of Sciences. 2004;1021:77-85. [pmid: 15251877].
Grant B.F, Dawson D.A. Age at onset of alcohol use and its association with DSMIV alcohol abuse and dependence: Results from the National Longitudinal Alcohol Epidemiologic Survey. Journal of Substance Abuse. 1997;9:103-110. [pmid: 9494942].
Grant B.F, Dawson D.A. Age at onset of drug use and its association with DSMIV drug abuse and dependence: Results from the National Longitudinal Alcohol Epidemiologic Survey. Journal of Substance Abuse. 1998;10:163-173. [pmid: 9854701].
Grant B.F, Dawson D.A, Stinson F.S, et al. The 12-month prevalence and trends in DSMIV alcohol abuse and dependence: United States, 1991-1992 and 2001-2002. Drug and Alcohol Dependence. 2004;74:223-234. [pmid: 15194200].
Grossman M, Chaloupka F.J, Sirtalan I. An empirical analysis of alcohol addiction: Results from the Monitoring the Future panels. Economic Inquiry. 1998;36:39-48.
Grossman, M., Coate, D., and Arluck, G.M. Price sensitivity of alcoholic beverages in the United States: Youth alcohol consumption. In: Holder, H.D., ed. Control Issues in Alcohol Abuse Prevention: Strategies for States and Communities. Greenwich, CT: JAI Press, 1987. pp. 169–198.
Grunbaum, J.A., Kann, L., Kinchen, S., et al. Youth risk behavior surveillance—United States, 2003. MMWR Surveillance Summaries: Morbidity and Mortality Weekly Report Summary 53(2):1–96, May 21, 2004. Errata in MMWR Morbidity and Mortality Weekly Report 53(24):536, June 25 2004; 54(24):608, June 24, 2005.
Hawkins J.D, Catalano R.F, Miller J.Y. Risk and protective factors for alcohol and other drug problems in adolescence and early adulthood: Implications for substance abuse prevention. Psychological Bulletin. 1992;112:64-105. [pmid: 1529040].
Hawkins J.D, Graham J.W, Maguin E, et al. Exploring the effects of age of alcohol initiation and psychosocial risk factors on subsequent alcohol misuse. Journal of Studies on Alcohol. 1997;58:280-290. [pmid: 9130220]. [pmcid: 1894758].
Hibell, B., Andersson, B., and Bjarnasson, T., et al. The ESPAD Report 2003: Alcohol and Other Drug Use Among Students in 35 European Countries. Stockholm, Sweden: Modintrickoffset AB, 2004. Available online at: http://www.monitoringthefuture.org/pubs/espadusa2003.pdf.
Hingson R, Heeren T, Jamanka A, et al. Age of drinking onset and unintentional injury involvement after drinking. JAMA. 2000;284:1527-1533. [pmid: 11000646].
Hingson R, Heeren T, Levenson S, et al. Age of drinking onset, driving after drinking, and involvement in alcoholrelated motor vehicle crashes. Accident Analysis and Prevention. 2002;34:85-92. [pmid: 11789578].
Hingson R, Heeren T, Winter M, et al. Magnitude of alcohol-related mortality and morbidity among U.S. college students age 18–24: Changes from 1998 to 2001. Annual Review of Public Health. 2005;26:259-279.
Hingson R, Heeren T, Zakocs R. Age of drinking onset and involvement in physical fights after drinking. Pediatrics. 2001;108:872-877. [pmid: 11581438].
Hingson, R., and Kenkel, D. Social health and economic consequences of underage drinking. In: National Research Council and Institute of Medicine, Bonnie, R.J., and O'Connell, M.E., eds. Reducing Underage Drinking: A Collective Responsibility. Washington, DC: National Academies Press, 2004. pp. 351–382. Available online at: http://www.nap.edu/books/0309089352/html.
Hingson R, Winter M. Epidemiology and consequences of drinking and driving. Alcohol Research & Health. 2003;27(1):63-78. [pmid: 15301401].
Jacobson R. The contributions of sex and drinking history to the CT brain scan changes in alcoholics. Psychological Medicine. 1986;16:547-559. [pmid: 3763773].
Johnston, L.D., O'Malley, P.M., Bachman, J.G., et al. Monitoring the Future, National Survey Results on Drug Use, 1975-2005. Volume 1: Secondary School Students. NIH Pub. No. 06-5883. Bethesda, MD: National Institute on Drug Abuse, 2006a. Available online at: http://www.monitoringthefuture.org/pubs/monographs/vol1_2005.pdf.
Johnston, L.D., O'Malley, P.M., Bachman, J.G., et al. (December 21, 2006) Teen Drug Use Continues Down in 2006, Particularly Among Older Teens; but Use of Prescription-Type Drugs Remains High. University of Michigan News and Information Services: Ann Arbor, MI. 2006b. Available online at: www.monitoringthefuture.org. Accessed 01/02/2007.
Jones K.L, Smith D.W. Recognition of the fetal alcohol syndrome in early infancy. Lancet. 1973;2(7836):999-1001. [pmid: 4127281].
Jones S.P, Heaven P.C. Psychosocial correlates of adolescent drug-taking behaviour. Journal of Adolescence. 1998;21:127-134. [pmid: 9585491].
Kandel D. Homophily, selection and socialization in adolescent friendships. American Journal of Sociology. 1978;84:427-436.
Kenkel D.S. Drinking, driving, and deterrence: The effectiveness and social costs of alternative policies. Journal of Law and Economics. 1993;36:877-913.
Kulick A.D, Rosenberg H. Influence of positive and negative film portrayals of drinking on older adolescents' alcohol outcome expectancies. Journal of Applied Social Psychology. 2001;31:1492.
Kulig J.W. the American Academy of Pediatrics Committee on Substance Abuse. Tobacco alcohol other drugs: The role of the pediatrician in prevention identification management of substance abuse. Pediatrics. 2005;115:816-821. [pmid: 15741395].
Kypri K, McCarthy D.M, Coe M.T, et al. Transition to independent living and substance involvement of treated and high-risk youth. Journal of Child and Adolescent Substance Abuse. 2004;13:85-100.
Larimer M.E, Cronce J.M. Identification, prevention and treatment: A review of individual-focused strategies to reduce problematic alcohol consumption by college students. Journal of Studies on Alcohol Supplement. 2002;14:148-163. [pmid: 12022721].
Lerner R.M. Promoting healthy adolescent behavior and development: Issues in design and evaluation of effective youth programs. Journal of Pediatric Nursing. 2002;17:338-344. [pmid: 12395301].
Levy, D.T., Miller, T.R., and Cox, K.C. Costs of Underage Drinking. Washington, DC: U.S. Department of Justice, Office of Justice Programs, Office of Juvenile Justice and Delinquency Prevention, 1999. Available online at: http://www.udetc.org/documents/costunderagedrinking.pdf.
Little P.J, Kuhn C.M, Wilson W.A, et al. Differential effects of ethanol in adolescent and adult rats. Alcoholism: Clinical and Experimental Research. 1996;20:1346-1351.
Martin C.S, Langenbucher J.W, Kaczynski N.A, et al. Staging in the onset of DSMIV alcohol symptoms in adolescents: Survival/hazard analyses. Journal of Studies on Alcohol. 1996;57:549-558. [pmid: 8858553].
Martin C.S, Winters K.C. Diagnosis and assessment of alcohol use disorders among adolescents. Alcohol Health & Research World. 1998;22(2):95-105. [pmid: 15706783].
Masten A.S. Regulatory processes, risk, and resilience in adolescent development. Annals of the New York Academy of Sciences. 2004;1021:310-319. [pmid: 15251901].
National Highway Traffic Safety Administration (NHTSA). Traffic Safety Facts 2002: Alcohol. DOT Pub. No. HS-809-606. Washington, DC: NHTSA, National Center for Statistics and Analysis, 2003. Available online at: http:///www-nrd.nhtsa.dot.gov/pdf/nrd30/NCSA/TSF2002/2002alcfacts.pdf.
National Institute on Alcohol Abuse and Alcoholism (NIAAA). A Call to Action: Changing the Culture of Drinking at U.S. Colleges. Bethesda, MD: NIAAA, 2002. Available online at: http://www.collegedrinkingprevention.gov/NIAAACollegeMaterials/TaskForce/TaskForce_TOC.aspx.
O'Leary T.A, Brown S.A, Colby S.M, et al. Treating adolescents together or individually? Issues in adolescent substance abuse interventions. Alcoholism: Clinical and Experimental Research. 2002;26:890-899.
Perry C.L, Komro K.A, Veblen-Mortenson S, et al. A randomized controlled trial of the middle and junior high school D.A.R.E. and D.A.R.E. Plus programs. Archives of Pediatrics and Adolescent Medicine. 2003;157(2):178-184. [pmid: 12580689].
Perry C.L, Williams C.L, Komro K.A, et al. Project Northland: Long-term outcomes of community action to reduce adolescent alcohol use. Health Education Research. 2002;17:117-132. [pmid: 11888042].
Perry C.L, Williams C.L, Veblen-Mortenson S, et al. Project Northland: Outcomes of a communitywide alcohol use prevention program during early adolescence. American Journal of Public Health. 1996;86:956-965. [pmid: 8669519]. [pmcid: 1380436].
Pfefferbaum A, Rosenbloom M, Deshmukh A, et al. Sex differences in the effects of alcohol on brain structure. American Journal of Psychiatry. 2001;158:188-197. [pmid: 11156800].
Reifman A, Barnes G.M, Dintcheff B.A, et al. Parental and peer influences on the onset of heavier drinking among adolescents. Journal of Studies on Alcohol. 1998;59:311-317. [pmid: 9598712].
Restak, R.. The Secret Life of the Brain. Washington, DC: National Academies Press, 2001.
Rhee S.H, Hewitt J.K, Young S.E, et al. Genetic and environmental influences on substance initiation, use, and problem use in adolescents. Archives of General Psychiatry. 2003;60:1256-1264. [pmid: 14662558].
Robins, L.N., and Przybeck, T.R. Age of onset of drug use as factor in drug and other disorders. In: Jones, C.L., and Battjes, R.J., eds. Etiology of Drug Abuse: Implications for Prevention. NIDA Research Monograph No. 56. Rockville, MD: National Institute on Drug Abuse, 1985. pp. 178–192. Available online at: http://www.drugabuse.gov/pdf/monographs/56.pdf.
Rodd Z.A, Bell R.L, Sable H.J.K, et al. Recent advances in animal models of alcohol craving and relapse. Pharmacology, Biochemistry, and Behavior. 2004;79(3):439-450.
Ruhm C.J. Alcohol policies and highway vehicle fatalities. Journal of Health Economics. 1996;15:435-454. [pmid: 10164038].
Russell, M. Prevalence of alcoholism among children of alcoholics. In: Windle, M., and Searles, J.S., eds. Children of Alcoholics: Critical Perspectives. New York: Guilford, 1990. pp. 9–38.
Sampson, R.J., and Laub, J.H. Crime in the Making: Pathways and Turning Points Through Life. Cambridge, MA: Harvard University Press, 1993.
Sargent J.D, Wills T.A, Stoolmiller M, et al. Alcohol use in motion pictures and its relation with early-onset teen drinking. Journal of Studies on Alcohol. 2006;67:54-65. [pmid: 16536129].
Scales P, Benson P, Leffert N, et al. The contribution of developmental assets to the prediction of thriving among adolescents. Applied Developmental Science. 2000;4:27-46.
Schulenberg J, O'Malley P.M, Bachman J.G, et al. Getting drunk and growing up: Trajectories of frequent binge drinking during the transition to young adulthood. Journal of Studies on Alcohol. 1996b;57:289-304. [pmid: 8709588].
Schulenberg J.E, Wadsworth K.N, O'Malley P.M, et al. Adolescent risk factors for binge drinking during the transition to young adulthood: Variable-and pattern-centered approaches to change. Developmental Psychology. 1996a;32:659-674.
Shiffman, S., and Balabanis, M. Associations between alcohol and tobacco. In: Fertig, J.B., and Allen, J.P., eds. Alcohol and Tobacco: From Basic Science to Clinical Practice. NIAAA Research Monograph No. 30. NIH Pub. No. 95-3931. Washington, DC: U.S. Govt. Print. Off., 1995. pp. 17–36.
Siciliano D, Smith R.F. Periadolescent alcohol alters adult behavioral characteristics in the rat. Physiology and Behavior. 2001;74(45):637-643. [pmid: 11790425].
Sieving R.E, Perry C.L, Williams C.L. Do friendships change behaviors, or do behaviors change friendships? Examining paths of influence in young adolescents' alcohol use. Journal of Adolescent Health. 2000;26:27-35. [pmid: 10638715].
Silveri M.M, Spear L.P. Decreased sensitivity to the hypnotic effects of ethanol early in ontogeny. Alcoholism: Clinical and Experimental Research. 1998;22:670-676.
Smith G.S, Branas C.C, Miller T.R. Fatal nontraffic injuries involving alcohol: A meta-analysis. Annals of Emergency Medicine. 1999;33:659-668. [pmid: 10339681].
Soloff P.H, Lynch K.G, Moss H.B. Serotonin, impulsivity, and alcohol use disorders in the older adolescent: A psychobiological study. Alcoholism: Clinical and Experimental Research. 2000;24:1609-1619.
Spear L.P. The adolescent brain and age-related behavioral manifestations. Neuroscience and Biobehavioral Reviews. 2000;24:417-463. [pmid: 10817843].
Spear, L.P., and Varlinskaya, E.I. Adolescence: Alcohol sensitivity, tolerance, and intake. In: Galanter, M., ed. Recent Developments in Alcoholism, Vol. 17: Alcohol Problems in Adolescents and Young Adults: Epidemiology, Neurobiology, Prevention, Treatment. New York: Springer, 2005. pp. 143–159.
Stattin H, Kerr M. Parental monitoring: A reinterpretation. Child Development. 2000;71:1072-1085. [pmid: 11016567].
Steinberg L. Risk taking in adolescence: What changes and why?. Annals of the New York Academy of Sciences. 2004;1021:51-58. [pmid: 15251873].
Steinberg L, Fletcher A, Darling N. Parental monitoring and peer influences on adolescent substance use. Pediatrics. 1994;93(6 PR 2):1060-1064. [pmid: 8197008].
Stice E, Barrera M, Chassin L. Prospective differential prediction of adolescent alcohol use and problem use: Examining the mechanisms of effect. Journal of Abnormal Psychology. 1998;107:616-628. [pmid: 9830249].
Substance Abuse and Mental Health Services Administration (SAMHSA). Results From the 2005 National Survey on Drug Use and Health: National Findings. NSDUH Series H-30, DHHS Pub. No. SMA 06-4194. Rockville, MD: SAMHSA, Office of Applied Studies, 2006.
Sutton M, Godfrey C. A grouped data regression approach to estimating economic and social influences on individual drinking behaviour. Health Economics. 1995;4:237-247. [pmid: 7550773].
Swartzwelder H.S, Wilson W.A, Tayyeb M.I. Age-dependent inhibition of long-term potentiation by ethanol in immature versus mature hippocampus. Alcoholism: Clinical and Experimental Research. 1995a;19:1480-1485.
Swartzwelder H.S, Wilson W.A, Tayyeb M.I. Differential sensitivity of NMDA receptormediated synaptic potentials to ethanol in immature versus mature hippocampus. Alcoholism: Clinical and Experimental Research. 1995b;19:320-323.
Swensen, C.C., Henggeler, S.W., Taylor, I.S., et al. Multisystemic Therapy and Neighborhood Partnerships: Reducing Adolescent Violence and Substance Abuse. New York: Guilford, 2005.
Tapert S.F, Brown S.A. Neuropsychological correlates of adolescent substance abuse: Four-year outcomes. Journal of the International Neuropsychological Society. 1999;5:481-493. [pmid: 10561928].
Tevyaw T.O, Monti P.M. Motivational enhancement and other brief interventions for adolescent substance abuse: Foundations, applications, and evaluations. Addiction. 2004;99(Suppl. 2):63-75. [pmid: 15488106].
Tschann J.M, Adler N.E, Irwin C.E Jr., et al. Initiation of substance use in early adolescence: The roles of pubertal timing and emotional distress. Health Psychology. 1994;13:326-333. [pmid: 7957011].
U.S. Department of Transportation Fatality Analysis Reporting System 2004. Available online at: http://www-fars.nhtsa.dot.gov.
Varlinskaya E.I, Spear L.P. Acute ethanol withdrawal (hangover) and social behavior in adolescent and adult male and female Sprague-Dawley rats. Alcoholism: Clinical and Experimental Research. 2004;28:40-50.
Victor, M., Davis, R.D., and Collins, G.H. The Wernicke-Korsakoff Syndrome and Related Neurologic Disorders Due to Alcoholism and Malnutrition. Philadelphia, PA: F.A. Davis, 1989.
Vygotsky, L.S. Mind and Society: The Development of Higher Mental Processes. Cambridge, MA: Harvard University Press, 1978.
Waldron H.B, Kaminer Y. On the learning curve: The emerging evidence supporting cognitive-behavioral therapies for adolescent substance abuse. Addiction. 2004;99(Suppl. 2):93-105. [pmid: 15488108].
White, A.M., and Swartzwelder, H.S. Age-related effects of alcohol on memory and memory-related brain function in adolescents and adults. In: Galanter, M., ed. Recent Developments in Alcoholism, Vol. 17: Alcohol Problems in Adolescents and Young Adults: Epidemiology, Neurobiology, Prevention, Treatment. New York: Springer, 2005. pp. 161–176.
White A.M, Truesdale M.C, Bae J.G, et al. Differential effects of ethanol on motor coordination in adolescent and adult rats. Pharmacology, Biochemistry and Behavior. 2002;73:673-677.
Wilson C.R, Sherritt L, Gates E, et al. Are clinical impressions of adolescent substance use accurate?. Pediatrics. 2004;114(5):e536-540. [pmid: 15520086].
Wood D.J, Bruner J, Ross G. The role of tutoring in problem solving. Journal of Child Psychology and Psychiatry. 1976;17:89-100. [pmid: 932126].