# Conclusion

Underage alcohol use remains a major public health and safety problem in the United States, creating serious personal, social, and economic consequences for adolescents, their families, communities, and the Nation as a whole. An emerging body of research on the effects of underage alcohol use on human maturation adds new urgency to the decades' long effort by the public and private sectors to prevent and reduce underage drinking.

Pervasive drinking by youth and the emergence of alcohol misuse and dependence in late adolescence are intertwined with developmental processes. Therefore, the prevention and reduction of underage drinking must be addressed within a developmental framework, which takes into account the dynamic processes of human maturation, the influence of social systems within an adolescent's environment, and the role of individual characteristics in the adolescent's decision to drink. Because adolescent development unfolds within many contexts in American society, including family, peers, school, extracurricular and community activities, part-time work, the community itself, and the overall culture, every American has a responsibility to help protect adolescents from the potentially adverse consequences of alcohol use.

As the Call to Action makes clear, each of us has an important role to play in the prevention and reduction of underage drinking through our individual and collective efforts, ensuring that the future America offers its youth is neither shortened nor impaired by the consequences of alcohol use. This Call to Action is exactly that—a call to every American to join with the Surgeon General in a national effort to address underage drinking early, continuously, and in the context of human development. Underage alcohol use is everybody's problem—and its solution is everybody's responsibility.