# References

1 RAND (Santa Monica C. Evidence Report and Evidence-based Recommendations: Health Risk Appraisals and Medicare. Contract no.: 500-98-0281. Baltimore, MD. Centers for Medicare and Medicaid Services. 2003.
2 Jadad AR, Moore RA, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: Is blinding necessary?. Control Clin Trials. 1996;17(1):1-12. [pmid: 8721797].
3 Oremus M, Wolfson C, Perrault A, et al. Interrater reliability of the modified Jadad quality scale for systematic reviews of Alzheimer’s disease drug trials. Dement Geriatr Cogn Disord. 2001;12(3):232-6. [pmid: 11244218].
4 Wells GA, Shea B, O’Connell D, et al. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. Last Accessed February 1, 2009. http://www.ohri.ca/programs/clinical_epidemiology/oxford.htm.
5 Zaza S, Wright-De Aguero LK, Briss PA, et al. Data collection instrument and procedure for systematic reviews in the Guide to Community Preventive Services. Task Force on Community Preventive Services. Am J Prev Med. 2000;18(1 Suppl):44-74. [pmid: 10806979].
6 Agency for Healthcare Research and Quality. Methods Guide for Comparative Effectiveness Reviews. internet. http://www.ncbi.nlm.nih.gov/books/NBK47095/.
7 Fries JF, Bloch DA, Harrington H, et al. Two-year results of a randomized controlled trial of a health promotion program in a retiree population: The Bank of America study. Am J Med. 1993;94(5):455-62. [pmid: 8498389].
8 Gomel MK, Oldenburg B, Simpson JM, et al. Composite cardiovascular risk outcomes of a work-site intervention trial. Am J Public Health. 1997;87(4):673-6. [pmid: 9146453].
9 Taimela S, Justen S, Aronen P, et al. An occupational health intervention programme for workers at high risk for sickness absence. Cost effectiveness analysis based on a randomised controlled trial. Occup Environ Med. 2008;65(4):242-8. [pmid: 17933885].
10 van Stralen MM, de Vries H, Bolman C, et al. Exploring the efficacy and moderators of two computer-tailored physical activity interventions for older adults: a randomized controlled trial. Ann Behav Med. 2010;39(2):139-50. [pmid: 20182833].
11 Leigh JP, Richardson N, Beck R, et al. Randomized controlled study of a retiree health promotion program. The Bank of American Study. Arch Intern Med. 1992;152(6):1201-6. [pmid: 1599348].
12 Gomel M, Oldenburg B, Simpson JM, et al. Work-site cardiovascular risk reduction: a randomized trial of health risk assessment, education, counseling, and incentives. Am J Public Health. 1993;83(9):1231-8. [pmid: 8362997].
13 Taimela S, Malmivaara A, Justen S, et al. The effectiveness of two occupational health intervention programmes in reducing sickness absence among employees at risk. Two randomised controlled trials. Occup Environ Med. 2008;65(4):236-41. [pmid: 17681994].
14 van Stralen MM, de Vries H, Mudde AN, et al. Efficacy of Two Tailored Interventions Promoting Physical Activity in Older Adults. Am J Prev Med. 2009;37(5):405-17. [pmid: 19840695].
15 Bertera RL. Behavioral risk factor and illness day changes with workplace health promotion: two-year results. Am J Health Promot. 1993;7(5):365-73. [pmid: 10148712].
16 Faghri PD, Blozie E, Gustavesen S, et al. The role of tailored consultation following health-risk appraisals in employees’ health behavior. J Occup Environ Med. 2008;50(12):1378-85. [pmid: 19092493].
17 Moy F, Sallam AA, Wong M. The results of a worksite health promotion programme in Kuala Lumpur, Malaysia. Health Promot Int. 2006;21(4):301-10. [pmid: 16963785].
18 Erfurt JC, Foote A, Heirich MA. Worksite wellness programs: incremental comparison of screening and referral alone, health education, follow-up counseling, and plant organization. Am J Health Promot. 1991;5(6):438-48. [pmid: 10148672].
19 Goetzel RZ, Ozminkowski RJ, Bruno JA, et al. The long-term impact of Johnson & Johnson’s Health & Wellness Program on employee health risks. J Occup Environ Med. 2002;44(5):417-24. [pmid: 12024687].
20 Yen L, Edington MP, McDonald T, et al. Changes in health risks among the participants in the United Auto Workers--General Motors LifeSteps Health Promotion Program. Am J Health Promot. 2001;16(1):7-15. [pmid: 11575055].
21 Chan CW, Witherspoon JM. Health risk appraisal modifies cigarette smoking behavior among college students. J Gen Intern Med. 1988;3(6):555-9. [pmid: 3230458].
22 Richter JM, Malkiewicz JA, Shaw D. Health promotion behaviors in nursing students. J Nurs Educ. 1987;26(9):367-71. [pmid: 2830376].
23 Shephard RJ, Corey P, Cox M. Health hazard appraisal--the influence of an employee fitness program. Can J Public Health. Revue(3). 1982:183-7. [pmid: 7127239].
24 Wilson RW, Wingender MK, Redican KJ, et al. Effects of the Health Hazard Appraisal inventory on practices of college students. Health Educ. 1980;11(1):28-30. [pmid: 6769847].
25 Papadaki A, Scott JA. Follow-up of a web-based tailored intervention promoting the Mediterranean diet in Scotland. Patient Educ Couns. 2008;73(2):256-63. [pmid: 18640000].
26 Maes S, Kittel F, Scholten H, et al. ‘Healthier Work at Brabantia’, a comprehensive approach to wellness at the worksite. Saf Sci. 1992;15(4–6):351-66.
27 Van Beurden E, James R, Dunn T, et al. Risk assessment and dietary counselling for cholesterol reduction. Health Educ Res. 1990;5(4):445-50.
28 Blair SN, Piserchia PV, Wilbur CS, et al. A public health intervention model for work-site health promotion. Impact on exercise and physical fitness in a health promotion plan after 24 months. JAMA. 1986;255(7):921-6. [pmid: 3944998].
29 Korolewski LS. Evaluation of lifestyle risk assessment and health education program. Pub Health. 1984;98(6):372-6. [pmid: 6522578].
30 Karlehagen S, Ohlson CG. Primary prevention of cardiovascular disease by an occupational health service. Prev Med. 2003;37(3):219-25. [pmid: 12914827].
31 Sabti Z, Handschin M, Kutlar JM, et al. Evaluation of a physical activity promotion program in primary care. Fam Pract. 2010;27(3):279-84. [pmid: 20332179].
32 McKee MD, Deen D, Maher S, et al. Implementation of a pilot primary care lifestyle change intervention for families of pre-school children: Lessons learned. Patient Educ Couns. 2010;79(3):299-305. [pmid: 20435428].
33 Shi L. The impact of increasing intensity of health promotion intervention on risk reduction. [47 refs]. Eval Health Prof. 1992;15(1):3-25. [pmid: 10117742].
34 Singleton SP, Neale AV, Scott RO, et al. Choesterol reduction among volunteers in a health promotion project. Am J Health Promot. 1988;2(4):5-12. [pmid: 10302266].
35 Talvi AI, Jarvisalo JO, Knuts LR. A health promotion programme for oil refinery employees: changes of health promotion needs observed at three years. Occup Med. 1999;49(2):93-101.
36 O’Loughlin J, Renaud L, Paradis G, et al. Screening school personnel for cardiovascular disease risk factors: Short-term impact on behavior and perceived role as promoters of heart health. Prev Med. 1996;25(6):660-7. [pmid: 8936567].
37 Pescatello LS, Murphy D, Vollono J, et al. The cardiovascular health impact of an incentive worksite health promotion program. Am J Health Promot. 2001;16(1):16-20. [pmid: 11575051].
38 Puska P, Niemensivu H, Puhakka P, et al. Results of a one-year worksite and mass media based intervention on health behaviour and chronic disease risk factors. Scand J Soc Med. 1988;16(4):241-50. [pmid: 3232055].
39 Angotti CM, Chan WT, Sample CJ, et al. Combined dietary and exercise intervention for control of serum cholesterol in the workplace. Am J Health Promot. 2000;15(1):9-16. [pmid: 11184120].
40 Breslow L, Fielding J, Herrman AA, et al. Worksite health promotion: its evolution and the Johnson & Johnson experience. Prev Med. 1990;19(1):13-21. [pmid: 2320555].
41 Hedberg GE, Wikstrom-Frisen L, Janlert U. Comparison between two programmes for reducing the levels of risk indicators of heart diseases among male professional drivers. Occup Environ Med. 1998;55(8):554-61. [pmid: 9849543].
42 Bergstrom G, Bjorklund C, Fried I, et al. A comprehensive workplace intervention and its outcome with regard to lifestyle, health and sick leave: the AHA study. Work. 2008;31(2):167-80. [pmid: 18957735].
43 Fouad MN, Kiefe CI, Bartolucci AA, et al. A hypertension control program tailored to unskilled and minority workers. Ethn Dis. 1997;7(3):191-9. [pmid: 9467701].
44 Herman CW, Musich S, Lu C, et al. Effectiveness of an incentive-based online physical activity intervention on employee health status. J Occup Environ Med. 2006;48(9):889-95. [pmid: 16966955].
45 Blair SN, Smith M, Collingwood TR, et al. Health promotion for educators: impact on absenteeism. Prev Med. 1986;15(2):166-75. [pmid: 3714669].
46 Gold DB, Anderson DR, Serxner SA. Impact of a telephone-based intervention on the reduction of health risks. Am J Health Promot. 2000;15(2):97-106. [pmid: 11194702].
47 Holt MC, McCauley M, Paul D. Health impacts of AT and T’s Total Life Concept (TLC) program after five years. Am J Health Promot. 1995;9(6):421-5. [pmid: 10150532].
48 Kemper HCG, Verhagen EALM, Milo D, et al. Effects of health information in youth on adult physical activity: 20-year study results from the Amsterdam Growth and Health Longitudinal Study. Am J Human Biol. 2002;14(4):448-56. [pmid: 12112566].
49 Lingfors H, Persson LG, Lindstrom K, et al. Effects of a global health and risk assessment tool for prevention of ischemic heart disease in an individual health dialogue compared with a community health strategy only results from the Live for Life health promotion programme. Prev Med. 2009;48(1):20-4. [pmid: 19013188].
50 Mills PR, Kessler RC, Cooper J, et al. Impact of a health promotion program on employee health risks and work productivity. Am J Health Promot. 2007;22(1):45-53. [pmid: 17894263].
51 Goetzel R, Sepulveda M, Knight K, et al. Association of IBM’s "A Plan for Life" health promotion program with changes in employees’ health risk status. J Occup Med. 1994;36(9):1005-9. [pmid: 7823211].
52 Oxford Centre for Evidence-based Medicine. Oxford Centre for Evidence-based Medicine - Levels of Evidence. Oxford. Oxford Centre for Evidence-based Medicine. Available at: http://www.cebm.net/index.aspx?o=1025. Accessed on: September 1. 2010.
53 Wellsource, Inc. Scientific Validity. www.wellsource.com/scientific-validity.html 2011 Dec 1. Clackamas, OR. Wellsource, Inc. 12. 1. 2011.
54 Boudreau F, Godin G, Pineau R, et al. Health risk appraisal in an occupational setting and its impact on exercise behavior. J Occup Environ Med. 1995;37(9):1145-50. [pmid: 8528724].
55 Campbell MK, Tessaro I, DeVellis B, et al. Effects of a tailored health promotion program for female blue-collar workers: Health Works for Women. Prev Med. 2002;34(3):313-23. [pmid: 11902848].
56 Brug J, Steenhuis I, van Assema P, et al. The impact of a computer-tailored nutrition intervention. Prev Med. 1996;25(3):236-42. [pmid: 8781000].
57 Connell CM, Sharpe LA, Gallant MP. Effect of health risk appraisal on health outcomes in a university worksite health promotion trial. Health Educ Res. 1995;10(2):199-209.
58 Elliot DL, Goldberg L, Kuehl KS, et al. The PHLAME (Promoting Healthy Lifestyles: Alternative Models’ Effects) firefighter study: outcomes of two models of behavior change. J Occup Environ Med. 2007;49(2):204-13. [pmid: 17293760].
59 Elliot DL, Goldberg L, Duncan TE, et al. The PHLAME firefighters’ study: feasibility and findings. Am J Health Behav. 2004;28(1):13-23. [pmid: 14977155].
60 Maron DJ, Forbes BL, Groves JR, et al. Health-risk appraisal with or without disease management for worksite cardiovascular risk reduction. J Cardiovasc Nurs. 2008;23(6):513-8. [pmid: 18953215].
61 Nurminen E, Malmivaara A, Ilmarinen J, et al. Effectiveness of a worksite exercise program with respect to perceived work ability and sick leaves among women with physical work. Scand J Work Environ Health. 2002;28(2):85-93. [pmid: 12019592].
62 Prochaska JO, Butterworth S, Redding CA, et al. Initial efficacy of MI, TTM tailoring and HRI’s with multiple behaviors for employee health promotion. Prev Med. 2008;46(3):226-31. [pmid: 18155287].
63 Proper KI, Hildebrandt VH, van der Beek AJ, et al. Effect of individual counseling on physical activity fitness and health: a randomized controlled trial in a workplace setting. Am J Prev Med. 2003;24(3):218-26. [pmid: 12657339].
64 Sorensen G, Barbeau EM, Stoddard AM, et al. Tools for health: the efficacy of a tailored intervention targeted for construction laborers. Canc Causes Contr. 2007;18(1):51-9.
65 Strychar IM, Champagne F, Ghadirian P, et al. Impact of receiving blood cholesterol test results on dietary change. Am J Prev Med. 1998;14(2):103-10. [pmid: 9631161].
66 De Bourdeaudhuij I, Stevens V, Vandelanotte C, et al. Evaluation of an interactive computer-tailored nutrition intervention in a real-life setting. Ann Behav Med. 2007;33(1):39-48. [pmid: 17291169].
67 Nisbeth O, Klausen K, Andersen LB. Effectiveness of counselling over 1 year on changes in lifestyle and coronary heart disease risk factors. Patient Educ Couns. 2000;40(2):121-31. [pmid: 10771366].
68 Crouch M, Sallis JF, Farquhar JW, et al. Personal and mediated health counseling for sustained dietary reduction of hypercholesterolemia. Prev Med. 1986;15(3):282-91. [pmid: 3749008].
69 Cockcroft A, Gooch C, Ellinghouse C, et al. Evaluation of a programme of health measurements and advice among hospital staff. Occup Med. 1994;44(2):70-6.
70 Braeckman L, De Bacquer D, Maes L, et al. Effects of a low-intensity worksite-based nutrition intervention. Occup Med (Lond). 1999;49(8):549-55. [pmid: 10658309].
71 Gemson DH, Sloan RP. Efficacy of computerized health risk appraisal as part of a periodic health examination at the worksite. Am J Health Promot. 1995;9(6):462-6. [pmid: 10150537].
72 Hanlon P, McEwen J, Carey L, et al. Health checks and coronary risk: Further evidence from a randomised controlled trial. Br Med J. 1995;311(7020):1609-13. [pmid: 8555805].
73 Heirich MA, Foote A, Erfurt JC, et al. Work-site physical fitness programs. Comparing the impact of different program designs on cardiovascular risks. J Occup Environ Med. 1993;35(5):510-7.
74 Maruyama C, Kimura M, Okumura H, et al. Effect of a worksite-based intervention program on metabolic parameters in middle-aged male white-collar workers: a randomized controlled trial. Prev Med. 2010;51(1):11-7. [pmid: 20403374].
75 Peters KK, Carlson JG. Worksite stress management with high-risk maintenance workers: A controlled study. Int J Stress Manag. 1999;6(1):21-44.
76 Racette SB, Deusinger SS, Inman CL, et al. Worksite Opportunities for Wellness (WOW): effects on cardiovascular disease risk factors after 1 year. Prev Med. 2009;49(2–3):108-14. [pmid: 19576927].
77 Rahe RH, Taylor CB, Tolles RL, et al. A novel stress and coping workplace program reduces illness and healthcare utilization. Psychosom Med. 2002;64(2):278-86. [pmid: 11914444].
78 Selbst M, Bell MM, Thome MJ. The impact of a cholesterol screening and intervention program among unskilled and semiskilled workers. Am J Health Promot. 1992;6(4):261-3. [pmid: 10146804].
79 Fielding JE, Mason T, Kinght K, et al. A randomized trial of the IMPACT worksite cholesterol reduction program. Am J Prev Med. 1995;11(2):120-3. [pmid: 7632447].
80 Makrides L, Dagenais GR, Chockalingam A, et al. Evaluation of a workplace health program to reduce coronary risk factors. Clin Govern. 2008;13(2):95-105.
81 Pelletier KR, Rodenburg A, Chikamoto Y, et al. Managing job strain: A randomized controlled trial of an intervention conducted by mail and telephone. Am J Health Promot. 1998;12(3):166-9. [pmid: 10176090].
82 Stevens VJ, Glasgow RE, Toobert DJ, et al. Randomized trial of a brief dietary intervention to decrease consumption of fat and increase consumption of fruits and vegetables. Am J Health Promot. 2002;16(3):129-34. [pmid: 11802257].
83 Toft U, Kristoffersen L, Ladelund S, et al. The impact of a population-based multi-factorial lifestyle intervention on changes in long-term dietary habits. The Inter99 study. Prev Med. 2008;47(4):378-83. [pmid: 18590758].
84 Campbell MK, DeVellis BM, Strecher VJ. Improving dietary behavior: the effectiveness of tailored messages in primary care settings. Am J Public Health. 1994;84:783-7. [pmid: 8179049].
85 Charlson ME, Peterson JC, Boutin-Foster C, et al. Changing health behaviors to improve health outcomes after angioplasty: a randomized trial of net present value versus future value risk communication. Health Educ Res. 2008;23(5):826-39. [pmid: 18025064].
86 Ferrer RL, Mody-Bailey P, Jaen CR, et al. A medical assistant-based program to promote healthy behaviors in primary care. Ann Fam Med. 2009;7(6):504-12. [pmid: 19901309].
87 Harari D, Iliffe S, Kharicha K, et al. Promotion of health in older people: a randomised controlled trial of health risk appraisal in British general practice. Age Ageing. 2008;37(5):565-71. [pmid: 18755784].
88 Kreuter MW, Strecher VJ. Do tailored behavior change messages enhance the effectiveness of health risk appraisal? Results from a randomized trial. Health Educ Res. 1996;11(1):97-105. [pmid: 10160231].
89 Lauritzen T, Ager Jensen SM, Thomsen LJ, et al. Health tests and health consultations reduced cardiovascular risk without psychological strain, increased healthcare utilization or increased costs: An overview of the results from a 5-year randomized trial in primary care. The Ebeltoft Health Promotion Project (EHPP). Scand J Public Health. 2008;36(6):650-61. [pmid: 18775821].
90 Steptoe A, Doherty S, Rink E, et al. Behavioural counselling in general practice for the promotion of healthy behaviour among adults at increased risk of coronary heart disease: Randomised trial. Br Med J. 1999;319(7215):943-7. [pmid: 10514155].
91 Stoddard AM, Palombo R, Troped PJ, et al. Cardiovascular disease risk reduction: The Massachusetts WISEWOMAN Project. J Women’s Health. 2004;13(5):539-46.
92 von Huth SL, Ladelund S, Borch-Johnsen K, et al. A randomized multifactorial intervention study for prevention of ischaemic heart disease (Inter99): the long-term effect on physical activity. Scand J Public Health. 2008;36(4):380-8. [pmid: 18539692].
93 Lowensteyn I, Joseph L, Levinton C, et al. Can computerized risk profiles help patients improve their coronary risk? The results of the Coronary Health Assessment Study (CHAS). Prev Med. 1998;27(5, Pt.1). Sep–Oct.
94 Smith WA, Ekdahl SS, Henley CE. Use of Health Hazard Appraisal in counseling for reduction of risk factors. J Am Osteopath Assoc. 1985;85(12):809-14. [pmid: 3908417].
95 Spoth RL, Dush DM, Conley M. Evaluating minimal intervention health promotion in a clinical context. Int Q Community Health Educ. 1991;12(3):203-16. [pmid: 20840969].
96 Godin G, Desharnais R, Jobin J, et al. The impact of physical fitness and health-age appraisal upon exercise intentions and behavior. J Behav Med. 1987;10(3):241-50. [pmid: 3612781].
97 Mayer JA, Jermanovich A, Wright BL, et al. Changes in health behaviors of older adults: the San Diego Medicare Preventive Health Project. Prev Med. 1994;23(2):127-33. [pmid: 8047517].
98 Kim Y, Pike J, Adams H, et al. Telephone intervention promoting weight-related health behaviors. Prev Med. 2010;50(3):112-7. [pmid: 20006642].
99 Kroeze W, Oenema A, Dagnelie PC, et al. Examining the minimal required elements of a computer-tailored intervention aimed at dietary fat reduction: Results of a randomized controlled dismantling study. Health Educ Res. 2008;23(5):880-91. [pmid: 18063650].
100 Spittaels H, De Bourdeaudhuij I, Vandelanotte C. Evaluation of a website-delivered computer-tailored intervention for increasing physical activity in the general population. Prev Med. 2007;44(3):209-17. [pmid: 17197015].
101 Smeets T, Brug J, de Vries H. Effects of tailoring health messages on physical activity. Health Educ Res. 2008;23(3):402-13. [pmid: 17032705].
102 Blalock SJ, DeVellis BM, Patterson CC, et al. Effects of an osteoporosis prevention program incorporating tailored educational materials. Am J Health Promot. 2002;16(3):146-56. [pmid: 11802260].
103 Fjeldsoe BS, Miller YD, Marshall AL. MobileMums: a randomized controlled trial of an SMS-based physical activity intervention. Ann Behav Med. 2010;39(2):101-11. [pmid: 20174902].
104 Gagnon H, Godin G, Alary M, et al. A randomized trial to evaluate the efficacy of a computer-tailored intervention to promote safer injection practices among drug users. AIDS and Behavior. 2010;14(3):538-48. [pmid: 20033276].
105 Aronow HU, Hahn JE. Stay Well and Healthy! Pilot study findings from an inhome preventive healthcare programme for persons ageing with intellectual and/or developmental disabilities. J Appl Res Intellect Disabil. 2005;18(2):163-73.
106 Baer JS, Kivlahan DR, Blume AW. Brief intervention for heavy-drinking college students: 4-year follow-up and natural history. Am J Public Health. 2001;91(8):1310-6. [pmid: 11499124].
107 Edelman D, Oddone EZ, Liebowitz RS, et al. A multidimensional integrative medicine intervention to improve cardiovascular risk. J Gen Intern Med. 2006;21(7):728-34. [pmid: 16808774].
108 De Bourdeaudhuij I, Maes L, De Henauw S, et al. Evaluation of a computer-tailored physical activity intervention in adolescents in six European countries: The Activ-O-Meter in the HELENA intervention study. J Adolesc Health. 2010;46(5):458-66. [pmid: 20413082].
109 Haerens L, Maes L, Vereecken C, et al. Effectiveness of a computer tailored physical activity intervention in adolescents compared to a generic advice. Patient Educ Couns. 2009;77(1):38-41. [pmid: 19406608].
110 Dally DL, Dahar W, Scott A, et al. The impact of a health education program targeting patients with high visit rates in a managed care organization. Am J Health Promot. 2002;17(2):101-11. [pmid: 12471862].
111 McClure JB, Ludman EJ, Grothaus L, et al. Impact of a brief motivational smoking cessation intervention: The get PHIT randomized controlled trial. Am J Prev Med. 2009;37(2):116-23. [pmid: 19524389].
112 Alexander GL, McClure JB, Calvi JH, et al. A randomized clinical trial evaluating online interventions to improve fruit and vegetable consumption. Am J Public Health. 2010;100(2):319-26. [pmid: 20019315].
113 Walker SN, Pullen CH, Boeckner L, et al. Clinical trial of tailored activity and eating newsletters with older rural women. Nurs Res. 2009;58(2):74-85. [pmid: 19289928].
114 Lalonde L, O’Connor AM, Duguay P, et al. Evaluation of a decision aid and a personal risk profile in community pharmacy for patients considering options to improve cardiovascular health: The OPTIONS pilot study. Int J Pharm Pract. 2006;14(1):51-62.
115 Meng H, Wamsley BR, Friedman B, et al. Impact of body mass index on the effectiveness of a disease management-health promotion intervention on disability status. American journal of health promotion : AJHP. 2010;24(3):214-22. [pmid: 20073389].
116 Wallace JI, Buchner DM, Grothaus L, et al. Implementation and effectiveness of a community-based health promotion program for older adults. J Gerontol A Biol Sci Med Sci. 1998;53(4):M301-M306. [pmid: 18314570].
117 Walker SN, Pullen CH, Hageman PA, et al. Maintenance of activity and eating change after a clinical trial of tailored newsletters with older rural women. Nurs Res. 2010;59(5):311-21. [pmid: 20697307].
118 Vandelanotte C, De Bourdeaudhuij I, Sallis JF, et al. Efficacy of sequential or simultaneous interactive computer-tailored interventions for increasing physical activity and decreasing fat intake. Ann Behav Med. 2005;29(2):138-46. [pmid: 15823787].
119 van ‘t Riet J, Ruiter RAC, Werrij MQ, et al. Investigating message-framing effects in the context of a tailored intervention promoting physical activity. Health Educ Res. 2010;25(2):343-54. [pmid: 19841041].
120 Stuifbergen AK, Blozis SA, Becker H, et al. A randomized controlled trial of a wellness intervention for women with fibromyalgia syndrome. Clin Rehabil. 2010;24(4):305-18. [pmid: 20360151].
121 Brennan T, Spettell C, Villagra V, et al. Disease management to promote blood pressure control among African Americans. Popul Health Manag. 2010;13(2):65-72. [pmid: 20415618].
122 Lawler SP, Winkler E, Reeves MM, et al. Multiple health behavior changes and co-variation in a telephone counseling trial. Ann Behav Med. 2010;39(3):250-7. [pmid: 20419359].
123 Fries JF, Harrington H, Edwards R, et al. Randomized controlled trial of cost reductions from a health education program: the California Public Employees’ Retirement System (PERS) study. Am J Health Promot. 1994;8(3):216-23. [pmid: 10146667].
124 Gallagher EM, Brunt H. Head over heels: Impact of a health promotion program to reduce falls in the elderly. Can J Aging. 1996;15(1):84-96.
125 Nice DS, Woodruff SI. Self-selection in responding to a health risk appraisal: Are we preaching to the choir?. Am J Health Promot. 1990;4(5):367-72. [pmid: 22204577].
126 Nitzke S, Kritsch K, Boeckner L, et al. A stage-tailored multi-modal intervention increases fruit and vegetable intakes of low-income young adults. Am J Health Promot. 2007;22(1):6-14. [pmid: 17894257].
127 Hartman RT, Wolfson J, Yevich SJ. Military deployment health surveillance policy and its application to Special Operations Forces. Mil Med. 2004;169(1):1-6. [pmid: 14964493].
128 Soler RE, Leeks KD, Razi S, et al. A systematic review of selected interventions for worksite health promotion. The assessment of health risks with feedback. Am J Prev Med. 2010;38(2 Suppl):S237-S262. [pmid: 20117610].
129 Alexander G. SPM Handbook of Health Assessment Tools. Pittsburgh, PA. The Society of Prospective Medicine and The Institute for Health and Productivity Management. 1999. Health risk appraisal.
130 Anderson DR, Staufacker MJ. The impact of worksite-based health risk appraisal on health-related outcomes: a review of the literature. Am J Health Promot. 1996;10(6):499-508. [pmid: 10163313].
131 DeFriese GH, Fielding JE. Health risk appraisal in the 1990s: opportunities, challenges, and expectations. [33 refs]. Annu Rev Public Health. 1990;11:401-18. [pmid: 2191669].
132 Centers for Disease Control and Prevention (CDC). Workplace Health Promotion - Glossary Terms. http://www.cdc.gov/workplacehealthpromotion/glossary/#H. http://www.cdc.gov/workplacehealthpromotion/glossary/#H.
133 The Society of Prospective Medicine Handbook of Health Assessment Tools. Pittsburgh, PA. The Society of Prospective Medicine and The Institute for Health and Productivity. 1999.
134 Rosenthal MB, Landon BE, Normand SL, et al. Employers’ use of value-based purchasing strategies. JAMA. 2007;298(14):2281-8. [pmid: 18029832].
135 Huskamp HA, Rosenthal MB. Health risk appraisals: How much do they influence employees’ health behaviour. Health Aff (Millwood). 2009;28(5):1532-40. [pmid: 19738273].
136 Wagner E, Beery W, Schoenbach V, et al. An Assessment of Health Hazard/Health Risk Appraisal. Am J Public Health. 1982;72:347-52. [pmid: 7065313].
137 Schoenbach V, Wagner E, Beery W. Health risk appraisal: review of evidence for effectiveness. Health Service Research. 1987;22(4):553-80.
138 Becker MH, Janz NK. On the effectiveness and utility of health hazard/health risk appraisal in clinical and nonclinical settings. Health Serv Res. 1987;22:537-51. [pmid: 3679842].
139 Goulding MR. Public Health and Aging: Trends in Aging - United States and Worldwide. Morb Mort Weekly Rep. 2003;52(6):101-6.
140 The Henry J. Kaiser Family Foundation. Summary of New Health Reform Law. Menlo Park, CA. The Henry J. Kaiser Family Foundation. Available at: www.kff.org/healthreform/upload/8061.pdf. Accessed on: August 6, 2010.
141 Heaney CA, Goetzel RZ. A review of health-related outcomes of multi-component worksite health promotion programs. [65 refs]. Am J Health Promot. 1997;11(4):290-307. [pmid: 10165522].
142 Oremus M, Walker K, Dayes I, et al. Diagnosis and Treatment of Secondary Lymphedema. Rockville, MD. Agency for Healthcare Research and Quality. 2010. http://www.cms.gov/mcd/viewtechassess.asp?from2=viewtechassess.asp&where=index&tid=66&.
143 Loeppke R, Nicholson S, Taitel M, et al. The impact of an integrated population health enhancement and disease management program on employee health risk, health conditions, and productivity. Popul Health Manag. 2008;11(6):287-96. [pmid: 19108644].
144 Fries JF, Carey C, McShane DJ. Patient education in arthritis: randomized controlled trial of a mail-delivered program. J Rheumatol. 1997;24(7):1378-83. [pmid: 9228140].
145 Mackey T, Adams J. The use of health risk appraisal in a nursing center: costs and benefits. NLN Publ. 1994;(41-2629):253-65. [pmid: 7596802].
146 Kellerman ST, Felts WM, Chenier TC. The impact on factory workers of health risk appraisal and counseling in health promotion. Am J Prev Med. 1992;8(1):37-42. [pmid: 1575999].
147 Marlowe M, Adams J. Individual and organizational health at Rockwell International. Corp Comment. 1985;1(4):14-21. [pmid: 10272147].
148 Baldwin R, Pratt H, Goring H, et al. Does a nurse-led mental health liaison service for older people reduce psyhiatric morbidity in actue general medical wards? A randomised controlled trial. Age Ageing. 2004;33(5):472-8. [pmid: 15217778].
149 Steele R, Mummery WK, Dwyer T. Using the Internet to promote physical activity: A randomized trial of intervention delivery modes. J Phys Act Health. 2007;4(3):245-60. [pmid: 17846455].
150 Werch CE, Schroeder DA, Matthews LL. The health fair as a health promotion strategy: Effects on health risk behaviors and the utility of specific health fair activities. J Am Coll Health. 1986;35(2):74-9. [pmid: 3771942].
151 Hettler RB. Promoting health through risk reduction. New York. MacMillan Publishing Company. 1982. Wellness promotion and risk reduction on a university campus.
152 Hettler RB, Janty C, Moffat C. Proceedings of the Thirteenth Meeting of the Society of Prospective Medicine. Bethesda, MD. Society of Prospective Medicine. 1977. A comparison of seven methods of health hazard appraisal.
153 Breslow L, Beck JC, Morgenstern H. Development of a health risk appraisal for the elderly (HRA-E). Am J Health Promot. 1997;(11):337-43. [pmid: 10167368].
154 Shaughnessy PW, Crisler KS, Schlenker RE. Standardization Outcome and Assessment Information Set for Home Health Care: OASIS. Denver, CO. Center for Health Services and Policy Research. 1997.
155 Wendel-Vos GC, Schuit AJ, Saris WH, et al. Reproducibility and relative validity of the short questionnaire to assess health-enhancing physical activity. J Clin Epidemiol. 2003;56(12):1163-9. [pmid: 14680666].
156 Shape Up America! Physical Activity Readiness Questionnaire. www.shapeup.org/fitness/assess/parq1.php. 2011.
157 Ramey D, Raynauld J, Fries J. The Health Assessment Questionnaire 1992: Status and review. Arthritis Care Res J. 1992;(5):119-29.
158 Madigan EA, Forinsky RH. Inter-rater reliability of the Outcomes and Assessment Information Set: results from the field. Gerontologist. 2004;(44):689-92. [pmid: 15498844].
159 Brown SC, Geiselman PJ, Copeland AL, et al. Reliability and validity of the Personal Wellness Profile (PWP) Questionnaire in African American college women. J Cult Divers. 2008;15(4):163-7. [pmid: 19202717].
160 Ware JE Jr, Sherbourne CD. The MOS 36-item short-form health survey (SF-36). I. Conceptual framework and item selection. Med Care. 1992;30(6):473-83. [pmid: 1593914].
161 Reuben DB, Laliberte L, Hiris J, et al. A hierarchical exercise scale to measure function at the Advanced Activities of Daily Living (AADL) level. J Am Geriatr Soc. 1990;38(8):855-61. [pmid: 2387949].
162 Edwards N. Ottawa-Carleton Health Department Study - Unpublished Interview Schedule. Ottawa. Ottawa-Carleton Health Unit Study of Falls. 1991.
163 Radloff LS. CES-D scale: a self-report depression scale for research in the general population. App Psychol Meas. 1977;(14):1905-7.
164 Radloff LS, Locke BZ. Center for Epidemiologic Studies Depression Scale (CES-D). Modified from: Rush J, et al: Psychiatric Measures. APA. Washington, DC. 2000. https://sakai.ohsu.edu/access/content/user/brodym/N574A%20Spring08/appendix/CESDepre.doc/CES-d-validity.
165 Rimm EB, Giovannucci EL, Stampfer MJ, et al. Reproducibility and validity of an expanded self-administered semiquantitative food frequency questionnaire among male health professionals. Am J Epidemiol. 1992;135(10):1114-26. [pmid: 1632423].
166 Taylor HL, Jacobs DR, Schucker B. A questionnaire for the assessment of leisure time physical activities. J Chronic Dis. 1997;(31):741-55.
167 Saphire LS. Comprehensive health promotion: opportunities for demonstrating value added to the business. AAOHN J. 1995;43(11):570-3. [pmid: 7575793].
168 Schulz K, Altman D, Moher D, et al. CONSORT 2010 Statement: updated guidelines for reporting parallel group randomised trials. BMC Med. 2010;8:18. [doi: 10.1186/1741-7015-8-18]. [pmid: 20334633].
169 Elm Ev, Altman DG, Egger M, et al. Strengthening the reporting of observational studies in epidemiology (STROBE) statement: guidelines for reporting observational studies. Br Med J. 2007;335(7624):806-8. [pmid: 17947786].
170 Colditz GA, Martin P, Stampfer MJ, et al. Validation of questionnaire information on risk factors and disease outcomes in a prospective cohort study of women. Am J Epidemiol. 1986;123(5):894-900. [pmid: 3962971].
171 Newell SA, Girgis A, Sanson-Fisher RW, et al. The accuracy of self-reported health behaviors and risk factors relating to cancer and cardiovascular disease in the general population: a critical review. Am J Prev Med. 1999;17(3):211-29. [pmid: 10987638].
172 Dillman DA, Smyth JD, Christian LM, Internet Mail. Mixed-Mode Surveys: The Tailored Design Method. 3. Hoboken, NJ. John Wiley & Sons, Inc. 2009.
173 Aschengrau A, Seage GR. Essentials of Epidemiology in Public Health. London. Jones and Bartlett Publishers International. 2003.
174 Li CY, Sung FC. A review of the healthy worker effect in occupational epidemiology. Occup Med. 1999;49(4):225-9.
175 Administration on Aging - Department of Health and Human Services. Internet Usage and Online Activities of Older Adults. http://www.aoa.gov/AoAroot/Press_Room/Social_Media/Widget/Statistical_Profile/2010/6.aspx.
176 McCarney R, Warner J, Iliffe S, et al. The Hawthorne Effect: a randomised, controlled trial. BMC Medical Research Methodology. 2007;7(1):30. [pmid: 17608932].