# Executive Summary

## Introduction

This technology assessment on health risk appraisals (HRAs) was prepared by the McMaster University Evidence-based Practice Center (MU-EPC) for the Centers for Medicare and Medicaid Services (CMS). The primary goals of the assessment were to describe key features of HRAs, examine which features were associated with successful HRAs, and discuss the applicability of HRAs to the Medicare population.

CMS, in consultation with the MU-EPC and the Agency for Healthcare Research and Quality (AHRQ), drafted the following key questions (KQ) to guide the technology assessment.

KQ1 Describe the characteristics of the provision of HRAs, including the following:
  a. Which specific HRAs were studied in the literature?
  b. What were the methods of HRA administration, e.g., telephone, Web-based, in the doctor’s office, community based, workplace based, or other?
  c. What was the training of personnel who administered HRAs?
  d. What were the methods and frequencies of followup?
  e. What were the characteristics of the patient populations who received HRAs?
KQ2 What characteristics of HRAs (KQ1 a to e above) are associated with better health outcomes?
KQ3 What is the generalizability of the data in KQ1 and 2 to the Medicare population or subpopulations?

## Methods

### Literature Search

We searched Medline^®^, Embase^®^, Cochrane Central^®^, PsycINFO^®^, and Social Science Abstracts^®^ from each database’s inception date to June 2010. Search terms included a combination of subject headings and text words for HRA, e.g., ‘health risk appraisal’, ‘health risk assessment’, and ‘health hazard assessment’. Search terms were combined with text words denoting individualized or personalized feedback, e.g., ‘feedback’, ‘counsel’, ‘individual’, ‘personal’, ‘tailor’. To supplement the database search, we hand searched The American Journal of Health Promotion.

Inclusion/exclusion criteria. We included human studies published in the English language, provided they were randomized controlled trials (RCTs) or observational studies with comparison groups (e.g., cohort, case control). We excluded case reports, case series, narrative and systematic reviews, editorials, comments, letters, opinion pieces, abstracts, and conference proceedings.

The primary focus of included studies had to be HRAs for single disease entities (e.g., cardiovascular disease (CVD)), multiple disease entities, or general health. Our definition of an HRA contained three components: participants provided self-reported information to identify individual risk factors for disease; participants received individualized health-related feedback based on the information they provided; and the information was used to give participants at least one recommendation or intervention to promote health, sustain function, or prevent disease.1 We excluded studies reporting HRAs without all three components.

We also excluded studies without health outcomes. Health outcomes encompassed items such as self-reported risk factors or diagnoses (including food consumption), clinical measures (e.g., blood pressure), or physical measures (e.g., weight, performance on a test such as grip strength). Examples of non-health outcomes were cost comparisons between HRA programs, measures of satisfaction with HRAs (e.g., appearance of questionnaires, depth of feedback), or reported proportions of persons who returned HRA questionnaires.

### Study Selection and Reporting

A team of trained screeners applied the inclusion and exclusion criteria to the citations that were retrieved in the literature search. The screening process was divided into three levels: two levels of title and abstract screening and one level of full text screening. Studies that passed full text screening proceeded to full data extraction.

### Quality Assessment

Following data extraction, two raters independently assessed study quality using the modified Jadad scale2,3 for RCTs and the Newcastle-Ottawa Scale (NOS)4 for cohort and case control studies. The items in these quality scales are consistent with the Task Force on Community Preventive Services guideline for collecting data in systematic reviews.5

The overall quality of each extracted article with a comparison group was rated ‘good,’ ‘fair,’ or ‘poor’ in accordance with the recommendations outlined in the AHRQ methods guide for systematic reviews.6

We graded the overall strength of evidence for KQ2 and KQ3 in each of four domains: risk of bias, consistency, directness, and precision. We classified overall strength as high, medium, low, or insufficient based on the recommendations of the AHRQ methods guide.6

## Results

### Literature Review and Screening

The literature search yielded 5,973 unique citations. In total, 5,434 citations (91 percent) were excluded from further review following the two levels of title and abstract screening. Of the 539 citations promoted to full text screening, 421 (78 percent) were excluded and 118 (22 percent) proceeded to full data extraction and quality assessment. We were unable to retrieve 8 articles despite extensive searches of library holdings from multiple universities, interlibrary loan requests, and contact with authors. Figure 1 (Chapter 3) depicts the flow of articles through screening. As well, the figure shows the reasons for article exclusion at full text screening. Citations were managed in an online database using Distiller SR.

The 118 extracted articles included 81 RCTs and 37 cohort studies. Four articles7–10 were companion papers containing additional analyses to supplement data reported in primary reports.11–14 Thus, the 118 articles represented 114 unique studies.

### Quality Assessment

The majority of RCTs scored three or less on the modified Jadad scale, thus earning a poor quality rating. No RCTs had a good rating. Only one cohort study15 had a poor quality rating; the majority of cohort studies were fair quality.

The major quality issues with the RCTs were an inadequate description of the randomization process, lack of reporting double blinding or the number and reason for participant withdrawals by study group, and absence of reporting methods to assess adverse effects.

The most problematic quality issue for cohort studies was the lack of control for confounding. Seventeen studies reported use of chi-square, t-test, or analysis of variance statistical methods without mention of adjustment for potential confounders such as age or sex.15–31 In nonrandomized designs, adjustment for confounding is essential to account for the presence of influential third party variables that may be distributed unevenly across study groups. This adjustment is especially important in HRA studies, where third party variables such as age and sex often have an effect on health outcomes. Twenty cohort studies reported analyses adjusted for at least one potential confounding variable.32–51

The cohort studies had higher quality ratings and scores than the RCTs. This does not mean that HRA researchers designed better cohort studies than RCTs, nor that readers should give more credence to cohort study results. Indeed, several cohort studies did not apparently adjust for confounding. In addition, the Jadad and NOS scales were formulated to rate dissimilar study designs using different criteria. Furthermore, RCTs rank higher on the medical evidence hierarchy than cohort studies. The Oxford Centre for Evidence-based Medicine (CEBM) ranks RCTs as level 1b evidence and cohort studies as level 2b evidence.52 Thus, we can conclude that level 1b evidence for HRAs is poor to fair quality, while level 2b evidence is fair to good quality. From a quality standpoint, the extracted HRA articles may communicate a fairly similar level of evidence, regardless of study design.

### Key Questions

#### KQ1 Describe the characteristics of the provision of HRAs, including the following

##### a Which specific HRAs were studied in the literature?

Most articles were concerned with participants’ general or cardiovascular health status and therefore employed a combination of questionnaire-based and physical or clinical HRAs. Only one specific HRA questionnaire, i.e., Personal Wellness Profile™,53 was certified by the National Committee for Quality Assurance (NCQA).

##### b What were the methods of HRA administration, e.g., telephone, Web-based, in the doctor’s office, community based, workplace based, or other?

Many HRAs were administered in the workplace, with 56 articles set in places of employment.8,9,12,13,15–20,23,25,26,28–30,33,36–45,47,50,51,54–79 Two HRAs involved the workplace and home.80,81 Eighteen HRAs were administered in physicians’ offices or medical clinics,22,31,32,34,49,82–94 1 in physicians’ offices and the workplace,35 1 in physicians’ offices and the home,95 and 1 in a laboratory.96 Six articles did not report the locale.7,10,11,48,97,98

Twenty-three HRAs were administered in community settings: community at large (e.g., random samples of the population),27,46,99–104 community-dwelling persons with disability,105 universities,21,24,106,107 schools,108,109 members of a managed care organization,110 smokers,111 regional health councils,14 members of five health plans,112 rural women,113 in pharmacies,114 or in the elderly.115,116 Ten studies took place in the home.117–126

Several studies made use of the Internet to administer HRAs, provide feedback, or to provide personalized recommendations to improve health outcomes.25,50,62,66,100,112

##### c What was the training of personnel who administered HRAs?

Training of personnel responsible for administering HRAs was variable and included 21 different training descriptions (e.g., dietician, wellness professional, physician) in 80 articles.9,13,15,16,18,20–23,26–35,38,40–45,47–49,51,58–65,67,68,70–77,79–81,83,85–87,89–95,97,103–108,110,111,114,116,117,120–124,126 Thirty-eight articles7,8,10–12,14,17,19,24,25,36,37,39,46,50,54–57,66,69,78,82,84,88,96,98–102,109,112,113,115,118,119,125 did not report training.

##### d What were the methods and frequencies of followup?

Feedback was provided in the form of personalized HRA results on paper printouts (n=97), or in writing (n=68), in person (n=80), via telephone (n=33) or e-mail (n=19), during group sessions (n=26), or via posted mail (n=52). Sometimes feedback was incorporated into the provision of exercise programs (n=15), or incentives to modify behavior (n=20). Two articles19,37 did not specify the form in which authors provided feedback. All other extracted articles utilized at least two forms of feedback provision, with the majority of articles (n=63) reporting four or five forms. One article employed eight forms of feedback provision.44

Frequencies of followup varied across studies, although 72 percent involved between one and four followup contacts (counting the four companion sets of papers as one study per set). Twenty-two studies had one contact, 34 had two contacts, 15 had three contacts, and 11 had four contacts. The remaining 29 studies had between five82 and 52 contacts.47 Three studies did not report frequencies of followup.15,45,86

We found no correlation between degrees of feedback or frequencies of followup and dropout rates. In the extracted articles, dropout rates ranged from 0 percent16,19,29,51,77,105,124,127 to 80 percent.44 Nine articles9,12,15,20,24,73,78,79,81 and two companion papers8,13 omitted reports of dropout rates.

##### e What were the characteristics of the patient populations who received HRAs?

Typical participants in the extracted articles were likely to be females between the ages of 30 and 50 years. Participants were generally drawn from workplace or community settings and displayed average health or were sometimes selected to represent groups with above average risk factors for disease.

Since most HRAs were workplace or community based, age concentrations in the 30 to 50 year subgroup simply reflected the largest proportion of persons in the workforce or general population.

#### KQ2 What characteristics of HRAs (Question 1 a to e above) are associated with better health outcomes?

We were unable to find patterns in the evidence to answer this key question. The feedback and recommendation components of HRA programs, more so than the specific forms of these programs or any other component considered in KQ1 a to e, appeared to produce encouragement and motivation among participants to modify behaviors.

We observed that a preponderance of health outcomes in the extracted studies were intermediate markers such as blood pressure or cholesterol level. Persons in HRA intervention groups tended to show positive benefits on these outcomes.

Many findings were not statistically significant at the five percent level, despite some large sample sizes (36 articles had more than 1,000 participants). In some of the large studies, authors found no differences between intervention and control groups in areas such as exercise frequency or smoking abstinence,62 or blood pressure or cholesterol levels.91 We could not conclude whether the followup periods were too short to detect between-group differences, or whether intervention programs were no better than control programs.

#### KQ3 What is the generalizability of the data in Questions 1 and 2 to the Medicare population or subpopulations?

We found 16 articles that included members of the Medicare population (i.e., persons aged 65 years or over).7,10,11,14,26,80,85,87,91,97,113,115,116,121,123,124 Although these 16 articles were similar to the other 99 extracted articles in terms of interventions and findings, researchers cannot readily generalize results from HRA studies in persons aged less than 65 years to persons aged 65 years or over. Many ‘under 65’ studies were conducted in workplaces or the community and the aim was downstream health cost reduction or primary prevention. In the senior population, workplace cost reduction may not apply because many seniors are no longer part of the workforce and seniors are more likely to already have chronic diseases relative to persons in younger age groups.

We believe study design issues such as short followup periods explain the similar results between ‘under 65’ and ‘over 65’ studies, rather than generalizability.

None of the extracted studies included other types of persons covered by Medicare (e.g., persons with renal failure). The specific health circumstances of these groups would suggest nongeneralizability of results from the extracted studies.

## Discussion

We extracted data from 118 articles investigating HRA programs that involved risk factor assessments, individualized feedback based on these assessments, and recommendations to reduce at least one risk factor or improve health status. Many HRA programs demonstrated improvements on intermediate health outcomes such as blood pressure, cholesterol, physical activity, or fat intake. However, only one article considered hard health outcomes (i.e., freedom from death, myocardial infarction, stroke, Class II–IV angina, or severe asymptomatic ischemia).85 Followup periods were often shorter than 24 months, therefore, we were unable to assess whether HRA programs produced health benefits over the medium to long term.

Sixteen articles included one segment of the Medicare population, namely persons aged 65 years or over. Overall results in these 16 articles mirrored the general results described in the previous paragraph. Despite the similarity of results, we do not believe the findings in studies of persons under age 65 years can be generalized to studies in senior populations.

We raised several issues that researchers should consider in future HRA studies: persons most likely to benefit from HRA programs may be more likely to drop out of these programs and durability of program effects may therefore decrease over time, short term HRA programs may improve intermediate health outcomes without affecting disease incidence, and some program effects may be due to a Hawthorne Effect. Also, more research should focus on delineating suitable timelines for HRA feedback, as well as on forming guidelines for determining the ‘appropriateness’ of HRA programs.