# Peer Reviewers

We wish to acknowledge individuals listed below for their review of this report. This report has been reviewed in draft form by individuals chosen for their expertise and diverse perspectives. The purpose of the review was to provide candid, objective, and critical comments for consideration by the EPC in preparation of the final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers.

- James Fries
  Professor
  Stanford University
  Palo Alto, CA
- Ron Goetzel
  Research Professor/Vice President
  Emory University/Thomson Reuters
  Washington, DC
- Victor J. Schoenbach
  Associate Professor
  Department of Epidemiology, UNC Gillings School of Global Public Health
  Chapel Hill, NC