# Acknowledgments

We would like to thank our librarian, Maureen Rice, for her thorough management of search terms and project methodology. We would also like to thank the following people who assisted with screening and data extraction: Sameer Rawal, Catherine Salmon, Rob Stevens and Kate Walker. Thank you to Mary Gauld for her assistance with project coordination and to Kim Wittenberg for being our Task Order Officer.

Thank you to our editorial staff, Leah Macdonald, Roxanne Cheeseman, Julianna Beckett, and Maureen Rice for providing invaluable input into this document, as well as to Bryan Cheeseman for his assistance managing our reference databases.