# Discussion

## Quality Assessment

We rated 54 percent (n=44) of the randomized controlled trials (RCTs) as poor quality and the remainder (n=37) as fair quality. None of the RCTs were rated good quality. Quality scores were biased downward because the Jadad scale’s adverse effects question was largely inapplicable to evaluating Health Risk Appraisals (HRAs).

Thirty-four of the 44 RCTs with a poor quality rating scored a borderline 3 on the Jadad scale. If the adverse effects question were applicable, then some of these articles would have received an additional point and been rated fair quality (Jadad score four to six). For fair quality articles, four of 37 articles scored a borderline six on the Jadad scale. Some of these articles could have received scores of seven had the adverse effects question been applicable. If we factor in the ‘adverse effects’ bias, then we could conclude that the overall quality of the RCTs was fair. We note the majority of RCTs did not report randomization processes, blinding, blinding processes, or withdrawals. Consequently, the average article quality still reflects serious reporting omissions, notwithstanding any downward bias in quality scores.

The cohort studies had higher quality ratings and scores than the RCTs. This does not mean that HRA researchers designed better cohort studies than RCTs, nor that readers should give more credence to cohort study results. Indeed, several cohort studies did not apparently adjust for confounding. Also, the Jadad and Newcastle-Ottawa Scale (NOS) were formulated to rate dissimilar study designs using different criteria. This means a poor rating on one scale does not necessarily equal a poor rating on the other scale. Furthermore, RCTs rank higher on the medical evidence hierarchy than cohort studies. The Oxford Centre for Evidence-based Medicine (CEBM) ranks RCTs as level 1b evidence and cohort studies as level 2b evidence.52 Thus, we can conclude that level 1b evidence for HRAs is poor to fair quality, while level 2b evidence is fair to good quality. From a quality standpoint, the extracted HRA articles may communicate a fairly similar level of evidence, regardless of study design.

Quality ratings are based on what authors report in their published manuscripts, rather than on what they may have actually done during the course of research. Low quality ratings could reflect poor reporting (perhaps prompted by journal word restrictions) instead of poor research. Authors are encouraged to follow standardized recommendations such as the CONSORT statement for preparing RCT manuscripts168 or the STROBE guidelines for reporting observational studies169 to promote complete and transparent reporting of findings and to facilitate the critical appraisal and interpretation of these findings.

The 118 extracted articles did not consistently adhere to any standardized reporting recommendations, nor did any author group explicitly mention whether they followed such recommendations. Thus, we were unable to assess whether low quality ratings reflected poor reporting or poor study conduct.

## Key Questions

### KQ1 Describe the characteristics of the provision of HRAs, including the following

#### a Which specific HRAs were studied in the literature?

Most articles were concerned with general or cardiovascular health assessments and therefore employed a combination of questionnaire-based and physical or clinical HRAs. Articles using questionnaires only often asked participants to self-report previous diagnoses or risk factors for disease (e.g., smoking). HRAs designed for specific objectives such as improving diet rather than improving general health often utilized questionnaires to elicit information on items like participants’ food intake.

Overall, we found no pattern of specific HRAs targeted to any one objective, nor were specific types of HRAs more likely to be used in RCTs versus cohort studies.

Questionnaire based risk factor and health status assessment in HRAs is necessary for many reasons. Practical and financial constraints may limit the number of physical or clinical tests that may be performed as part of an HRA program. Also, physical or clinical tests cannot ascertain certain risk factors (e.g., high risk sexual behavior).

The validity of self-reports is always an issue. Seminal research found over 90 percent accuracy when comparing self reported cases of breast, skin, large bowel, or thyroid cancer to medical records, although accuracy was lower for self reported lung, ovary, or uterine cancer.170 A review of the accuracy of self reported health behaviors and risk factors in cancer and cardiovascular disease found that self reported information underestimated the proportion of persons in the general population who were actually ‘at risk’. Also, the review showed that self reported risk factor prevalence in community settings was lower than prevalence estimates using gold standard data.171

Research results suggest that self-report cannot be the sole source of information for assessing risk factors and health status. Given the impracticality of collecting duplicate information using questionnaires and physical or clinical tests in every HRA setting, HRAs using self-reported data could collect information using validated questionnaires. If the validation process was appropriate, then persons employing HRAs could estimate potential misclassification rates on self report and perhaps collect supplemental data in subgroups known to contribute disproportionately to the misclassification.

#### b What were the methods of HRA administration (e.g., telephone, Web-based) in the doctor’s office, community-based, workplace-based, or other?

Fifty-six of 118 articles involved workplace HRAs. Many companies undertook HRAs to lower downstream costs associated with absenteeism, disability payouts, or insurance premiums. Non-workplace HRAs were implemented to promote positive health behaviors and lower risk factors for disease with the intent of reducing future morbidity and mortality associated with primarily chronic health challenges.

No specific type of HRA was associated with one place of administration versus another. For example, we could not conclude from the evidence that companies were more likely to use a mix of questionnaires and physical or clinical assessments relative to community health programs.

#### c What was the training of personnel who administered HRAs?

Training of personnel responsible for administering HRAs was variable and included 21 different descriptions in 80 articles (38 articles did not report training). The evidence does not suggest that one type of training was associated with any particular HRA or place of administration.

We relied on authors’ descriptions of training. Some general descriptors, (e.g., trained staff and project staff) may describe the same type of training, although most authors did not detail the specific training regimens required of staff.

#### d What were the methods and frequencies of followup?

HRAs involve multiple contacts with participants and typical followup methods were employed in the extracted articles to maintain these contacts. In workplace HRAs, meetings were a favorite means of contact because the employment locality was the locus of program delivery and targeted participants were often encouraged to partake in the program during or adjacent to working hours. As well, companies typically set aside facilities for HRAs under their sponsorship.

Some community-based HRAs also involved in person meetings, although the logistics of asking participants to report to ‘program delivery’ centers encouraged greater use of mail and telephone contacts in these situations.

The increasing popularity of the Internet, and high levels of computer penetration in people’s homes, spurred an impetus to evaluate Internet-based HRAs. However, HRAs administered entirely online might not reach groups at highest risk for chronic disease (e.g., elderly, low income) because persons in these groups may be less likely to have Internet access than younger or higher income groups. This issue was largely unstudied in the extracted articles, indicating that more work is needed to assess the efficacy of online HRA delivery.

Frequency of followup is important in HRAs. The benefits of HRAs, especially for reducing chronic disease incidence, are unlikely to manifest themselves in the short term. Also, maintenance of benefit requires continued adherence to recommendations arising from HRAs. This is especially important in high risk groups, who are more likely than low risk groups to live sedentary lifestyles and engage in less healthy behaviors. Maintenance of HRA objectives such as exercise regimens or adequate cholesterol and blood pressure levels in high risk groups requires regular monitoring and encouragement over time, so HRAs with few followup contacts are likely to achieve low success in the medium to long term. Twenty-seven extracted articles had only one post-baseline followup contact. This may in part be due to financial constraints faced by researchers conducting the studies.

Readers should note that frequency of followup is different from the reporting of study results. While a majority of articles had multiple contacts with participants, authors tended to report results for the point in time that corresponded to the end of follow-up. This prevented us from assessing the durability of HRAs over time.

The extracted articles contained many different forms of feedback (e.g., written recommendations, in-person counseling). Most articles employed at least two forms. Multiple types of feedback could promote participant engagement. The variety of feedback itself could be enough to keep participants interested in a study. Also, some forms of feedback might suit the participants’ preferences better than others, so variety could enhance the chance of targetting more particpants with preferred modes of feedback, thus maintaining engagement. However, we did not find correlations between form of feedback or frequency of followup and dropout rate. Further research is required to elicit the specific factors that influence participation in HRAs.

#### e What were the characteristics of the patient populations who received HRAs?

Typical participants in the extracted articles were likely to be females between the ages of 30 and 50 years. Participants were generally drawn from workplace or community settings and displayed average health.

The preponderance of females in the extracted articles might be due to three factors. First, women may be more likely to participate in research; second, women were the targets of several articles;22,25,55,61,82,91,102,103,113,117,120 third, some articles were conducted in settings with a preponderance of women (e.g., hospital staff).69

Since most HRAs were workplace or community based, age concentrations in the 30 to 50 year subgroup simply reflected the largest proportions of persons in the workforce or general population.

### KQ2 What characteristics of HRAs (KQ1 a to e above) are associated with better health outcomes?

The evidence did not suggest a clear set of characteristics that were associated with better health outcomes. The feedback and recommendation components of HRA programs appeared to be the primary factors producing encouragement and motivation among participants to modify behaviors, certainly more so than any other component considered in Question 1 a–e. However, the evidence did not suggest a specific feedback or recommendation protocol that was more able than others to lead to behavior modification that would produce better health outcomes.

A systematic review of workplace HRAs128 found positive effects on outcomes when health risk assessment and feedback were supplemented with health education. However, health education was complemented by other supplemental interventions in 43 of 60 HRAs that included an education component. Furthermore, health education interventions were heterogeneous regarding frequency, setting (individual, group, both), and topics. Thus, the specific effect of health education on outcomes, as well as the optimal form of health education, could not be identified in the review.

Many HRA interventions with multiple contacts between participants and project staff showed benefits versus controls, although article methodologies, samples, and HRA designs were too heterogeneous for the additional potential benefits of specific multiple contacts to be quantified. However, given Dillman’s work172 in survey design and response, multiple contacts using varying contact methods are more likely to generate and maintain participant engagement. In the extracted articles, an example of a ‘multi contact’ HRA was one program involving written feedback, counseling, referrals, and in person and telephone followups.85

One element in KQ1, namely training of personnel administering HRAs, was not reported in 38 articles. Program staff must be versed in delivering an HRA, whether their responsibilities are to administer spirometry tests and measure lung function or deliver specialized individual counseling to persons at high risk of disease. However, staff must also be ‘customer friendly’ to build rapport with participants. While the benefits of a ‘personal touch’ are difficult to quantify in research, staff professionalism can make a difference in participant recruitment and retention. Researchers should report the types of training given to staff. We consider training to be the specific teaching and instruction given to staff to run HRA programs.

We observed that a preponderance of health outcomes in the extracted articles were intermediate markers such as blood pressure, cholesterol level, or physical activity. Persons in HRA intervention groups tended to show positive benefits on these outcomes. Since changes in intermediate outcomes do not confirm whether disease will occur at some point in the future,173 we can conclude that many HRA programs improved health behaviors (e.g., more physical activity) or biological measures (e.g., lower cholesterol), but we cannot conclude how these improvements might affect future disease incidence.

We recognize the difficulty of conducting followups in research that are long enough to detect the incidence of chronic disease. Prohibitive followup times would be required to wait for such diseases to occur. Consequently, intermediate markers serve as one means of assessing HRA outcomes given followup constraints. Many extracted articles (n=56) involved two or fewer followup contacts with participants and a majority (n=97) had total followup periods of 24 months or less.

Many findings in the extracted articles were not statistically significant at the five percent level, despite some large sample sizes (36 articles had more than 1,000 participants). In some of the large studies, authors found no differences between intervention and control groups in areas such as exercise frequency or smoking abstinence,62 or blood pressure or cholesterol levels.91 We could not conclude whether the followup periods were too short to detect between-group differences, keeping in mind the substantive benefits of HRAs are likely to accrue over the medium or long term, or whether intervention programs were no better than control programs.

### KQ3 What is the generalizability of the data in KQ1 and KQ2 to the Medicare population or subpopulations?

We found 16 articles that included members of the Medicare population, i.e., persons aged 65 years or over.7,10,11,14,26,80,85,87,91,97,113,115,116,121,123,124 Although these 16 articles were similar to the other 99 extracted articles in terms of interventions and findings, researchers cannot readily generalize results from HRA studies in persons aged less than 65 years to persons aged 65 years or over. Many ‘under 65’ studies were conducted in workplaces or the community and the aim was primary prevention (i.e., lowering risk factors to prevent disease incidence). In workplaces, companies also implemented HRAs in the hope of lowering future costs associated with lost productivity or disability/insurance payouts due to worker sickness.

In the senior population (i.e., persons age 65 years or over), workplace cost reduction may not apply since many seniors are no longer part of the workforce. Nevertheless, HRA programs could benefit active, healthy seniors with no chronic disease or seniors who are only mildly affected by chronic disease (mainly primary prevention). Additionally, HRA programs could benefit sick, frail seniors who are already affected and impaired by chronic disease (secondary or tertiary prevention). In the sick and frail population, HRA programs could be tailored to the specific needs of seniors facing health challenges. For example, feedback and recommendations might be different for persons with cardiovascular disease versus persons with permanent mobility limitations.

Due to the issues raised above, results of HRAs designed for young or middle aged members of the general community, or for workers (who may be healthier than average members of the population),174 may not be readily transferable to seniors. Researchers who adopt an ‘output oriented’ approach and infer generalizability based on the similarity of HRA results between articles risk ignoring the fundamental differences between the thrust of HRA programs in seniors versus programs in workers or members of the general public.

We believe the same design issues discussed in KQ2 above (e.g., short followups) explain the similar results between ‘under 65’ and ‘over 65’ studies, rather than generalizability.

None of the extracted articles included other types of persons covered by Medicare (e.g., persons with renal failure). The specific health circumstances of these groups would suggest non-generalizability of results from the extracted articles.

Besides outcomes, the mode of HRA administration is important to consider in the Medicare population. Health and mobility challenges in many seniors limit the ‘external’ settings available to conduct HRAs. Seniors may be more likely to participate in HRAs that involve home visits or external visits to familiar locations such as doctor’s offices. Similarly, today’s seniors will be more receptive to HRAs using technologically appropriate methods such as paper and pencil questionnaires rather than Internet based questionnaires. Although 42 percent of seniors access the Internet to check e-mail and search for information or follow current events, they are less likely to view online videos or send instant messages.175 Thus, the effectiveness of Internet based HRAs in this group is questionable. In the 10 extracted articles, HRA settings included health-related establishments such as doctor’s offices,87 hospitals,85 or regional health councils,14 community-based recruitment,115 or the workplace.26 Three articles did not report the setting.7,11,97 Five articles conducted followup through the mail,7,11,14,87,113 four through in-person meetings,85,91,97,115 one via telephone (in addition to in person meetings),85 and one via computer.26

## Additional Issues to Consider in the Evaluation of Health Risk Appraisal Programs

Our review of the HRA literature raised five further issues to consider. First, we were interested in the durability of effects from HRA programs. Since these programs are designed to alter people’s behavior, and the biggest program benefits are likely to accrue in persons with sedentary and unhealthy lifestyles, durability is an issue. Over time, persons with such lifestyles might be challenged to continue adhering to HRA-prescribed recommendations. Even healthy individuals may abandon recommendations, possibly because they do not see the potential long term advantages of taking additional steps to secure already healthy lifestyles. Thus, we wondered if the efficacy of HRA programs would decrease over time.

Since so few articles reported results at more than two time points, we did not have enough data to observe whether program efficacy decreased over time. We attempted to assess the impact of durability using authors’ reported dropout rates. These rates ranged from 0 to 25 percent in half (n=59) the extracted articles, although they primarily pertained to short term periods due to the limited lengths of followup in most articles. In articles with followup beyond 24 months, we observed higher dropout rates, including 40 percent after 30 months,110 55 percent after 48 months,37 27 percent after 60 months,89 and 82 percent (intervention group) and 40 percent (control group) after 108 months.39 While some articles compared characteristics of dropouts with persons who completed followup, we could not assess how outcomes might have differed had dropouts instead completed the studies. Also, we could not assess peoples’ motivations for dropping out because authors typically did not report such data. We suspected durability would impact results, but we could not explore the issue in depth given the available data.

Second, we were interested in the timeliness of the feedback to participants regarding their HRA results. Rapid return of results maintains participant engagement and encourages the issuance of recommendations to promote health, sustain function, or prevent disease that are commensurate with participants’ current health status. Long lags in feedback provision could promote participant disinterest or lead to outdated recommendations.

The authors of 68 articles12,14–17,24,25,27,29–33,35–38,41,45,50,56–62,64–66,68–72,74,76–78,84,86–89,91,93–97,99–101,104,107–109,111,113,116–119,121,122,124–126 and two companion papers8,10 wrote their text to emphasize the timeliness of feedback, which was usually implied to be at some point soon after the initial HRA (e.g., two weeks,68 four weeks15). However, we were unable to find a gold standard timeframe within which participants’ initial HRA results should be returned. Due to heterogeneity of timeframes, study populations, and outcome measures, we could not assess whether an association existed between timeliness and participant outcomes. We can only conclude that HRA results should be made available to participants as soon as possible after the administration of the HRA.

Thirdly, we considered whether the HRAs, forms of feedback, and recommendations were appropriate for the various study populations in the extracted articles. In the absence of generally-accepted guidelines for an ‘appropriate’ HRA program, we were unable to address this issue globally or in terms of specific study populations. Two exceptions include the use of an online component in HRA programs and the generalizability of workplace HRA programs to older populations, which we discussed above.

A fourth issue we considered concerned the fact that chronic diseases develop in persons over time, often after years of exposure to combinations of environmental and lifestyle risk factors. Additionally, genetic components affect individual susceptibility to these diseases. We doubted whether HRA programs lasting for periods under 24 months, which formed the bulk of programs researched in the extracted articles, could overcome the negative effects of a constellation of environmental, lifestyle, and genetic risk factors that may already have been operating in tandem for years to create the set of conditions necessary for the development of chronic disease. Given the dearth of disease-based outcomes (e.g., incidence of actual diseases in intervention versus control groups) in the extracted articles, we were unable to assess whether the short-term HRA programs included in most of the extracted articles prevented disease. Indeed, even if authors evaluated disease-based outcomes in short-term studies, we doubt the followups would have been long enough to detect differences in disease incidence between intervention and control groups.

The fifth issue was the extent to which observed results were due to a sort of ‘Hawthorne Effect,’ which is a term describing situations where people alter behaviors due to the attention they receive from participating in a research study, rather than from researchers’ manipulation of study variables (e.g., assignment to intervention or control groups).176 Programs that supplement feedback and recommendations with contact such as counseling or telephone followup may motivate participants to adhere to recommendations out of a desire to please project staff, regardless of the types of contacts.

## Conclusions

We extracted data from 118 articles investigating HRA programs that involved risk factor assessments, individualized feedback based on these assessments, and recommendations to reduce at least one risk factor or improve health status. Many HRA programs demonstrated improvements on intermediate health outcomes such as blood pressure, cholesterol, physical activity, or fat intake. However, only one article considered hard health outcomes (i.e., freedom from any of the following after 24-month followup: death, myocardial infarction, stroke, Class II–IV angina, or sever asymptomatic ischemia ).85 Also, followup periods were often shorter than 24 months. Therefore, we were unable to assess whether HRA programs produced health benefits over the medium to long term.

Sixteen articles included one segment of the Medicare population, namely persons aged 65 years or over. Overall results in these 16 articles mirrored the general results described in the previous paragraph. Despite the similarity of results, we do not believe the findings in studies of persons under age 65 years can be generalized to studies of the senior population.

We raised several issues that researchers should consider in future HRA studies: persons most likely to benefit from HRA programs may be more likely to drop out of these programs and durability of program effects may therefore decrease over time, short term HRA programs may improve intermediate health outcomes without affecting disease incidence, and some program effects may be due to a Hawthorne Effect. Also, more research should focus on delineating suitable timelines for HRA feedback, as well as on forming guidelines for determining the ‘appropriateness’ of HRA programs.