# Results

## Literature Review and Screening

The literature search yielded 5,973 unique citations. In total, 5,434 citations (91 percent) were excluded from further review following the two levels of title and abstract screening. Of the 539 citations promoted to full text screening, 421 (78 percent) were excluded, and 118 (22 percent) proceeded to full data extraction and quality assessment. We were unable to retrieve 8 articles143–150 despite extensive searches of library holdings from multiple universities, interlibrary loan requests, and contact with authors. Figure 1 depicts the flow of articles through screening. As well, the figure shows the reasons for article exclusion at full text screening.

Figure 1 Flow of articles through screening

Figure 1 is a flow diagram indicating the numbers of citations included and excluded at each level of screening. The literature search yielded 5973 unique citations. In total, 5255 citations were excluded from further review following the initial level of title and abstract screening. Out of the 718 citations promoted to the second level of title and abstract screening, 179 were excluded and 539 proceeded to full text screening. Of the 539 articles reviewed at full text, 421 were excluded. This exclusion number included 8 articles that could not be retrieved despite extensive searches of library holdings from multiple universities, inter-library loan requests, and contacts with authors. This left 118 articles that passed full text screening and proceeded to data extraction and quality assessment.

The 118 extracted articles included 81 RCTs (Table 1) and 37 cohort studies (Table 2). Four articles7–10 were companion papers containing additional analyses to supplement data reported in primary reports.11–14 Thus, the 118 articles represented 114 unique studies.

Table 1 Quality assessment of randomized controlled trials with Jadad Scale

Article | Jadad Score | Quality Rating
Alexander112 2010 | 4 | Fair
Aronow105 2005 | 2 | Poor
Baer106 2001 | 4 | Fair
Blalock102 2002 | 3 | Poor
Boudreau54 1995 | 2 | Poor
Braeckman70 1999 | 3 | Poor
Brennan121 2010 | 6 | Fair
Brug56 1996 | 2 | Poor
Campbell55 2002 | 3 | Poor
Campbell84 1994 | 3 | Poor
Charlson85 2008 | 6 | Fair
Cockcroft69 1994 | 3 | Poor
Connell57 1995 | 3 | Poor
Crouch68 1986 | 3 | Poor
Dally110 2002 | 3 | Poor
De Bourdeaudhuij66 2007 | 2 | Poor
De Bourdeaudhuij108 2010 | 2 | Poor
Edelman107 2006 | 5 | Fair
Elliot58 2007 | 4 | Fair
Elliot59 2004 | 3 | Poor
Ferrer86 2009 | 3 | Poor
Fielding79 1995 | 5 | Fair
Fjeldsoe103 2010 | 5 | Fair
Fries123 1994 | 3 | Poor
Fries7 1993 | 3 | Poor
Fries7 1993 | 3 | Poor
Gagnon104 2010 | 3 | Poor
Gallagher124 1996 | 4 | Fair
Gemson71 1995 | 4 | Fair
Godin96 1987 | 1 | Poor
Gomel12 1993 | 3 | Poor
Gomel8 1997 | 3 | Poor
Haerens109 2009 | 3 | Poor
Hanlon72 1995 | 4 | Fair
Harari87 2008 | 5 | Fair
Heirich73 1993 | 2 | Poor
Kim98 2010 | 6 | Fair
Kreuter88 1996 | 3 | Poor
Kroeze99 2008 | 3 | Poor
Lalonde114 2006 | 4 | Fair
Lauritzen89 2008 | 3 | Poor
Lawler122 2010 | 5 | Fair
Leigh11 1992 | 2 | Poor
Lowensteyn93 1998 | 4 | Fair
Makrides80 2008 | 4 | Fair
Maron60 2008 | 4 | Fair
Maruyama74 2010 | 4 | Fair
Mayer97 1994 | 4 | Fair
McClure111 2009 | 5 | Fair
Meng115 2010 | 3 | Poor
Nice125 1990 | 3 | Poor
Nisbeth67 2000 | 5 | Fair
Nitzke126 2007 | 5 | Fair
Nurminen61 2002 | 5 | Fair
Pelletier81 1998 | 3 | Poor
Peters75 1999 | 4 | Fair
Prochaska62 2008 | 3 | Poor
Proper63 2003 | 5 | Fair
Racette76 2009 | 4 | Fair
Rahe77 2002 | 4 | Fair
Selbst78 1992 | 6 | Fair
Smeets101 2008 | 4 | Fair
Smith94 1985 | 2 | Poor
Sorensen64 2007 | 3 | Poor
Spittaels100 2007 | 3 | Poor
Spoth95 1991 | 3 | Poor
Steptoe90 1999 | 3 | Poor
Stevens82 2002 | 3 | Poor
Stoddard91 2004 | 3 | Poor
Strychar65 1998 | 3 | Poor
Stuifbergen120 2010 | 5 | Fair
Taimela9 2008 | 5 | Fair
Taimela13 2008 | 5 | Fair
Toft83 2008 | 4 | Fair
van Stralen10 2010 | 3 | Poor
van Stralen14 2009 | 3 | Poor
van ’t Riet119 2010 | 2 | Poor
Vandelanotte118 2005 | 4 | Fair
Von Huth92 2008 | 3 | Poor
Walker113 2009 | 4 | Fair
Walker117 2010 | 3 | Poor
Wallace^116^1998 | 5 | Fair

Table 2 Quality assessment of cohort studies with Newcastle-Ottawa Scale (NOS)

Article | NOS Star Rating | Quality Assessment
Angotti39 2000 | 8 | Good
Bergstrom42 2008 | 6 | Fair
Bertera15 1993 | 2 | Poor
Blair45 1986 | 8 | Good
Blair28 1986 | 5 | Fair
Breslow40 1990 | 8 | Good
Chan21 1988 | 6 | Fair
Erfurt18 1991 | 6 | Fair
Faghri16 2008 | 6 | Fair
Fouad43 1997 | 8 | Fair
Gold46 2000 | 6 | Fair
Goetzel51 1994 | 7 | Good
Goetzel19 2002 | 6 | Fair
Hedberg41 1998 | 8 | Good
Herman44 2006 | 5 | Fair
Holt47 1995 | 7 | Good
Karlehagen30 2003 | 6 | Fair
Kemper48 2002 | 6 | Fair
Korolewski29 1984 | 4 | Fair
Lingfors49 2009 | 4 | Fair
Maes26 1992 | 6 | Fair
McKee32 2010 | 5 | Fair
Mills50 2007 | 8 | Good
Moy17 2006 | 7 | Good
O’Loughlin36 1996 | 6 | Fair
Papadaki25 2008 | 5 | Fair
Pescatello37 2001 | 8 | Good
Puska38 1988 | 8 | Good
Richter22 1987 | 6 | Fair
Sabti31 2010 | 5 | Fair
Shephard23 1982 | 6 | Fair
Shi33 1992 | 6 | Fair
Singleton34 1988 | 5 | Fair
Talvi35 1999 | 8 | Good
van Beurden27 1990 | 6 | Fair
Wilson24 1980 | 7 | Good
Yen20 2001 | 4 | Fair

Sample sizes ranged from less than 100 participants in 16 articles16,22,24,25,34,43,59,71,74,75,81,95,103,114,116,125 to greater than 1,000 participants in 36 articles.7,11,14,15,18–20,28,31,33,39,40,42,44–46,49–51,57,62,64,72,73,78,83,87–89,91,92,97,98,112,123,126 Forty-two articles had between 100 and 500 participants8,12,17,21,23,27,29,30,32,36,37,41,48,54,56,60,61,63,65–68,76,79,80,84,93,94,96,100,101,104–107,113,115,117,119,120,122,124 and 24 articles had between 501 and 1,000 participants.9,10,13,26,35,38,47,55,58,69,70,77,82,85,86,90,99,102,108–111,118,121

## Quality Assessment

Figures 2 and 3 depict the number of articles rated good, fair, or poor quality. The majority of randomized controlled trials (RCTs) scored a three or less on the modified Jadad scale, thus earning a poor quality rating. No RCTs had a good rating. Only one cohort study15 had a poor quality rating; the majority of cohort studies were fair quality. Quality scores and ratings for each article are shown in Tables 1 and 2.

Figure 2 Distribution of quality ratings - randomized controlled trials

Figure 2 is a bar graph that illustrates the distribution of quality rankings for the 81 included randomized control trials which were evaluated using the modified Jadad scale. The graph is composed of three vertical bars. The bar on the left represents the 44 RCT’s that were given a quality rating of poor. The middle bar represents the 37 studies given a quality rating of fair and the bar on the right represents the good quality RCTs, which number zero.

Figure 3 Distribution of quality ratings - cohort studies

Figure 3 contains a bar graph with three bars and depicts the distribution of quality rankings of the 37 observational studies which were ranked using the Newcastle-Ottawa Scale (NOS). The bar on the left represents the 1 study that was given a quality rating of poor. The middle bar represents the 24 studies given a quality rating of fair and the bar on the right represents the 12 studies given a quality rating of good.

Almost all RCTs reported randomization of study participants, types of statistical methods used to analyze data, and inclusion and exclusion criteria.

The major quality issues with a majority of the RCTs were: inadequate descriptions of the randomization process, lack of reporting of double blinding, inadequate specification of the number and reason for participant withdrawals by study group, and lack of discussion of methods used to assess adverse effects.

Lack of reporting of the randomization process is common in many RCTs, although a simple sentence (e.g., “Patients were randomized using a computer generated sequence of random numbers”) should suffice to communicate the integrity of the randomization process. Less acceptable methods of randomization, such as tossing coins or distributing envelopes containing group assignments, may be nonrandom or more susceptible to manipulation. To adequately assess the methodological quality of RCTs, authors should report the randomization process.

Double blinding may have been impossible in many of the studies due to the nature of the interventions. For example, blinding of participants in the same workplace might be difficult if the intervention is individual behavioral counseling given after an HRA versus an HRA alone. Coworkers may become aware of each other’s group assignments simply through casual ‘watercooler’ conversations. Some studies attempted to control for the inability to blind participants through cluster randomization, where entire worksites received a single intervention. While this might solve the challenge of participant blinding, investigators, data collectors, and data analysts could still be aware of participants’ group allocation. In these instances, investigators and data analysts could be blinded to group allocation. Also, in cluster-randomized trials, investigators could blind data collectors to study hypotheses, provide them with uniform training, and assign them to specific sites to minimize bias. Since none of the RCTs mentioned whether any of these steps were taken to blind research team members, we cannot ascertain whether knowledge of participants’ group assignments may have biased any results.

Regarding withdrawals, nonreporting of numbers and reasons for withdrawals in study groups prevents readers from assessing whether statistical comparisons are really being done on comparable groups.

Reporting of adverse effects was generally nonexistent. While adverse effects are an essential reporting component in RCTs of medical treatments, one can likely expect few, if any, adverse effects from an HRA program. Consequently, this element of the Jadad scale did not apply to many of the included RCTs. However, adverse effects may be applicable to some HRAs, such as those whose individual recommendations to improve health include specific medical treatments. In these cases, the need to report the methods used to assess adverse effects from treatment, as well as the effects themselves, would become important.

Compared to the RCTs, the cohort studies had higher overall quality ratings. The ‘exposed’ groups (i.e., participants receiving the intervention of interest) were somewhat or truly representative of the source population in almost all of the articles and the ‘nonexposed’ groups (i.e., participants serving as controls) were almost always drawn from the same population as the controls. Most cohort studies clearly described how participants were allocated to intervention and control groups.

Regarding adequacy of participant followup, half of the studies reported complete followup or had such small losses to followup that results were unlikely to be biased. The remaining studies reported followup rates yet did not describe characteristics of participants who were lost to followup, or they contained no statement about losses to followup.

The most problematic quality issue for cohort studies was the lack of control for confounding. Seventeen studies reported use of chi-square, t-test, or analysis of variance statistical methods without mention of adjustment for potential confounders such as age or sex.15–31 In nonrandomized designs, adjustment for confounding is essential to account for the presence of influential third party variables that may be distributed unevenly across study groups. This adjustment is especially important in HRA studies, where third party variables such as age and gender often have an effect on health outcomes. Twenty cohort studies reported analyses adjusted for at least one potential confounding variable.32–51

Two NOS questions pertain to outcomes. One question asks whether the outcome of interest was absent at the start of the study. In a typical epidemiologic cohort study, the outcome should be absent in all participants at baseline to assess the incidence rates of the outcome in the exposed and nonexposed groups over time, as well as to calculate a relative risk. In the included cohort studies, which were essentially nonrandomized trials rather than epidemiology studies, the outcomes were longitudinal changes in health indicators such as body mass index (BMI) or cardiovascular disease (CVD) risk index. Consequently, we assigned a star for this question if the studies reported a comparison of health outcome measures at baseline and some future followup point. All except one article34 earned a star for this question.

The other outcome question pertained to the method of assessing outcomes. We assigned a star if the studies used blinded outcomes assessors or a method of assessment that was likely to minimize bias in the event of unblinded outcomes assessment (e.g., a structured interview questionnaire, physical performance tests [e.g., chair rise], or clinical tests [e.g., spirometry]). Although no article reported blinded assessment, all except four studies28,31,34,44 employed a method that was likely to minimize biases associated with unblinded outcomes assessment.

The final quality issue for cohort studies was whether lengths of followup were long enough for outcomes to occur. We awarded a star for studies with followups of at least one year, although this cutoff point was somewhat arbitrary. The goal of most HRAs was to effect lasting beneficial changes in areas such as CVD risk, smoking cessation, or physical fitness. While many authors reported immediate gains from HRAs, positive changes in health outcomes often decreased over time as more participants stopped adhering to the recommendations necessary to maintain benefits. We felt 1 year was the minimum time period to examine durable HRA effects, although extended periods may be necessary to evaluate long-term benefits.

The Jadad scale does not include questions on outcomes and lengths of followup. However, the extracted RCTs largely mirrored the cohort studies in the area of outcomes. RCT outcomes were typically changes in health indicators over time. Lengths of followup, though, were one year or less in 66 RCTs, which indicates that most trials contained inadequate evidence to evaluate the long-term effects of HRAs.

## Key Questions

### 1 Describe the characteristics of the provision of HRAs, including the following

#### a Which specific HRAs were studied in the literature?

Most HRAs in the extracted articles (n=68) were developed to address and improve general health. Another major HRA objective was to improve cardiovascular health (n=36). Figure 4 shows the objectives of the HRAs in the extracted studies.

Figure 4 Objective of health risk appraisals

Notes: See evidence tables (Appendix D) for explanation of ‘other’ category; specific articles may have reported more than 1 type of objective.

Figure 4 presents a summary of the information provided in Table 3 in bar graph form. The graph is composed of six vertical bars that illustrate the health condition targeted by the intervention. The first bar represents 24 interventions targeting obesity/weight. The second bar represents 29 interventions targeting smoking cessation. The third bar represents 30 interventions with defined targets other than those in the other categories (for example, seat belt usage, absenteeism). The fourth bar represents 36 interventions targetting cardiovascular health. The fifth bar represents 54 interventions targeting physical activity. The last bar represents 68 interventions targeting general health.

The HRA instruments themselves were questionnaire-based tools designed specifically for the purpose of conducting HRAs, (e.g., Personal Wellness Profile™53). Other questionnaires used as HRAs were originally developed to measure constructs such as depression, self-reported disease risk factors, or behaviors such as food intake. Another group of HRAs were composed of physical (e.g., treadmill time) or clinical assessments (e.g., blood pressure, cholesterol) (Figure 5). Forty-eight articles contained only questionnaire-based HRAs9,10,13,14,21,22,24,29,31,32,34,36,42,43,48,54–56,61,64,77,81–84,87,92,98,101,103–110,112,115,116,118–120,122–126 and nine contained only physical or clinical assessments.27,30,37–39,68,69,78,79 Sixty-one articles had a mixture of questionnaire-based and clinical or physical assessments (Figure 5).7,8,11,12,15–20,23,25,26,28,33,35,40,41,44–47,49–51,57–60,62,63,65–67,70–76,80,85,86,88–91,93–97,99,100,102,111,113,114,117,121

Figure 5 Types of health risk appraisals

Figure 5 is a bar graph that illustrates the type of health risk appraisal in the study. The graph is composed of three bars. The bar on the left represents 9 Physical/Clinical Assessments. The middle bar represents 48 questionnaire based assessments. The last bar represents 61 instances where a combination of both physical/clinical and questionnaire based assessments were used.

Evidence Table 2 (Appendix D) lists the specific HRA questionnaires used in the extracted studies. Ninety-eight instances of named questionnaires (e.g., Lifestyle Assessment Questionnaire151,152) occurred in articles applying to the nonMedicare population. Some of these questionnaires were used in more than one article, and some articles employed more than one questionnaire. We tallied 42 miscellaneous HRA questionnaires, which composed compellations of measures likely taken from different sources (e.g., Heirich et al., HRA measured blood pressure, height, weight, frequency of exercise, and a brief patient history),73 author-developed instruments (e.g., Puska et al., baseline survey),38 vaguely described scales (e.g., De Bourdeauhuij et al., questions about psychosocial determinants of fat intake),66 or groups of questionnaires stitched together to form a single HRA instrument (e.g., Blair et al., physical exam, medical history, psychosocial questionnaire, job satisfaction and self-concept scales, health habits questionnaire, health risk appraisal questionnaire, clinical measurements, and fitness assessment).45 Seven articles did not report the HRA questionnaire.27,34,43,68,78,79,104 Only two instruments, namely the Personal Wellness Profile™,53 and the Insight ® Health Risk Appraisal Survey 19 were certified by the National Committee for Quality Assurance (NCQA).

The authors of 50 articles (see Evidence Table 2, Appendix D) reported the source of their HRA questionnaires or referenced research into the psychometric properties of these questionnaires.

In the 16 articles pertaining to the Medicare population (i.e., persons aged 65 years or over), 10^10,14,80,87,91,113,115,116,123,124^ reported use of specific questionnaires: Health Risk Appraisal for Older Persons,153 Outcomes and Assessment Information Set (OASIS) ADLs scale,154 HealthChek® Personal Risk Assessment (PRA) from Medical Sciences, Inc. Boston, MA., Short Questionnaire to Assess Health-enhancing Physical Activity (SQUASH),155 Physical Readniness Activity Questionnaire,156 Health Assessment Questionnaire,157 and Wellsource Inc.’s Personal Wellness Profile™.53

Validity data exist for OASIS, SQUASH, Health Assessment Questionnaire, and Personal Wellness Profile™. For OASIS, interrater reliability in 88 patients (mean age = 78 years) from 21 home healthcare agencies was good to excellent, with weighted kappa values ranging from 0.66 to 1.0 across 25 questionnaire items.158 For SQUASH, 50 persons aged 27 to 58 years completed the questionnaire twice with a 5-week interval between administrations.155 Spearman’s correlation coefficient for overall test-retest reliability was 0.58 (95 percent confidence interval: 0.36 to 0.74), while correlation coefficients (r) for separate questions ranged from 0.44 to 0.96. The Health Assessment Questionnaire, originally developed for use in rheumatoid arthritis studies, is a good predictor of future disability, with strong test-retest reliability (r varies from 0.87 to 0.99) and criterion validity (r varies from 0.71 to 0.95 in comparisons of questionnaires score and task performance). The Health Assessment Questionnaire also demonstrates good face, content, convergent, and predictive validity.157 The Personal Wellness Profile™ correlates with scales measuring stress, alcoholism, and nicotine dependence, and correlates with portions of a scale measuring food preference. The Personal Wellness Profile™ has good internal consistency (r=0.77) and reliable subscale scores (r=0.52 to 0.90).159

Two studies in the Medicare population used multiple questionnaires to form HRA instruments. The first article124 used the well-validated Short-Form Health Survey (SF-36) to measure quality of life,160 Advanced Activities of Daily Living Scale to measure social functioning (validity demonstrated in initial publication only),161 and an unpublished scale to measure falls.162 The second article116 employed the SF-36^160^ and the Centre for Epidemiologic Studies Depression Scale (CES-D).163 The CES-D has high internal consistency (Cronbach’s alpha = 0.85 in community samples and 0.90 in psychiatric samples) and moderate test-retest reliability (r=0.51 to 0.67). The CES-D is moderately correlated with the Hamilton Rating Scale for Depression (r=0.49 for patients with acute depression and 0.85 for patients with schizophrenia).164

One article85 in the Medicare population used a questionnaire with items drawn from several sources. The questionnaire elicited data on 13 cardiac risk factors, including physical activity, smoking, diet, and medications. The questionnaire included the Food Frequency Questionnaire (FFQ)165 and Modified Minnesota Leisure Time Activity Questionnaire (MMLTA).166 Data on psychometric properties exist for the FFQ.165 One hundred twenty-seven men completed the FFQ twice with a 1 year interval between administrations. During the interval, participants completed two 1 week diet records spaced approximately 6 months apart. Intraclass correlation coefficients comparing nutrient intakes assessed by FFQ versus diet record ranged from 0.28 to 0.86, depending on the specific nutrient (e.g., vitamin C) or questionnaire comparison under evaluation.

Two studies7,11 in the Medicare population used an author-developed ‘Health Risk Score’ that was adapted from the Healthtrac Health Assessment Questionnaire.157 Fries et al., evaluated the psychometric properties of the Health Risk Score in 914 control subjects and found good 6-month test-retest reliability (r=0.79),7 although convergent validity was poor (r=0.18) compared to current global health (visual analog scale of 0 to 100). Health Risk Score was somewhat correlated with minutes-per-week of exercise (r=0.33) and moderarely correlated with packs-per-day of smoking (r=0.65).

Three studies in the Medicare population did not contain information about, or references to, the psychometric properties of the HRA questionnaires used in the research.10,26,97 One article utilized a blood pressure monitor and self-report questions without reporting on the psychometric properties of the self-report questions.121

#### b What were the methods of HRA administration (e.g., telephone, Web-based) in the doctor’s office, community based, workplace based, or other?

Many HRAs were administered in the workplace, with 56 articles set in places of employment.8,9,12,13,15–20,23,25,26,28–30,33,36–45,47,50,51,54–79 Two HRAs involved the workplace and home.80,81 Eighteen HRAs were administered in physicians’ offices or medical clinics,22,31,32,34,49,82–94 one in physicians’ offices and the workplace,35 one in physicians’ offices and the home,95 and one in a laboratory.96 Six articles did not report the locale.7,10,11,48,97,98

Twenty-three HRAs were administered in community settings: community at large (e.g., random samples of the population),27,46,99–104 community-dwelling persons with disability,105 universities,21,24,106,107 schools,108,109 members of a managed care organization,110 smokers,111 regional health councils,14 members of five health plans,112 rural women,113 in pharmacies,114 or in the elderly.115,116 Ten studies took place in the home.117–126

Several studies made use of the Internet to administer HRAs, provide feedback, or provide personalized recommendations to improve health outcomes (Figure 6).25,50,62,66,100,112

Figure 6 Method of health risk appraisal administration

Combination: Article where the HRA was administered in more than one of the settings shown in the figure.

Figure 6 is a bar graph depicting the method by which the health risk appraisals (HRA) were administered. The first bar represents one HRA administered in a laboratory. The second bar represents 4 HRAs administered in combination of settings. The third bar represents 6 unreported methods of administration. The forth bar represents 10 HRAs administered in the home. The fifth bar represents 18 HRAs administered in clinicians’ offices or clinics. The sixth bar represents 23 HRAs administered in the community; the last bar represents 56 HRAs administered in the workplace.

#### c What was the training of personnel who administered HRAs?

Training of personnel varied across the extracted articles. Authors reported personnel as trained staff,29,60,87,89–91,106 dieticians,65,70,83,92 health fitness specialists,20,37,64,73 graduate students trained in HRA,21,68,97 trained coaches or peers,58,59,62,107 project staff,45,110 nurses or physicians,9,13,22,28,32,34,40,42,43,48,49,51,71,77,93–95,107,114,117,121,122,124 psychiatrist,77 physical or occupational therapists,42,61,63 miscellaneous professionals,23,33,47,75,126 trained health educators,16,34,81,111 counselors,72,79,103,122 consultants,41 behavior change personnel,85 trained medical assistants,86 exercise physiologists,67 teachers,108 pharmacists,114 ‘wellness professionals,’44 community workers,104 and nonprofessional interviewers.105 Twelve articles used multiple combinations of these types of personnel.18,26,27,30,31,35,38,74,76,80,116,120 One article used a self-administered HRA.123

Thirty-eight articles did not report the type of training.7,8,10–12,14,17,19,24,25,36,37,39,46,50,54–57,66,69,78,82,84,88,96,98–102,109,112,113,115,118,119,125 (Figure 7).

Figure 7 Number of articles reporting training of personnel administering health risk appraisals

Figure 7 depicts in bar graph form whether or not training was reported for personnel administering the HRA. The first bar indicates that in 38 instances no training was reported. The second bar indicates that in 80 instances training was reported.

#### d What were the methods and frequencies of followup?

Methods of followup (Figure 8; Table 3) or feedback was provided in the form of personalized HRA results on paper printouts (n=97) or in writing (n=68), in person (n=80), via telephone (n=33) or e-mail (n=19), during group sessions (n=26), or via postal mail (n=52). Sometimes feedback was incorporated into the provision of exercise programs (n=15) or incentives to modify behavior (n=20). Two articles19,37 did not specify the form in which authors provided feedback. All other extracted articles utilized at least two forms of feedback provision, with the majority of articles (n=63) reporting four or five forms. One article employed eight forms of feedback provision.44

Figure 8 Methods of followup/feedback in health risk appraisals

Note: Specific articles will be counted in more than 1 column if they reported more than 1 type of followup method.

Figure 8 summarizes in bar graph the follow-up methods used in the studies. The first bar indicates that there 19 instances of e-mail follow-up. The second bar shows that there were 25 instances where follow-up was presented in group sessions. The third bar indicates that there were 33 instances of telephone follow-up. The fourth bar shows that there were 52 instances of follwo-up by mail. The fifth bar indicates that there were 68 instances of written follow-up. The sixth bar indicates that there wer 80 instances of in-person follow-up; the last bar shows 97 instances of paper printout follow-up.

Table 3 Methods and frequencies of followup

Author | Personalized results (on paper) | Written recommendations | Counseling (verbal report - meeting with an expert) | Telephone | Education - written materials | Incentives | Electronic on-line/email | Group feedback/education | Exercise programs | Mail | Number of contact methods | Frequency of contact | Percentage of drop-outs
Alexander112 2010 | 1 | 1 | | | 1 | | 1 | | | | 4 | 4 | 31
Angotti39 2000 | 1 | 1 | 1 | | | | | | 1 | 1 | 5 | 9 | 13
Aronow105 2005 | 1 | 1 | 1 | | | | | | | 1 | 4 | 3 | 0
Baer106 2001 | 1 | 1 | 1 | 1 | 1 | 1 | | | | 1 | 7 | 2 | 6
Bergstrom42 2008 | 1 | 1 | 1 | 1 | | | | 1 | | 1 | 6 | 9 | 27.1
Bertera15 1993 | 1 | 1 | 1 | | 1 | 1 | | | | | 5 | NR | NR
Blair28 1986 | 1 | 1 | | | 1 | | | 1 | 1 | | 5 | 1 | 4
Blair45 1986 | 1 | | | | | 1 | | | 1 | | 3 | NR | 24
Blalock102 2002 | 1 | 1 | 1 | 1 | 1 | | | | | | 5 | 3 | 23
Boudreau54 1995 | 1 | | 1 | | 1 | | | | | 1 | 4 | 2 | 19
Braeckman70 1999 | 1 | | 1 | | 1 | | | 1 | | 1 | 5 | 6 | 4
Brennan121 2010 | 1 | | 1 | 1 | 1 | | | | | 1 | 5 | 10 | 24
Breslow40 1990 | | | 1 | | 1 | 1 | | 1 | | | 4 | 2 | 6
Brug56 1996 | 1 | 1 | | | | | 1 | | | | 3 | 1 | 32
Campbell84 2002 | 1 | 1 | | 1 | 1 | | 1 | | | | 5 | 2 | 37
Campbell55 1994 | 1 | 1 | | | | | | 1 | | | 3 | 1 | 17
Chan21 1988 | 1 | | 1 | | 1 | | | | | | 3 | 1 | 1
Charlson85 2008 | 1 | 1 | 1 | 1 | 1 | | | | | | 5 | 10 | 10
Cockcroft69 1994 | 1 | 1 | 1 | | | | | | | 1 | 4 | 1 | 72
Connell57 1995 | 1 | 1 | 1 | 1 | | | | | | 1 | 5 | 1 | 59
Crouch68 1986 | 1 | 1 | 1 | | 1 | | | | | | 4 | 9 | 13
Dally110 2002 | 1 | 1 | | 1 | 1 | 1 | | | | 1 | 6 | 3 | 39
De Bourdeauhuij108 2010 | 1 | 1 | | | 1 | | 1 | | | | 4 | 1 | 37
De Bourdeauhuij66 2007 | 1 | | | | 1 | 1 | | | | | 3 | 2 | 53
Edelman107 2006 | 1 | 1 | 1 | 1 | 1 | | | | | | 5 | 22 | 25
Elliot58 2007 | 1 | 1 | 1 | 1 | 1 | | | | | 1 | 6 | 15 | 20
Elliot127 2004 | 1 | 1 | 1 | 1 | 1 | | | | | 1 | 6 | 14 | 0
Erfurt18 1991 | 1 | 1 | 1 | 1 | 1 | | | 1 | | 1 | 7 | 6 | 76
Faghri16 2008 | 1 | | 1 | | | | | | | | 2 | 1 | 0
Ferrer86 2009 | 1 | 1 | | 1 | 1 | | | | | | 4 | NR | 45
Fielding79 1995 | 1 | | 1 | | 1 | 1 | | | | 1 | 5 | 12 | 9
Fjeldsoe103 2010 | | 1 | 1 | | 1 | 1 | 1 | | | | 5 | 42 | 31
Fouad43 1997 | | | 1 | 1 | 1 | 1 | | 1 | 1 | 1 | 7 | 15 | 2
Fries123 1994 | 1 | 1 | | | 1 | | | | | 1 | 4 | 2 | 19
Fries7 1993 & Leigh11 1992 | 1 | 1 | 1 | | 1 | | | | | 1 | 5 | 4 | 31
Gagnon104 2010 | 1 | | | | | | 1 | | | | 2 | 4 | 33
Gallagher124 1996 | 1 | 1 | 1 | 1 | 1 | | | | | 1 | 6 | 2 | 0
Gemson71 1995 | 1 | 1 | 1 | | | | | | | 1 | 4 | 1 | 44
Godin96 1987 | 1 | 1 | | 1 | | | | | | | 3 | 2 | 35
Goetzel19 2002 | 1 | | 1 | | 1 | 1 | | 1 | | 1 | 6 | 2 | 0
Goetzel51 1994 | 1 | | 1 | | 1 | 1 | | 1 | 1 | | 6 | 1 to 6 | 0
Gold46 2000 | 1 | | 1 | 1 | 1 | | | | | 1 | 5 | 1 | 65
Gomel8,12 1993, 1997 | 1 | 1 | 1 | | 1 | 1 | | | | | 5 | 3 | NR
Haerens109 2009 | 1 | 1 | | | 1 | | | | | | 3 | 2 | 25
Hanlon72 1995 | 1 | 1 | | | 1 | | | | | 1 | 4 | 2 | 19
Harari87 2008 | 1 | 1 | | | 1 | | | | | 1 | 4 | 1 | 20
Hedberg41 1998 | 1 | 1 | 1 | 1 | 1 | | | 1 | | | 6 | 3 | 10
Heirich73 1993 | | | 1 | | | | | | 1 | | 2 | 1 | NR
Herman44 2006 | 1 | 1 | 1 | | 1 | 1 | 1 | 1 | 1 | | 8 | 2 | 80
Holt47 1995 | 1 | | | | 1 | 1 | | 1 | 1 | 1 | 6 | 52 | 69
Karlehagen30 2003 | 1 | 1 | 1 | | 1 | | | | | | 4 | 3 | 7
Kemper48 2002 | 1 | 1 | 1 | | 1 | | | | | | 4 | 8 | 35
Kim98 2010 | | | 1 | 1 | 1 | | | | | | 3 | 15 | 44
Korolewski29 1984 | 1 | | 1 | | 1 | | | 1 | | 1 | 5 | 1 | 0
Kreuter88 1996 | 1 | | 1 | 1 | | | | | | 1 | 4 | 2 | 14
Kroeze99 2008 | 1 | 1 | 1 | | | | 1 | | | 1 | 5 | 2 | 12
Lalonde114 2006 | 1 | 1 | 1 | 1 | 1 | | | | | 1 | 6 | 3 | 8
Lauritzen89 2008 | 1 | 1 | 1 | | 1 | | | | | 1 | 5 | 3 | 38
Lawler122 2010 | | | 1 | 1 | 1 | | | | | 1 | 4 | 24 | 2
Lingfors49 2008 | 1 | | | | 1 | | | 1 | | | 3 | 2 | 42
Lowensteyn93 1998 | 1 | | 1 | | | | | | | | 2 | 2 | 65
Maes26 1992 | 1 | 1 | 1 | | | | | | 1 | | 4 | 1 | 56
Makrides80 2008 | 1 | | 1 | | 1 | | | 1 | | | 4 | 2 | 30
Maron60 2008 | 1 | 1 | 1 | | 1 | | | | | | 4 | 23 | 39
Maruyama74 2010 | 1 | 1 | 1 | | 1 | | 1 | | | | 5 | 7 | 14
Mayer97 1994 | 1 | 1 | 1 | 1 | 1 | | | 1 | | | 6 | 4 | 14
McClure111 2009 | 1 | | 1 | | | 1 | | | | | 3 | 2 | 13
McKee32 2010 | | | 1 | 1 | | | | | | | 2 | 2 | 39
Meng115 2010 | | | 1 | | 1 | | | | | | 2 | 22 | 41
Mills50 2007 | 1 | 1 | 1 | | | | 1 | | | | 4 | 4 | 49
Moy17 2006 | 1 | | 1 | | 1 | | 1 | 1 | | | 5 | 4 | 19
Nice125 1990 | 1 | 1 | | | | | | | | 1 | 3 | 1 | 66
Nisbeth67 2000 | 1 | 1 | | | | | | | | | 2 | 2 | 13
Nitzke126 2007 | 1 | | 1 | | 1 | | | | | 1 | 4 | 2 | 39
Nurminen61 2002 | 1 | 1 | 1 | 1 | | | | | 1 | | 5 | 4 | 10
O’Loughlin36 1996 | 1 | | 1 | | 1 | | | | | | 3 | 1 | 33
Papadaki25 2008 | 1 | 1 | 1 | | 1 | | 1 | | | | 5 | 6 | 29
Pelletier81 1998 | 1 | | 1 | 1 | 1 | | | | | | 4 | 9 | NR
Pescatello37 2001 | | | | | | | | | | | 0 | 4 | 55
Peters75 1999 | 1 | 1 | 1 | | 1 | | | 1 | | 1 | 6 | 16 | 34
Prochaska62 2008 | 1 | 1 | 1 | 1 | | 1 | 1 | | | 1 | 7 | 3 | 47
Proper63 2003 | 1 | | 1 | | 1 | | | | | | 3 | 8 | 26
Puska38 1988 | 1 | 1 | | | | | | 1 | | | 3 | 4 | 14
Racette76 2009 | 1 | | 1 | | 1 | 1 | | 1 | 1 | | 6 | 2 | 19
Rahe77 2002 | 1 | | 1 | | 1 | | | 1 | | 1 | 5 | 4 | 0
Richter22 1987 | 1 | 1 | 1 | | 1 | | | | | | 4 | 2 | 9
Sabti31 2010 | | | 1 | | 1 | 1 | | | | 1 | 4 | 9 | 13
Selbst78 1992 | 1 | | 1 | | 1 | | | 1 | | 1 | 5 | 2 | NR
Shephard23 1982 | 1 | | | | | | | | 1 | 1 | 3 | 3 | 13
Shi33 1992 | | 1 | 1 | | 1 | | | | 1 | 1 | 5 | 6 | 31
Singleton34 1988 | 1 | | 1 | 1 | | 1 | | | | 1 | 5 | 3 | 67
Smeets101 2008 | 1 | 1 | | | 1 | | 1 | | 1 | | 5 | 1 | 6
Smith94 1985 | 1 | 1 | 1 | | 1 | | | | | 1 | 5 | 1 | 30
Sorensen64 2007 | 1 | 1 | | 1 | 1 | | | | | 1 | 5 | 7 | 14
Spittaels100 2007 | 1 | 1 | | | 1 | | 1 | | | | 4 | 2 | 34
Spoth90 1991 | 1 | 1 | 1 | | 1 | | | 1 | | 1 | 6 | 1 | 10
Steptoe90 1999 | 1 | | 1 | 1 | | | | | | | 3 | 2 | 41
Stevens82 2002 | 1 | 1 | 1 | 1 | 1 | | 1 | | | 1 | 7 | 5 | 8
Stoddard91 2004 | 1 | | 1 | | 1 | | | 1 | | | 4 | 1 | 23
Strychar65 1998 | 1 | 1 | 1 | | 1 | | | | | 1 | 5 | 2 | 12
Stuifbergen120 2010 | | | | 1 | 1 | | | 1 | | | 3 | 11 | 12
Taimela9,13 2008 | 1 | | 1 | 1 | | | | | | 1 | 4 | 1 | NR
Talvi35 1999 | 1 | | 1 | | 1 | | | | 1 | | 4 | 1 | 10
Toft83 2008 | 1 | | 1 | | 1 | | | 1 | | | 4 | 7 | 24
van Beurden27 1990 | 1 | 1 | 1 | | 1 | | | | | 1 | 5 | 3 | 78
Vandelanotte118 2005 | 1 | 1 | | | 1 | | 1 | | | 1 | 5 | 2 | 25
van t’Riet119 2009 | | 1 | | | | | 1 | | | | 2 | 3 | 32
van Stralen14 2009 & van Stralen10 2010 | 1 | 1 | | | | 1 | 1 | | | | 4 | 2 | 62
Von Huth92 2008 | 1 | 1 | 1 | | 1 | | | 1 | | 1 | 6 | 3 | 33
Walker113 2009 | 1 | 1 | | | | | | | | 1 | 3 | 4 | 4
Walker117 2010 | 1 | 1 | | | | | | | | 1 | 3 | 2 | 4
Wallace116 1998 | 1 | 1 | 1 | | 1 | 1 | | | 1 | | 6 | 3 | 10
Wilson24 1980 | 1 | | 1 | | 1 | 1 | | | | 1 | 5 | 2 | NR
Yen20 2001 | | | 1 | | 1 | 1 | | | | 1 | 4 | 2 | NR

Abbreviations: NR = not reported

Frequencies of followup (Figure 9; Table 3) varied across studies, although 72 percent involved between one and four followup contacts (counting the four companion sets of papers as one study per set). Twenty-two studies had one contact, 34 had two contacts, 15 had three contacts, and 11 had four contacts. The remaining 29 studies had between five82 and 52 contacts.47 Three studies did not report frequencies of followup.15,45,86

Figure 9 Frequencies of followup in health risk appraisals

Figure 9 is a bar graph that identifies the frequency of follow-up assessements in the articles. The first bar indicates that 1 assessment was completed in 22 studies. The second bar indicates that 2 assessments were completed in 34 of the studies. The third bar indicates that 3 assessments were completed in 15 of the studies. The fourth bar indicates that 4 assessments were completed in 11 articles. The fifth bar indicates that greater than 4 assessments were performed in 29 articles; the final bar indicates that the number of assessments was not reported in 3 of the studies.

Higher degrees of feedback and frequencies of followup might lead to greater participant engagement in HRA studies. This could lower dropout rates (Table 3). In the extracted articles, dropout rates ranged from zero percent16,19,29,51,77,105,124,127 to 80 percent.44 Nine articles9,12,15,20,24,73,78,79,81 and two companion papers8,13 omitted reports of dropout rates. We calculated dropout rates as the number of participants who completed a study (i.e., data available at the last follow-up timepoint) divided by the number of participants who began the study at baseline.

Pearson correlation coefficients between the number of methods of followup/feedback (e.g., telephone, in person) and percentage of dropouts (r=0.01, p=0.93) or frequency of followup and percentage of dropouts (r=0.07, p=0.46) were low and not statistically significant at the 5% level. Contrary to our assumption, the data fail to suggest possible linkages between tenacity of followup and dropout rates (Figures 10 and 11).

Figure 10 Correlation between number of methods of followup/feedback and percentage of dropouts

Figure 10 is a scatterplot showing the correlation between the number of methods of follow-up/feedback in the articles, which is on the x-axis, and the percentage of dropouts in the articles, which is on the y-axis. There is no discernable pattern in the plot to suggest a correlation.

Figure 11 Correlation between frequency of followup/number of contacts and percentage of dropouts

Figure 11 is a scatterplot showing the correlation between the frequency of follow-up/number of contacts in the articles, which is on the x-axis, and the percentage of dropouts in the articles, which is on the y-axis. There is no discernable pattern in the plot to suggest a correlation.

#### e What were the characteristics of the patient populations who received HRAs?

Most extracted articles included participants whose mean age ranged from 30 to 50 years; a majority of articles included samples composed of at least one-third women.

The mean age range in 67 articles was 30 to 50 years (Figure 12).8,9,12,13,16–19,25,30–32,34–38,41,42,44–50,54,56–65,67–70,74,76,77,79,80,83,84,86,88–90,93,94,96,98–105,111,112,118,119 Four articles21,108,109,125 contained a sample of persons completely under a mean age of 30 years. Fourteen articles involved persons with mean age between 50 and 64 years,10,14,27,71,82,85,91,95,110,113,114,120–122 and 7 articles included participants with a mean age over 65 years.7,11,87,97,115,116,124 One article reported an age range (i.e., 20 to 65 years),26 another article reported that 50 percent of the sample was greater than 40 years of age,15 a third article reported that 63 percent of the sample was less than 45 years of age,43 and a fourth article reported three mean ages—all 50 years or more—depending on whether participants were employed, retirees, or seniors.123 Mean ages were not reported in 22 articles.20,22–24,28,29,33,39,40,51,55,66,72,73,75,78,81,92,106,107,117,126

Figure 12 Mean age range in the extracted articles

Note: Figure excludes 1 article with a reported age range of 20–65 years, 1 article with a reported range > 40 years, 1 article with a reported range < 45 years, and one article with three different mean ages (1 mean age per study subgroup).

Figure 12 is a bar graph providing the mean age range (in years) under study by the number of articles. The first bar illustrates that 4 studies had a mean age range of less than 30 years. Bar two shows that 67 studies had a mean age range between 30 to 50 years. Bar three shows that 14 studies had a mean age range of 51 to 64; bar four identifies 7 studies with a mean age range of 65 or more; and bar five identifies that mean age range was not reported in 22 studies.

Thirty-one to 60 percent of participants were female in 41 articles,7,10,11,14,19,23,24,27,28,30,31,38,44,46–49,54,63,65,66,75,77,83,87,89,90,92,94,95,97,99,101,104–106,108,109,111,114,119 and 61 to 90 percent were female in 26 articles (Figure 13).16,34,36,37,45,57,60,62,69,78,81,84,86,88,98,100,107,110,112,115,116,118,121,122,124,126 Females comprised 30 percent or less of the samples in 26 articles8,9,12,13,15,17,18,33,35,41–43,56,58,64,67,68,70–72,74,79,85,93,96,125 and over 90 percent in 11 articles.22,25,55,61,82,91,102,103,113,117,120 Percentages of women were not reported in 14 articles.20,21,26,29,32,39,40,51,59,66,73,76,80,123

Figure 13 Percentage of women in the extracted articles

Figure 13 uses a bar graph to identify the percentage of women in the studies. The first bar indicates that in 26 articles women made up less than or equal to 30 percent of the population under study. The second bar indicates that in 41 articles women comprised 31 to 60 percent of the population under study. The third bar shows that in 26 articles women comprised 61 to 90 percent of the population under study. The forth bar indicates that in 11 studies, the percentage of women was greater than 90. The final bar identifies that in 14 articles the percentage of women was not reported.

Articles based in workplace settings tended to include samples of all workers (e.g., evaluations of wellness programs at American15 or Dutch26 companies) or subsamples of employees at increased risk for negative health outcomes (e.g., university employees with higher than average risks for CVD).60

Articles from community-based settings aimed at the general population recruited participants randomly from national sample frames (e.g., addresses supplied by a national telephone company)101 or more narrowly-focused recruitment vehicles such as company client lists,46 regional health councils,14 or research sites affiliated with the National Cancer Institute.112

Articles from community-based settings tended to focus on specific populations. For example, studies of university students recruited participants from persons living in dormitories, sororities, and fraternities,21,24 while one study of seniors recruited Medicare beneficiaries from primary care physicians’ practices.115

Eighteen31,32,34,35,49,83,84,86–89,91–95,104,112 articles recruited from physicians’ offices. Recruitment ranged from random selection of persons on general practitioners’ patient lists89 to targeting specific patient subgroups such as uninsured or underinsured women aged 50 years or over.91

### 2 What characteristics of HRAs (Question 1 a–e above) are associated with better health outcomes?

Many articles reported benefits for intervention groups in domains such as general health, lowered cholesterol, reductions in blood pressure, reduced fat intake, or improved physical activity (Table 4; Evidence Table, Appendix D). Overall, we were unable to find patterns in the evidence that would suggest whether certain characteristics of HRAs are associated with better health outcomes. Rather, positive benefits from HRAs tended to occur in all of these domains, regardless of types of HRAs, methods of administration, training of HRA staff, methods and frequency of followup, and sample characteristics.

Table 4 Outcomes in the extracted articles

Author | General Health | Smoking Cessation | Obesity / Weight | Physical Activity | Cardiovascular Health | Other
Alexander112 2010 | √^*^
Angotti39 2000 | √ | | √ | √ | | √^*^
Aronow105 2005 | √
Baer106 2001 | √ | | | | | √^*^
Bergstrom42 2008 | √ | √^*^ | | √
Bertera15 1993 | √ | | | | √ | √
Blair28 1986 | √ | | | √^*^
Blair45 1986 | √ | | √ | | √
Blalock102 2002 | | | | √ | | √
Boudreau54 1995 | | | | √ | √
Braeckman70 1999 | √ | | √^*^ | | | √
Breslow40 1990 | | √ | | √^*^
Brug56 1996 | √ | | | | | √
Campbell55 2002 | √^*^ | | | √
Campbell84 1994 | √ | | | | | √^*^
Chan21 1988 | √^*^ | √^*^
Cockcroft69 1994 | √ | | | | | √
Connell^57^1995 | √ | | | √ | | √
Crouch68 1986 | | | √ | | √
Dally110 2002 | √
De Bourdeauhuij66 2007 | √^*^
De Bourdeauhuij108 2010 | √ | | | √^*^
Edelman107 2006 | | | | √^*^ | √
Elliot58 2007 | √^*^ | | √^*^ | √
Elliot59 2004 | √^*^ | | √ | √ | √^*^
Erfurt^18^1991 | | √^*^ | √^*^ | | √
Faghri16 2008 | √ | | | √
Ferrer86 2009 | √ | √ | | √
Fielding79 1995 | | | √ | | √ | √
Fjeldsoe103 2010 | | | | √
Fouad43 1997 | | | | | √^*^
Gagnon104 2010 | | | | | | √
Gemson71 1995 | √ | | √ | √ | √ | √
Godin96 1987 | | | | √
Goetzel19 2002 | √ | √ | √ | √ | √ | √
Goetzel51 1994 | | √ | √ | | √
Gold46 2000 | √ | | | | | √
Gomel8,12 1993, 1997 | | √^*^ | √^*^ | | √^*^
Haerens109 2009 | | | | √
Hanlon72 1995 | | | | | √
Hedberg41 1998 | √ | √ | √ | √ | √
Heirich73 1993 | √ | √ | √^*^ | √^*^ | √
Herman44 2006 | | √ | √^*^ | √^*^
Holt47 1995 | √^*^
Karlehagen30 2003 | | | | | √^*^
Kemper48 2002 | | | | √
Kim98 2010 | √^*^ | | √ | √
Korolewski29 1984 | √
Kreuter88 1996 | √ | √
Kroeze99 2008 | √^*^ | | √
Lalonde114 2006 | | | | | √
Lauritzen89 2008 | | | | | √^*^
Lawler122 2010 | | | | √ | | √
Lingfors49 2009 | | √ | √ | √
Lowensteyn93 1998 | | | | | √
Maron60 2008 | | | | | √^*^
Maruyama74 2010 | | | | | | √
McClure111 2009 | | √^*^
McKee32 2010 | √ | | | | | √
Mills50 2007 | √^*^ | | | | | √^*^
Moy17 2006 | √ | √ | | √
Nice125 1990 | √ | √^*^ | | √^*^
Nisbeth67 2000 | | | | √ | √^*^
Nitzke126 2007 | √ | √ | | √ | | √
Nurminen61 2002 | √ | | | | | √
O’Loughlin^36^1996 | | √ | | √^*^ | √
Papadaki25 2008 | √^*^
Pelletier81 1998 | √ | | | | | √
Pescatello37 2001 | | | | | √^*^
Peters75 1999 | √ | √^*^ | √^*^ | √^*^
Prochaska62 2008 | √ | √ | | √
Proper63 2003 | √^*^ | | | √^*^
Puska38 1988 | √^*^ | √^*^
Racette76 2009 | | | √ | √ | √ | √
Rahe77 2002 | √ | | | | | √
Richter22 1987 | | | | √^*^
Sabti31 2010 | | | | √
Selbst78 1992 | √
Shephard23 1982 | √^*^
Shi33 1992 | √ | √ | √
Singleton34 1988 | √
Smeets101 2008 | | | | √^*^
Smith94 1985 | √ | √ | √ | √
Sorensen64 2008 | √^*^ | √^*^
Spittaels100 2007 | | | | √^*^
Spoth95 1992 | | | | | √^*^
Steptoe90 1999 | √ | √ | √ | √ | √
Stevens82 2002 | √^*^
Strychar65 1998 | | | | | √
Stuifbergen120 2101 | √^*^
Taimela9,13 2008 | √ | | | | | √
Talvi35 1999 | √ | √ | √ | √
Toft83 2008 | √^*^ | | | | √^*^
van Beurden27 1990 | | | | | √^*^
Vandelanotte118 2005 | | | | √^*^ | | √^*^
van ’t Riet119 2010 | | | | √
Von Huth92 2008 | | | | √ | √
Walker117 2010 | | | | √ | | √
Wilson24 1980 | √
Yen20 2001 | √^*^ | | | | | √
Medicare Population
Brennan121 2010 | | | | | √^*^
Charlson85 2008 | | | | | √
Fries123 1994 | √^*^
Fries7 1993 | √^*^ | √ | | √
Gallagher124 1996 | | | | | | √
Harari87 2008 | √^*^ | | | √^*^
Leigh11 1992 | √^*^ | √ | | √
Maes26 1992 | √
Makrides80 2008 | | | | | √^*^
Mayer97 1994 | √^*^ | | | √^*^
Meng115 2010 | √^*^ | | | | | √
Stoddard91 2004 | | | | √^*^ | √
van Stralen10 2010 | | | | √
van Stralen14 2009 | | | | √^*^
Walker113 2009 | √ | | | √^*^ | √
Wallace^116^1998 | √^*^ | √ | | √ | | √

√ represents outcome measure

* represents statistically significant between group results (p<0.05); may refer to more than one significant outcome. Refer to Appendix D: Evidence Table for more detail

Notwithstanding the items discussed in Question 1 a–e above, HRA programs involving elicitation of risk factors, individualized feedback, and recommendations appeared to provide participants with motivational boosts to alter their behaviors in a positive manner. We believe the process following HRA questionnaire administration, namely feedback and recommendations, provides participants with a sense of engagement that encourages behavioral change.

Some evidence exists to support the notion that the feedback and recommendation components of HRAs provide the impetus for change. We looked at 10 articles comparing HRA programs to no intervention (e.g., control groups who continued with usual practice and did not receive HRAs).9,26,57,72,73,89,96,115,124,167 HRA programs in these 10 articles varied, yet many included some form of counseling, either from health professionals or wellness experts.26,57,73,89,167 One article provided a voluntary hotline for participants to call and receive medical advice.9 Other articles included motivational videos and instructional booklets,124 feedback on improving physical fitness or ‘health age’,96 health promotion and home care vouchers,115 or health education and feedback.72

Some results indicated improvement for intervention groups: lower systolic blood pressure and BMI after one year,57 improved cholesterol and self-reported diet, as well as decreased alcohol intake, after five months,72 number of sick days remaining constant (higher for controls),9 lower cholesterol and BMI at five years,89 lower stress,26 less increase in disability over 22 months,115 and higher exercise levels, as well as weight and cardiovascular risk score reductions, over three years.73 Three articles reporting results after short followups (i.e., two,167 three,96 and six124 months) did not find statistically significant differences between intervention and control groups.

In these 10 articles, specific HRAs were too heterogeneous for us to determine whether one type of intervention was more efficacious than another.

For the overall strength of evidence for this key question, we considered the quality assessments of individual articles reported above and judged the overall risk of bias in the evidence for this question to be medium. Reporting issues in RCTs (e.g., no description of randomization processes) and lack of control for confounding in observational studies could introduce bias, although the heterogeneity of HRA programs and multiplicity of outcomes, rather than bias, prevented us from providing a firmer answer to this question.

We rated consistency high because most effect sizes were similar in terms of direction of effect. We assigned a medium score to directness because in the 37 cohort studies absence of randomization and lack of control for confounding in some, raises the potential for residual confounding of results. We rated precision high because half (n=60) of the 118 extracted articles had large sample sizes of 501 participants or more. Again, though, program and outcome heterogeneity had greater weight on our conclusions to this question, despite the medium to high overall strength of evidence.

### 3 What is the generalizability of the data in Questions 1 and 2 to the Medicare population or subpopulations?

We found 16 articles (15 studies – two papers pertained to one study)7,11 that included a segment of the Medicare population: senior citizens aged 65 years or over.7,10,11,14,26,80,85,87,91,97,113,115,116,121,124,157 In seven articles, the mean age or age range was at least 65 years.7,11,87,97,115,116,124 Another article included ‘seniors’ with a mean age of 64 years and ‘retirees’ with a mean age of 74 years;123 one article included 40 persons aged 65 years or over.10 The other seven articles included senior citizens, although this segment of the population was not the primary focus of the research. In these additional seven articles, mean age was 64 years (SD=8.6 years)14 or 63 years (SD=11.6 years in one group and 1.5 years in the other group);85 17 percent (246/1193)91 or 13 percent (29/225)113 of the samples were aged 65 years or over; the age range included persons between 20 and 65 years;26 mean age was 44 years with an upper age bound of 66 years;80 or mean age was 55 years (SD=11.5 years).121

Three other articles may have included senior citizens, although we did not include them in the answer to this key question because of incomplete data.55,82,84 Two of these articles enrolled persons aged 49 years or over84 or 50 years or over,55 but the authors did not report whether the upper age bounds in their samples included senior citizens. Another article reported an age range of 40 to 70 years, but the authors did not indicate how many persons in their sample were senior citizens.82

Females comprised 100 percent of the samples in two of the 16 articles,91,113 approximately 55 percent in six articles,7,10,11,14,87,97 67 percent in one article,121 71 percent in one article,115 73 percent in one article,116 80 percent in two articles,80,124 and 27 percent in one article.85 Two articles did not report the percentage.26,123

Participant recruitment was done at health councils,10,14 a hospital clinic,85 the workplace,26,80 group medical practices or health maintenance organizations,87,91,97,115 private insurance company databases,121 Medicare claims data for retired state civil servants,123 corporate retirement clubs,7,11 or advertisements116,124 (including one advertisement campaign in a seniors’ center),116 and through random digit dialing in a rural population.113

Interventions generally included HRAs, feedback, and recommendations versus HRAs alone. Control groups received HRA questionnaires without feedback or recommendations. One article compared individually tailored to generic newsletters113 and another compared two ‘economic’ methods of providing participants with cardiovascular risk feedback (net present value versus future value).85 Some articles involved face-to-face feedback or counseling.80,124

Results suggested some differences in health outcomes between intervention and control groups (Table 4). Many articles tested multiple outcomes and found statistically significant results for some outcomes and nonsignificant results for other outcomes. Intervention groups had increased physical activity (p<0.05)14,91 or improved timed chair stands (p<0.001).113 In one article, the intervention group had a higher resting metabolic rate, more minutes per week of stretching exercises, lower fat intake, and lower caffeine intake relative to the control group (p<0.05 for all comparisons).97 In another article, the intervention group demonstrated fewer increases in ADL dependency over 12 months compared to the control group (p=0.04).115 Reductions in salt and dietary fat intake were greater in the intervention group versus control group in the companion papers (p<0.05).7,11 Results for fruit and vegetable intake, daily caloric expenditure from saturated fat, systolic blood pressure, and body fat percentage were better in the intervention group in one article.113 Compared to controls, intervention groups showed lower systolic blood pressure (p=0.03),121 lower health risk score (p<0.01),123 lower CES-D scores and higher scores on six of eight SF-36 subscales,116 and some improvement (p<0.05) in cholesterol, cigarette smoking, BMI, stroke risk, and coronary risk.80 In many of these articles, some between-group differences were statistically significant and others were not (e.g., systolic blood pressure was different and diastolic blood pressure was not different between groups121).

Four articles reported no statistically significant differences between groups on any health outcomes.10,26,85,124

As expected, participant ages in the articles involving the senior population (with two exceptions)26,80 were greater than the 30 to 50 year age range in the remaining 99 articles. Also, participant recruitment in the 16 articles was focused on medical practices or specialized locales (i.e., retirement clubs) rather than the workplace or community. Types of interventions and results in the 16 articles generally mirrored the contents of the other 99 articles.

For the overall strength of evidence for this key question, we rated the risk of bias to be medium. We scored four of the RCTs11,14,91,115 and a companion paper7 as poor quality using the Jadad scale, although the non-applicability of the adverse effects question in the Jadad scale (see ‘quality assessment’ in Chapter 4) could have biased the ratings downward. The remaining articles10,26,80,85,87,97,113,116,121,123,124 were fair quality.

We scored overall consistency of evidence medium because results were equivocal in terms of differential effects between intervention and comparison groups (Table 4).

Directness was ranked high since 15 of the 16 articles were RCTs or a companion to an RCT and the mechanism of randomization is likely to eliminate most or all confounding, thus promoting a direct link between interventions and outcomes.

Seven articles7,11,14,87,91,97,123 had sample sizes greater than 1,000 persons, so precision was rated high.