# Methods

## Literature Search Strategy

A literature search was conducted to capture relevant, published studies on the topic of interest. Medline^®^, Embase^®^, Cochrane Central^®^, PsycINFO^®^, and Social Science Abstracts^®^ were searched, from each database’s inception date to June 2010. Search terms included a combination of subject headings and text words for Health Risk Appraisals (HRA), e.g., ‘health risk appraisal,’ ‘health risk assessment,’ and ‘health hazard assessment.’ Search terms were combined with text words denoting individualized or personalized feedback, e.g., ‘feedback,’ ‘counsel,’ ‘individual,’ ‘personal,’ ‘tailor.’ Appendix A contains a detailed description of the literature search strategies. To supplement the database search, we hand searched The American Journal of Health Promotion for the same time period.

Inclusion/exclusion criteria. We included human studies published in the English language, provided they were randomized controlled trials (RCTs) or observational studies with comparison groups (e.g., cohort, case control). We excluded case reports, case series, narrative and systematic reviews, editorials, comments, letters, opinion pieces, abstracts, and conference proceedings.

The primary focus of included studies had to be HRAs for single disease entities such as cardiovascular disease (CVD), multiple disease entities, or general health. Our definition of an HRA contained three components: participants provided self-reported information to identify individual risk factors for disease; participants received individualized health-related feedback based on the information they provided; and the information was used to give participants at least one recommendation or intervention to promote health, sustain function, or prevent disease.1 Any HRA, regardless of its delivery mechanism (e.g., single or multiple questionnaire administration, use of written feedback material, counseling, resource referral), that fulfilled these three criteria was included in the review. We excluded studies reporting HRAs without all three components.

We also excluded studies without health outcomes. Health outcomes encompassed items such as self-reported risk factors (including food consumption) or diagnoses, clinical measures (e.g., blood pressure), or physical measures (e.g., weight, performance on a test such as grip strength). Examples of non-health outcomes were cost comparisons between HRA programs, measures of satisfaction with HRAs (e.g., appearance of questionnaires, depth of feedback), or reported proportions of persons who returned HRA questionnaires.

## Article Selection and Reporting

A team of trained raters applied the inclusion and exclusion criteria to the citations that were retrieved in the literature search. Rater guidelines and standardized forms were developed to govern the screening process. The forms were created and stored online using Distiller SR software (Evidence Partners Incorporated, Ottawa, Ontario, Canada). See Appendix B.

The screening process was divided into three levels. For the first two levels, two independent raters evaluated the titles and abstracts of citations that were obtained from the literature search. Citations satisfying the inclusion criteria were advanced to the next level. Citations also advanced if there was insufficient information to determine whether the inclusion criteria were satisfied.

We attempted to retrieve complete, published manuscripts for all citations that passed title and abstract screening. Once retrieved, complete manuscripts were screened to determine if the inclusion criteria were met.

At every stage of screening, agreement was required from both raters for an article to be promoted to the next level. Discrepancies were resolved by consensus. If consensus could not be reached, then a neutral third party reviewed the article in question and made a final decision.

Studies that passed full text screening proceeded to full data extraction. The authors of this report reviewed the extracted data to confirm the accuracy of the work.

### Quality Assessment of Included Studies

Following data extraction, two raters independently assessed article quality using the modified Jadad scale for RCTs and the Newcastle-Ottawa Scale (NOS) for cohort and case control studies. We selected these scales because of their widespread use in systematic reviews of RCTs and observational studies. Although several quality scales exist, no one instrument is a gold standard, nor is any one instrument more appropriate than another for assessing the quality of HRA articles. The Jadad and NOS scales provide a rapid and efficient means of assessing article quality and have been used in previous technology assessments for the Centers for Medicare and Medicaid Services (CMS).142 These scales are shown in Appendix B. The items in these scales are consistent with the Task Force on Community Preventive Services guideline for collecting data in systematic reviews.5

The modified Jadad scale2,3 contains six questions covering the following domains: randomization, double blinding, tracking of withdrawals and adverse effects, use of statistics, and inclusion and exclusion criteria. One point is awarded for each ‘yes’ response; zero points for ‘no’ responses. Additional points may be added or deducted if the randomization scheme and blinding are appropriate or inappropriate. The maximum score is eight points.

The NOS consists of two subscales, one for cohort and the other for case control studies.4 Both subscales measure the same three broad domains: selection of study groups, comparability of study groups, and means of ascertaining exposure or outcome. The NOS contains a ‘star system’ to score studies (maximum score is nine stars). Studies are rated using checklists; stars are awarded for responses that signify the highest possible quality on each checklist item.

We modified three NOS questions to reflect the characteristics of cohort studies in the HRA domain. ‘Exposed’ subjects in these studies were persons who received an intervention; ‘unexposed’ subjects formed control groups. Consequently, we modified the ‘ascertainment of exposure’ question so that a star could be awarded if authors described how participants were assigned to intervention and control groups. For the question on confounding, we added a third response option, i.e., ‘no matching or control of confounding described in article’ (no star). We modified the first response option for the ‘assessment of outcome’ question to include physical or clinical assessments, or assessments done with structured interview questionnaires.

The overall quality of each extracted article with a comparison group was rated ‘good,’ ‘fair,’ or ‘poor’ in accordance with the recommendations outlined in the Agency for Healthcare Research and Quality (AHRQ) methods guide for systematic reviews.6 Jadad scale scores less than four indicated poor quality, four to six fair quality, and over six good quality. NOS scores less than four indicated poor quality, four to six fair quality, and over six good quality.

We graded the overall strength of evidence for Key Questions 2 and 3 using the recommendations of the AHRQ methods guide.6 These recommendations require evidence to be assessed in four domains: risk of bias, consistency, directness, and precision. For each domain, the strength of evidence is rated as high, moderate, low, or insufficient:

■ High: High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect;
■ Moderate: Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate;
■ Low: Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of effect and is likely to change the estimate; or
■ Insufficient: Evidence is either unavailable or does not permit estimation of an effect.

We did not assess the overall strength of evidence for Key Question 1a to e because the five sub questions required us to enumerate study characteristics rather than address evidence treatment effects.

### Answering the Key Questions

The research team used a qualitative, descriptive approach to answer the key questions. This approach included summarizing the extracted data in tables and using these summaries to address the key questions. The research team did not believe a meta analysis was feasible because the included studies contained a substantial degree of clinical and methodological heterogeneity.