# Appendixes

APPENDIX A Search Terms

APPENDIX B Screening Forms

APPENDIX C Excluded Studies

APPENDIX D Evidence Tables