# Evidence Tables

Evidence Table 1 Objective of health risk appraisals

Evidence Table 2 Health risk appraisal instruments used in the extracted studies