# Excluded Studies

Major study ties modifiable risk factors to health costs. Healthcare Demand & Disease Management. 1999;5(2):22-5. OVID-Medline. Exclude: No comparison group. [pmid: 10346539].
Web-based ‘early warning’ predictive modeling system enhances preventive care. Disease Management Advisor. 2000;6(12):192-5. OVID-Medline. Exclude: No comparison group. [pmid: 11195598].
Abildso CG, Zizzi SJ, Reger-Nash B. Evaluating an insurance-sponsored weight management program with the RE-AIM Model, West Virginia, 2004–2008. Preventing Chronic Disease. 2010;7(3):A46 U. PDATE_OVID_EMBASE. [pmid: 20394685].
Acquista VW, Wachtel TJ, Gomes CI, et al. Home-based Health Risk Appraisal and screening program. J Community Health. 1988;13(1):43-52. OVID-Medline. Exclude: No comparison group. [pmid: 3360980].
Aldana SG, Jacobson BH, Harris CJ, et al. Influence of a mobile worksite health promotion program on health care costs. Am J Prev Med. 2000;9(6):378-83. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 8311988].
Aldana SG, Merrill RM, Price K, et al. Financial impact of a comprehensive multisite workplace health promotion program. Prev Med. 2005;40(2):131-7. OVID-Medline. Exclude: Self reported information not provided to participants. [pmid: 15533521].
Alderman MH, Melcher LA. Occupationally-sponsored, community-provided hypertension control. J Occup Med. 1983;25(6):465-70. OVID-Embase. Exclude: Individualized recommendation not provided. [pmid: 6886849].
Allenspach EC, Handschin M, Joss MK, et al. Patient and physician acceptance of a campaign approach to promoting physical activity: The "Move for Health" project. Swiss Medical Weekly. 2007;137(19–20):292-9. OVID-Embase. Exclude: Does not report health outcomes. [pmid: 17594542].
Anderson DM, Hampton MB, Blokhuis JA, et al. The number of times attended as a factor in the success of a comprehensive hospital-based approach to health promotion. J Hosp Mark. 1998;12(2):85-93. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 10186253].
Anderson DR, Whitmer RW, Goetzel RZ, et al. The relationship between modifiable health risks and group-level health care expenditures. Health Enhancement Research Organization (HERO) Research Committee. [Erratum appears in Am J Health Promot 2001 Jan–Feb;15(3):191]. Am J Health Promot. 2000;15(1):45-52. OVID-Medline. Exclude: No feedback provided to participants. [pmid: 11184118].
Anderson ES, Winett RA, Wojcik JR, et al. A computerized social cognitive intervention for nutrition behavior: Direct and mediated effects on fat, fiber, fruits and vegetables, self-efficacy and outcome expectations among food shoppers. Ann Behav Med. 2001;23(2):88-100. OVID-PsycINFO. Exclude: Self reported information not provided to participants. [pmid: 11394559].
Anderson RC, Anderson KE. Worksite health promotion. The benefits of providing personal health status feedback and education programs to employees. AAOHN J. 1991;39(2):57-61. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 1993085].
Anderson RC, Anderson KE. Positive changes and worksite health education. Psychol Rep. 1994;74(2):607-10. OVID-PsycINFO. Exclude: Individualized recommendation not provided. [pmid: 8197297].
Aoun S, Donovan RJ, Johnson L, et al. Preventive care in the context of men’s health. Journal of Health Psychology. 2002;7(3):243-52. OVID-Embase. Exclude: Individualized recommendation not provided. [pmid: 22114248].
Arbeit ML, Johnson CC, Mott DS, et al. The Heart Smart cardiovascular school health promotion: Behavior correlates of risk factor change. Prev Med. 1992;21(1):18-32. OVID-Embase. Exclude: No feedback provided to participants. [pmid: 1738766].
Baer JT. Improved plasma cholesterol levels in men after a nutrition education program at the worksite. J Am Diet Assoc. 1993;93(6):658-63. OVID-Medline. Exclude: No feedback provided to participants. [pmid: 8389779].
Baier CA, Grodzin CJ, Port JD, et al. Coronary risk factor behavior change in hospital personnel following a screening program. Am J Prev Med. 1992;8(2):115-22. OVID-Medline. Exclude: No comparison group. [pmid: 1599719].
Baker EA, Israel BA, Schurman SJ. A participatory approach to worksite health promotion. J Ambulatory Care Manage. 1994;17(2):68-81. OVID-Medline. Exclude: Individualized recommendation not provided. [pmid: 10133290].
Balasubramanian BA, Cohen DJ, Clark EC, et al. Practice-level approaches for behavioral counseling and patient health behaviors. Am J Prev Med. 2008;35(5:Suppl):Suppl-13. OVID-Medline. Exclude: Self reported information not provided to participants. [pmid: 18929988].
Baldwin R. Evaluation of a nurse-led psychogeriatric liaison service. The Research Findings Register. 2003. OVID-EBM-cctr.
Baquero B, Ayala GX, Arredondo EM, et al. Secretos de la Buena Vida: Processes of dietary change via a tailored nutrition communication intervention for Latinas. Health Educ Res. 2009;24(5):855-66. OVID-Embase. Exclude: Does not report health outcomes. [pmid: 19339374].
Bartlett EE, Pegues HU, Shaffer CR, et al. Health hazard appraisal in a family practice center: an exploratory study. J Community Health. 1983;9(2):135-44. OVID-Medline. Exclude: No comparison group. [pmid: 6678263].
Baruth M, Wilcox S, Dunn AL, et al. Psychosocial mediators of physical activity and fitness changes in the activity counseling trial. Ann Behav Med. 2010;39(3):274-89. UPDATE_OVID_PsycINFO. Exclude: Does not report health outcomes. [pmid: 20431975].
Basen-Engquist K, Hudmon KS, Tripp M, et al. Worksite health and safety climate: scale development and effects of a health promotion intervention. Prev Med. 1998;27(1):111-9. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 9465361].
Beery WL, Greenwald HP. A modified health risk appraisal as a component of a senior health promotion program. HMO Pract. 1996;10(2):91-4. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 10158546].
Belcher DW. Implementing preventing services. Success and failure in an outpatient trial. Arch Intern Med. 1990;150(12):2533-1. OVID-Embase. Exclude: Does not report health outcomes. [pmid: 2244769].
Beresford SA, Shannon J, McLerran D, et al. Seattle 5-a-Day Work-Site Project: process evaluation. Health Education & Behavior. 2000;27(2):213-22. OVID-Medline. Exclude: No feedback provided to participants. [pmid: 10768802].
Beresford SA, Thompson B, Feng Z, et al. Seattle 5 a Day worksite program to increase fruit and vegetable consumption. Prev Med. 2001;32(3):230-8. OVID-Medline. Exclude: No feedback provided to participants. [pmid: 11277680].
Bertera RL. Planning and implementing health promotion in the workplace: a case study of the Du Pont Company experience. Health Educ Q. 1990;17(3):307-27. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 2228633].
Bertera RL. The effects of workplace health promotion on absenteeism and employment costs in a large industrial population. Am J Public Health. 1990;80(9):1101-5. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 2382748].
Billings DW, Cook RF, Hendrickson A, et al. A web-based approach to managing stress and mood disorders in the workforce. J Occup Environ Med. 2008;50(8):960-8. OVID-PsycINFO. Exclude: Self reported information not provided to participants. [pmid: 18695455].
Blackburn J, Brumby S, Willder S, et al. Intervening to improve health indicators among Australian farm families. Journal of Agromedicine. 2009;14(3):345-56. OVID-Embase. Exclude: Individualized recommendation not provided. [pmid: 19657884].
Blaedel A, Hansen CH, Nielsen K. Health promotion project: "Health check" for the hotel and catering branch. Homeost Health Dis. 2005;43(3):164-8. OVID-Embase. Exclude: Does not report health outcomes.
Block G, Block T, Wakimoto P, et al. Demonstration of an E-mailed worksite nutrition intervention program. Preventing Chronic Disease. 2004;1(4):A06. OVID-Medline. Exclude: No comparison group. [pmid: 15670437].
Block P, Vanner EA, Keys CB, et al. Project Shake-It-Up: using health promotion, capacity building and a disability studies framework to increase self efficacy. Disabil Rehabil. 2010;32(9):741-54. UPDATE_OVID_EMBASE. Exclude: No feedback provided to participants. [pmid: 20302442].
Bly JL, Jones RC, Richardson JE. Impact of worksite health promotion on health care costs and utilization. Evaluation of Johnson & Johnson’s Live for Life program. JAMA. 1986;256(23):3235-40. OVID-Medline. Exclude: No feedback provided to participants. [pmid: 3783867].
Bock BC, Marcus BH, Pinto BM, et al. Maintenance of physical activity following an individualized motivationally tailored interention. Ann Behav Med. 2001;23(2):79-87. OVID-PsycINFO. Exclude: No feedback provided to participants. [pmid: 11394558].
Bopp M, Wilcox S, Laken M, et al. 8 Steps to Fitness: A faith-based, behavior change physical activity intervention for African Americans. Journal of physical activity & health. 2009;6(5):568-77. OVID-PsycINFO. Exclude: Self reported information not provided to participants. [pmid: 19953833].
Bovet P, Perret F, Cornuz J, et al. Improved smoking cessation in smokers given ultrasound photographs of their own atherosclerotic plaques. Prev Med. 2002;34(2):215-20. OVID-PsycINFO. Exclude: Self reported information not provided to participants. [pmid: 11817917].
Boyle TC, Coffey J, Palmer T. Men’s health initiative risk assessment study: effect of community pharmacy-based screening. Journal of the American Pharmacists Association: JAPhA. 2004;44(5):569-77. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 15496042].
Bracken AC, Hersh AL, Johnson DJ. A computerized school-based health assessment with rapid feedback to improve adolescent health. Clin Pediatr (Phila). 1998;37(11):677-83. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 9825212].
Brenner B. Implementing a community intervention program for health promotion. Soc Work Health Care. 2002;35(1–2):359-75. OVID-Embase. Exclude: Does not report health outcomes. [pmid: 12365749].
Breslow L, Beck JC, Morgenstern H, et al. Development of a health risk appraisal for the elderly (HRA-E). Am J Health Promot. 1997;11(5):337-43. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 10167368].
Briley ME, Montgomery DH, Blewett J. Worksite nutrition education can lower total cholesterol levels and promote weight loss among police department employees. J Am Diet Assoc. 1992;92(11):1382-4. OVID-Medline. Exclude: Individualized recommendation not provided. [pmid: 1430725].
Brodey BB, Cuffel B, McCulloch J, et al. The acceptability and effectiveness of patient-reported assessments and feedback in a managed behavioral healthcare setting. The American journal of managed care. 2005;11(12):774-80. OVID-EBM-cctr. Exclude: No feedback provided to participants. [pmid: 16336061].
Browne G, Byrne C, Roberts J, et al. When the bough breaks: provider-initiated comprehensive care is more effective and less expensive for sole-support parents on social assistance. Social Science & Medicine. 2001;53(12):1697-710. OVID-Medline. Exclude: Self reported information not provided to participants. [pmid: 11762894].
Brownson RC, Smith CA, Pratt M. Preventing cardiovascular disease through community-based risk reduction: the Bootheel Heart Health Project. Am J Public Health. 1996;86(2):206-13. CSA-SocialScienceAbstracts. Exclude: No feedback provided to participants. [pmid: 8633737].
Brumby SA, Willder SJ, Martin J. The sustainable farm families project: changing attitudes to health. Rural & Remote Health. 2009;9(1):1012. Mar. OVID-Medline. Exclude: No comparison group. [pmid: 19292570].
Brumley DW. FitBlue: A multidimensional weight management initiative. Disease Management. 2007;10(SUPPL 1):S18-S22. OVID-Embase. Exclude: Individualized recommendation not provided.
Bula CJ, Alessi CA, Aronow HU, et al. Community physicians’ cooperation with a program of in-home comprehensive geriatric assessment. J Am Geriatr Soc. 1993;43(9):1016-20. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 7657917].
Bulc M, Svab I, Yaphe J. The countrywide integrated non-communicable disease intervention programme (CINDI) and the effects of healthcare system reform in Slovenia. European Journal of General Practice. 2001;7(4):154-60. OVID-Embase. Exclude: Individualized recommendation not provided.
Bull FC, Kreuter MW, Scharff DP. Effects of tailored, personalized and general health messages on physical activity. Patient Educ Couns. 1999;36(2):181-92. OVID-Embase. Exclude: Does not report health outcomes. [pmid: 10223022].
Burke V, Giangiulio N, Gillam HF, et al. Health promotion in couples adapting to a shared lifestyle. Health Educ Res. 1999;14(2):269-88. OVID-Embase. Exclude: Self reported information not provided to participants. [pmid: 10387506].
Burton NW, Pakenham KI, Brown WJ. Feasibility and effectiveness of psychosocial resilience training: a pilot study of the READY program. Psychology, Health & Medicine. 2010;15(3):266-77. UPDATE_OVID_EMBASE. Exclude: No feedback provided to participants.
Burton WN, Conti DJ. Disability management: corporate medical department management of employee health and productivity. Journal of Occupational & Environmental Medicine. 2000;42(10):1006-12. OVID-Medline. Exclude: No feedback provided to participants. [pmid: 11039164].
Burton WN, Chen CY, Conti DJ, et al. The association between health risk change and presenteeism change. Journal of Occupational & Environmental Medicine. 2006;48(3):252-63. OVID-Medline. Exclude: No comparison group. [pmid: 16531829].
Cadzow RB, Servoss TJ. The association between perceived social support and health among patients at a free urban clinic. J Natl Med Assoc. 2009;101(3):243-50. OVID-Medline. Exclude: No feedback provided to participants. [pmid: 19331256].
Cakir H, Pinar R. Randomized Controlled Trial on Lifestyle Modification in Hypertensive Patients. West J Nurs Res. 2006;28(2):190-209. OVID-PsycINFO. Exclude: Self reported information not provided to participants. [pmid: 16513919].
Calderon KS, Smallwood C, Tipton DA. Kennedy Space Center Cardiovascular Disease Risk Reduction Program evaluation. Vascular Health & Risk Management. 2008;4(2):421-6. OVID-Medline. Exclude: No comparison group. [pmid: 18561517].
Calfas KJ, Long BJ, Sallis JF, et al. A controlled trial of physician counseling to promote the adoption of physical activity. Prev Med. 1996;25(3):225-33. OVID-PsycINFO. Exclude: No feedback provided to participants. [pmid: 8780999].
Calfas KJ, Sallis JF, Oldenburg B, et al. Mediators of change in physical activity following an intervention in primary care: PACE. Prev Med. 1997;26(3):297-304. OVID-PsycINFO. Exclude: Self reported information not provided to participants. [pmid: 9144753].
Camann MA. To your health: implementation of a wellness program for treatment staff and persons with mental illness. Arch Psychiatr Nurs. 2001;15(4):182-7. OVID-Medline. Exclude: No comparison group. [pmid: 11498811].
Cantor JC, Morisky DE, Green LW. Cost-effectiveness of educational interventions to improve patient outcomes in blood pressure control. Prev Med. 1985;14(6):782-800. OVID-Embase. Exclude: Self reported information not provided to participants. [pmid: 3937154].
Carleton RA, Lasater TM, Assaf AR, et al. The Pawtucket Heart Health Program: Community changes in cardiovascular risk factors and projected disease risk. Am J Public Health. 1995;85(6):777-85. OVID-Embase. Exclude: Self reported information not provided to participants. [pmid: 7762709].
Castro CM, Wilcox S, O’Sullivan P, et al. An exercise program for women who are caring for relatives with dementia. Psychosom Med. 2002;64(3):458-68. OVID-PsycINFO. Exclude: Self reported information not provided to participants. [pmid: 12021419].
Chambers LW, Kaczorowski J, Dolovich L, et al. A community-based program for cardiovascular health awareness. Canadian Journal of Public Health. 2005;96(4):294-8. OVID-Embase. Exclude: Does not report health outcomes. [pmid: 16625801].
Chen JL, Weiss S, Heyman MB, et al. Pilot study of an individually tailored educational program by mail to promote healthy weight in Chinese American children. Journal for Specialists in Pediatric Nursing. 2008;13(3):212-22. OVID-PsycINFO. Exclude: No comparison group. [pmid: 18638051].
Chen MY. The effectiveness of health promotion counseling to family caregivers. Public Health Nurs. 1999;16(2):125-32. OVID-PsycINFO. Exclude: Self reported information not provided to participants. [pmid: 10319663].
Christenson GM, Kiefhaber A. The National Survey of Worksite Health Promotion Activities. AAOHN J. 1998;36(6):262-5. OVID-Embase. Exclude: Does not report health outcomes. [pmid: 3370087].
Chung M, Melnyk P, Blue D, et al. Worksite health promotion: the value of the Tune Up Your Heart program. Population Health Management. 2009;12(6):297-304. OVID-Medline. Exclude: No comparison group. [pmid: 20038255].
Ciardullo AV, Daghio MM, Severi S, et al. Improving the cardio-respiratory fitness in older people and cardiac patients: findings from an Italian participatory research. Monaldi Arch Chest Dis. 2003;60(2):107-10. OVID-Medline. Exclude: No comparison group. [pmid: 12918160].
Clark PG, Nigg CR, Greene G, et al. The Study of Exercise and Nutrition in Older Rhode Islanders (SENIOR): Translating theory into research. Health Educ Res. 2000;17(5):552-61. OVID-Embase. Exclude: Does not report health outcomes. [pmid: 12408200].
Clifford PA, Tan SY, Gorsuch RL. Efficacy of a self-directed behavioral health change program: weight, body composition, cardiovascular fitness, blood pressure, health risk, and psychosocial mediating variables. J Behav Med. 1991;14(3):303-23. OVID-Medline. Exclude: Self reported information not provided to participants. [pmid: 1875406].
Cohen GD, Perlstein S, Chapline J, et al. The Impact of Professionally Conducted Cultural Programs on the Physical Health, Mental Health, and Social Functioning of Older Adults. The Gerontologist. 2006;46(6):726-34. OVID-PsycINFO. Exclude: Self reported information not provided to participants. [pmid: 17169928].
Cole RE, Horacek T. Effectiveness of the "My Body Knows When" intuitive-eating pilot program. American Journal of Health Behavior. 2010;34(3):286-97. OVID-Embase. Exclude: No feedback provided to participants. [pmid: 20001186].
Cornfeld MJ, Schnoll RA, Tofani SH, et al. Implementation of a comprehensive cancer control program at the worksite: year one summary report. Journal of Occupational & Environmental Medicine. 2002;44(5):398-406. OVID-Medline. Exclude: No comparison group. [pmid: 12024685].
Coulter ID, Hurwitz EL, Aronow HU, et al. Chiropractic patients in a comprehensive home-based geriatric assessment, follow-up and health promotion program. Topics in Clinical Chiropractic. 1996;3(2):46-55. OVID-EBM-cctr. Exclude: No feedback provided to participants.
Cousins M, McDowell I, Lynch W. Use of medical care after a community-based health promotion program: A quasi-experimental study. Am J Health Promot. 1995;10(1):47-54. OVID-Embase. Exclude: Does not report health outcomes. [pmid: 10155658].
Cowdery JE, Suggs LS, Parker S. Application of a Web-based tailored health risk assessment in a work-site population. Health Promotion Practice. 2007;8(1):88-95. OVID-Medline. Exclude: No comparison group. [pmid: 16980572].
Craig A, Hancock K. The influence of a healthy lifestyle program in a work environment: A controlled long-term study. Journal of Occupational Health and Safety - Australia and New Zealand. 1996;12(2):193-206. OVID-Embase. Exclude: No feedback provided to participants.
Croteau KA. A preliminary study on the impact of a pedometer-based intervention on daily steps. Am J Health Promot. 2004;18(3):217-20. Hand search. Exclude: Self reported information not provided to participants. [pmid: 14748310].
Crump CE, Shegog R, Gottlieb NH, et al. Comparison of participation in federal worksite and community health promotion programs. Am J Health Promot. 2001;15(4):232-6. OVID-Medline. Exclude: No feedback provided to participants. [pmid: 11349343].
Cummings GE, Francescutti LH, Predy G, et al. Health promotion and disease prevention in the emergency department: A feasibility study. Canadian Journal of Emergency Medicine. 2006;8(2):100-5. OVID-Embase. Exclude: Individualized recommendation not provided. [pmid: 17175870].
Cupples ME, McKnight A. Randomised controlled trial of health promotion in general practice for patients at high cardiovascular risk. Br Med J. 1994;309(6960):993-6. OVID-Embase. Exclude: No feedback provided to participants. [pmid: 7950723].
Curtin B. Health hazard appraisal: a tool for health maintenance. J Ambulatory Care Manage. 1981;4(1):65-72. OVID-Medline. Exclude: No comparison group. [pmid: 10250225].
Dalton BA, Harris JS. A comprehensive approach to corporate health management. J Occup Med. 1991;33(3):338-47. OVID-Medline. Exclude: No feedback provided to participants. [pmid: 1903156].
Davis KE, Jackson KL, Kronenfeld JJ, et al. Determinants of participation in worksite health promotion activities. Health Educ Q. 1987;14(2):195-205. OVID-Medline. Exclude: No feedback provided to participants. [pmid: 3597109].
Davis L, Loyo K, Glowka A, et al. A comprehensive worksite wellness program in Austin, Texas: partnership between Steps to a Healthier Austin and Capital Metropolitan Transportation Authority. Preventing Chronic Disease. 2009;6(2):A60. OVID-Medline. Exclude: No comparison group. [pmid: 19289003].
De Cocker KA, De Bourdeaudhuij IM, Cardon GM. The effect of a multi-strategy workplace physical activity intervention promoting pedometer use and step count increase. Health Educ Res. 2010;25(4):608-19. UPDATE_OVID_PsycINFO. Exclude: No feedback provided to participants. [pmid: 19751999].
DeBar LL, Dickerson J, Clarke G, et al. Using a website to build community and enhance outcomes in a group, multi-component intervention promoting health diet and exercise in adolescents. J Pediatr Psychol. 2009;34(5):539-50. OVID-PsycINFO. Exclude: Self reported information not provided to participants. [pmid: 19091807].
DeFriese GH. Assessing the use of health risk appraisals. Business & Health. 1987;4(6):38-42. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 10281229].
DeGraw C. A community-based school health system: parameters for developing a comprehensive student health promotion program. J Sch Health. 1994;64(5):192-5. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 8078313].
del Pilar Rocha-Goldberg M, Corsino L, Batch B, et al. Hypertension Improvement Project (HIP) Latino: Results of a pilot study of lifestyle intervention for lowering blood pressure in Latino adults. Ethnicity & Health. 2010;15(3):269-82. UPDATE_OVID_PsycINFO. [pmid: 20379894].
Delichatsios HK, Hunt MK, Lobb R, et al. EatSmart: Efficacy of a multifaceted preventive nutrition intervention in clinical practice. Prev Med. 2001;33(2,Pt.1of2):91-8. OVID-PsycINFO. Exclude: Does not report health outcomes. [pmid: 11493041].
Denelsbeck S. Engaging employees in health and wellness: The Healthy Pfizer program. Am J Manag Care. 2006;12:SP40-SP43. OVID-Embase. Exclude: Does not report health outcomes. [pmid: 17173491].
Desharnais R, Godin G, Jobin J. Motivational characteristics of Evalu* Life and the Canadian Home Fitness Test. Canadian Journal of Public Health. 1987;78(3):161-4. OVID-Embase. Exclude: Does not report health outcomes. [pmid: 3607691].
Dettloff RW, Morse JA. Demonstration of community pharmacy and managed care organization collaboration on cardiovascular disease risk factor identification using health risk appraisal. Journal of the American Pharmacists Association: JAPhA. 2009;49(2):220-2. OVID-Medline. Exclude: No comparison group. [pmid: 19289349].
Di Noia J, Contento IR, Prochaska JO. Computer-mediated intervention tailored on transtheoretical model stages and processes of change increases fruit and vegetable consumption among urban African-American adolescents. Am J Health Promot. 2008;22(5):336-41. Hand search. Exclude: No feedback provided to participants. [pmid: 18517094].
Dishman RK, DeJoy DM, Wilson MG, et al. Move to improve: A randomized workplace trial to increase physical activity. Am J Prev Med. 2009;36(2):133-41. OVID-PsycINFO. Exclude: No feedback provided to participants. [pmid: 19135905].
Dobbins TA, Simpson JM, Oldenburg B, et al. Who comes to a workplace health risk assessment?. International Journal of Behavioral Medicine. 1998;5(4):323-34. OVID-Embase. Exclude: Does not report health outcomes. [pmid: 16250699].
Drolet BC, Rodgers S. A comprehensive medical student wellness program-design and implementation at vanderbilt school of medicine. Acad Med. 2010;85(1):103-10. OVID-Embase. Exclude: Does not report health outcomes. [pmid: 20042835].
Dubbert PM, Cooper KM, Kirchner KA, et al. Effects of nurse counseling on walking for exercise in elderly primary care patients. The Journals of Gerontology: Series A: Biological Sciences and Medical Sciences. 2002;57A(11):M733-M740. OVID-PsycINFO. Exclude: Self reported information not provided to participants.
Dwyer GB, Dwyer ES. Participation and psychological changes among retirees in a corporate fitness program. Am J Health Promot. 1992;6(3):167-8. OVID-Embase. Exclude: No comparison group. [pmid: 10146828].
Eakin EG, Bull SS, Riley KM, et al. Resources for health: A primary-care-based diet and physical activity intervention targeting urban Latinos with multiple chronic conditions. Health Psychol. 2007;26(4):392-400. OVID-PsycINFO. Exclude: Self reported information not provided to participants. [pmid: 17605558].
Eaton DK, Marx E, Bowie SE. Faculty and staff health promotion: results from the School Health Policies and Programs Study 2006. J Sch Health. 2007;77(8):557-66. OVID-Medline. Exclude: No feedback provided to participants. [pmid: 17908108].
Eddy JM, Eynon D, Nagy S, et al. Impact of a physical fitness program in a blue-collar workforce. Health Values. 1990;14(6):14-23. OVID-Medline. Exclude: Individualized recommendation not provided. [pmid: 10107726].
Edington M, Karjalainen T, Hirschland D, et al. The UAW-GM health promotion program. Successful outcomes. [Review] [4 refs]. AAOHN J. 2002;50(1):26-31. OVID-Medline. Exclude: No comparison group. [pmid: 11842778].
Eichler K, Scrabal C, Steurer J, et al. Preventive health risk appraisal for older people and impact on GPs’ patient management: a prospective study. Fam Pract. 2007;24(6):604-9. OVID-Medline. Exclude: No comparison group. [pmid: 17986626].
Einvik G, Ekeberg O, Lavik JG, et al. The influence of long-term awareness of hyperlipidemia and of 3 years of dietary counseling on depression, anxiety, and quality of life. J Psychosom Res. 2010;68(6):567-72. UPDATE_OVID_PsycINFO. Exclude: Does not report health outcomes. [pmid: 20488274].
Eklund K, Sjostrand J, Dahlin-Ivanoff S. A randomized controlled trial of a health-promotion programme and its effect on ADL dependence and self-reported health problems for the elderly visually impaired. Scandinavian Journal of Occupational Therapy. 2008;15(2):68-74. OVID-Embase. Exclude: Self reported information not provided to participants. [pmid: 17852958].
Elder JP, Williams SJ, Drew JA, et al. Longitudinal effects of preventive services on health behaviors among an elderly cohort. Am J Prev Med. 1995;11(6):354-9. OVID-Medline. Exclude: No comparison group. [pmid: 8775655].
Elder JP, Candelaria JI, Woodruff SI, et al. Results of Language for Health: Cardiovascular disease nutrition education for Latino English-as-a-second language students. Health Education & Behavior. 2000;27(1):50-63. OVID-PsycINFO. Exclude: Self reported information not provided to participants. [pmid: 10709792].
Ellis LB, Joo HY, Gross CR. Use of a computer-based health risk appraisal by older adults. J Fam Pract. 1991;33(4):390-4. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 1919457].
Elm Ev, Altman DG, Egger M, et al. Strengthening the reporting of observational studies in epidemiology (STROBE) statement: guidelines for reporting observational studies. BMJ. 2007;335(7624):806-8. http://www.bmj.com/content/335/7624/806.short. Exclude: Individualized recommendation not provided. [pmid: 17947786].
Elo AL, Leppanen A. Efforts of health promotion teams to improve the psychosocial work environment. J Occup Health Psychol. 1999;4(2):87-94. OVID-PsycINFO. Exclude: Individualized recommendation not provided. [pmid: 10212862].
Emmons KM, Linnan LA, Shadel WG, et al. The Working Healthy Project: a worksite health-promotion trial targeting physical activity, diet, and smoking. Journal of Occupational & Environmental Medicine. 1999;41(7):545-55. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 10412096].
Emmons KM, Marcus BH, Linnan L, et al. Mechanisms in multiple risk factor interventions: Smoking, physical activity, and dietary fat intake among manufacturing workers. Prev Med. 1994;23(4):481-9. OVID-Embase. Exclude: Does not report health outcomes. [pmid: 7971876].
Erfurt JC, Holtyn K. Health promotion in small business: what works and what doesn’t work. J Occup Med. 1991;33(1):66-73. OVID-Medline. Exclude: No comparison group. [pmid: 1995805].
Erfurt JC, Foote A, Heirich MA, et al. Improving participation in worksite wellness programs: Comparing health education classes, a menu approach, and follow-up counseling. Am J Health Promot. 2000;4(4):270-8. OVID-Embase. Exclude: Does not report health outcomes. [pmid: 22204510].
Estabrooks PA, Smith-Ray RL. Piloting a behavioral intervention delivered through interactive voice response telephone messages to promote weight loss in a pre-diabetic population. Patient Educ Couns. 2008;72(1):34-41. OVID-Embase. Exclude: No feedback provided to participants. [pmid: 18282679].
Evans GF, Harris P, McNeill AW, et al. Montana State University: an employee wellness program financed by a self-insurance group health plan. Am J Health Promot. 1989;3(4):25-33. Hand search. Exclude: No feedback provided to participants. [pmid: 22206392].
Faghri PD, Omokaro C, Parker C, et al. E-technology and pedometer walking program to increase physical activity at work. Journal of Primary Prevention. 2008;29(1):73-91. OVID-Medline. Exclude: Self reported information not provided to participants. [pmid: 18213518].
Farrell SW, Kohl HW, Bogdanffy GM. Incidence and reasons for medical referral in a worksite health promotion program. Am J Health Promot. 2000;3(3):6-10. OVID-Embase. Exclude: Does not report health outcomes. [pmid: 22206329].
Feinstein RE. Prevention-oriented primary care: a collaborative model for office-based cardiovascular risk reduction. Heart Disease. 1999;1(5):264-71. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 11720633].
Fielding JE. Worksite health promotion survey: smoking control activities. Prev Med. 1990;19(4):402-13. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 2399222].
Fielding JE. Work site stress management: national survey results. J Occup Med. 1989;31(12):990-5. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 2614540].
Fielding JE. Frequency of health risk assessment activities at U.S. worksites. Am J Prev Med. 1989;5(2):73-81. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 2730795].
Fielding JE, Breslow L. Health promotion programs sponsored by California employers. Am J Public Health. 1983;73(5):538-42. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 6837818].
Fine A, Ward M, Burr M, et al. Health promotion in small workplaces - A feasibility study. Health Educ J. 2004;63(4):334-46. OVID-Embase. Exclude: Does not report health outcomes.
Flocke SA, Gordon LE, Pomiecko GL. Evaluation of a community health promotion resource for primary care practices. Am J Prev Med. 2006;30(3):243-51. OVID-Embase. Exclude: Individualized recommendation not provided. [pmid: 16476641].
Flora JA, Lefebvre RC, Murray DM, et al. A community education monitoring system: Methods from the Stanford Five-City project, the Minnesota Heart Health Program and the Pawtucket Heart Health Program. Health Educ Res. 1993;8(1):81-95. OVID-Embase. Exclude: Does not report health outcomes. [pmid: 11067188].
Fox PJ, Breuer W, Wright JA. Effects of a health promotion program on sustaining health behaviors in older adults. Am J Prev Med. 1997;13(4):257-64. OVID-Embase. Exclude: Does not report health outcomes. [pmid: 9236961].
Frank E, Elon L, Hertzberg V. A quantitative assessment of a 4-year old intervention that improved patient counseling through improving medical student health. MedGenMed Medscape General Medicine. 2007;9(2). OVID-Embase. Exclude: No feedback provided to participants.
Fries JF, Fries ST, Parcell CL, et al. Health risk changes with a low-cost individualized health promotion program: Effects at up to 30 months. Am J Health Promot. 1992;6(5):364-71. OVID-Embase. Exclude: No comparison group. [pmid: 10148757].
Fries JF, Carey C, McShane DJ. Patient education in arthritis: randomized controlled trial of a mail-delivered program. J Rheumatol. 1997;24(7):1378-83. OVID-Medline. Exclude: Could not be retrieved. [pmid: 9228140].
Gabel JR, Whitmore H, Pickreign J, et al. Obesity and the workplace: current programs and attitudes among employers and employees. Health Aff (Millwood). 2009;28(1):46-56. OVID-Medline. Exclude: Self reported information not provided to participants. [pmid: 19124853].
Gemson DH, Commisso R, Fuente J, et al. Promoting weight loss and blood pressure control at work: impact of an education and intervention program. Journal of Occupational & Environmental Medicine. 2008;50(3):272-81. OVID-Medline. Exclude: No feedback provided to participants. [pmid: 18332777].
Giampaoli S, Poce A, Sciarra F, et al. Change in cardiovascular risk factors during a 10-year community intervention program. Acta Cardiol. 1997;52(5):411-22. OVID-Embase. Exclude: No feedback provided to participants. [pmid: 9428939].
Gilbert N, Barkham M, Richards A, et al. The effectiveness of a primary care mental health service delivering brief psychological interventions: A benchmarking study using the CORE system. Primary Care Mental Health. 2000;3(4):241-51. OVID-Embase. Exclude: Self reported information not provided to participants.
Gillis DE, Grossman MD, McLellan BY, et al. Participants’ evaluations of components of a physical-activity-promotion program for seniors (CHAMPS II). Journal of Aging and Physical Activity. 2000;10(3):336-53. OVID-Embase. Exclude: Does not report health outcomes.
Glanz K, Murphy S, Moylan J, et al. Improving dietary self-monitoring and adherence with hand-held computers: a pilot study. Am J Health Promot. 2006;20(3):165-70. Hand search. Exclude: Does not report health outcomes. [pmid: 16422134].
Glasgow RE, Hollis JF, Pettigrew L, et al. Implementing a year-long, worksite-based incentive program for smoking cessation. Am J Health Promot. 1991;5(3):192-9. OVID-Medline. Exclude: No feedback provided to participants. [pmid: 10148668].
Glasgow RE, Terborg JR, Hollis JF, et al. Take heart: results from the initial phase of a work-site wellness program. Am J Public Health. 1995;85(2):209-16. OVID-Medline. Exclude: No feedback provided to participants. [pmid: 7856780].
Glasgow RE, Strycker LA, King DK, et al. Robustness of a computer-assisted diabetes self-management intervention across patient characteristics, healthcare settings, and intervention staff. Am J Manag Care. 2006;12(3):137-45. OVID-Medline. Exclude: Self reported information not provided to participants. [pmid: 16524346].
Glasgow RE, Nelson CC, Kearney KA, et al. Reach, engagement, and retention in an Internet-based weight loss program in a multi-site randomized controlled trial. Journal of Medical Internet Research. 2007;9(2):1-10. OVID-PsycINFO. Exclude: Does not report health outcomes.
Godard C, Chevalier A, Lecrubier Y, et al. APRAND programme: An intervention to prevent relapses of anxiety and depressive disorders First results of a medical health promotion intervention in a population of employees. European Psychiatry. 2006;21(7):451-9. OVID-PsycINFO. Exclude: Self reported information not provided to participants. [pmid: 16675204].
Goetz AA, Duff JF, Bernstein JE. Health risk appraisal: the estimation of risk. Public Health Rep. 1980;95(2):119-26. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 7360870].
Goetzel RZ, Jacobson BH, Aldana SG, et al. Health care costs of worksite health promotion participants and non-participants. J Occup Environ Med. 2000;40(4):341-6. OVID-Embase. Exclude: Does not report health outcomes. [pmid: 9571525].
Golaszewski T, Yen LT. Demographic characteristics of users of worksite health promotion written materials. Am J Health Promot. 1992;6(5):359-63. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 10148756].
Goldstein MG, Pinto BM, Marcus BH, et al. Physician-based physical activity counseling for middle-aged and older adults: A randomized trial. Ann Behav Med. 1999;21(1):40-7. OVID-PsycINFO. Exclude: No feedback provided to participants. [pmid: 18425653].
Goodspeed RB, DeLucia AG. Stress reduction at the worksite: an evaluation of two methods. Am J Health Promot. 1990;4(5):333-7. Hand search. Exclude: Self reported information not provided to participants. [pmid: 22204572].
Gosliner WA, James P, Yancey AK, et al. Impact of a worksite wellness program on the nutrition and physical activity environment of child care centers. American journal of health promotion : AJHP. 2010;24(3):186-9. OVID-Embase. Exclude: No feedback provided to participants. [pmid: 20073385].
Gran B. Population based CVD health risk appraisal. A method to create a "critical mass" of health-conscious people. Scand J Soc Med. 1994;22(4):256-63. OVID-Medline. Exclude: Individualized recommendation not provided. [pmid: 7716436].
Greaney ML, Riebe D, Garber CE, et al. Long-term effects of a stage-based intervention for changing exercise intentions and behavior in older adults. Gerontologist. 2008;48(3):358-67. OVID-Embase. Exclude: Self reported information not provided to participants. [pmid: 18591361].
Green BB, McAfee T, Hindmarsh M, et al. Effectiveness of telephone support in increasing physical activity levels in primary care patients. Am J Prev Med. 2002;22(3):177-83. OVID-Medline. Exclude: Self reported information not provided to participants. [pmid: 11897462].
Greenwood PJ, Ellis LB, Gross CR. Knowledge gains from a computer-based health risk appraisal. Proceedings - the Annual Symposium on Computer Applications in Medical Care. 1991:173-6. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 1807581].
Gregg W, Foote A, Erfurt JC, et al. Worksite follow-up and engagement strategies for initiating health risk behavior changes. Health Educ Q. 1990;17(4):455-78. OVID-PsycINFO. Exclude: Individualized recommendation not provided. [pmid: 2262325].
Grosch JW, Alterman T, Petersen MR, et al. Worksite health promotion programs in the U.S.: factors associated with availability and participation. Am J Health Promot. 1998;13(1):36-45. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 10186933].
Gupta A, McMahon S, Sandhu G. Identification of health risk factors among undergraduate university students stage 2: health hazard appraisal. Nurs Pap. 1985;17(3):37-47. OVID-Medline. Exclude: No feedback provided to participants. [pmid: 3854459].
Hall N, De Beck P, Johnson D, et al. Randomized trial of a health promotion program for frail elders. Can J Aging. 1992;11(1):72-91. OVID-Embase. Exclude: No feedback provided to participants.
Halpin HA, McMenamin SB, Schmittdiel J, et al. The routine use of health risk appraisals: results from a national study of physician organizations. Am J Health Promot. 2005;20(1):34-8. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 16171159].
Harris JS. Northern Telecom: a million dollar medically based program in a rapidly changing high tech environment. Am J Health Promot. 2000;1(1):50-84. Hand search. Exclude: Individualized recommendation not provided. [pmid: 22208924].
Havas S, Damron D, Treiman K, et al. The Maryland WIC 5 a day promotion program pilot study: Rationale, results, and lessons learned. Journal of Nutrition Education. 1997;29(6):343-50. OVID-PsycINFO. Exclude: No feedback provided to participants.
Haynes CL, Cook GA. A comparison of patients’ perceptions and an audit of health promotion practice within a UK hospital. BMC Public Health. 2007;7:242. OVID-Medline. Exclude: No feedback provided to participants. [pmid: 17854495].
Heirich M, Sieck CJ. Worksite cardiovascular wellness programs as a route to substance abuse prevention. Journal of Occupational & Environmental Medicine. 2000;42(1):47-56. OVID-Medline. Exclude: Self reported information not provided to participants. [pmid: 10652688].
Henritze J, Brammell HL, McGloin J. LIFECHECK: a successful, low touch, low tech, in-plant, cardiovascular disease risk identification and modification program. Am J Health Promot. 1992;7(2):129-36. OVID-Medline. Exclude: Individualized recommendation not provided. [pmid: 10148717].
Henritze J, Brammell HL. Phase II Cardiac Wellness at the Adoph Coors Company. Am J Health Promot. 2000;4(1):25-31. Hand search. Exclude: Does not report health outcomes. [pmid: 22204355].
Hillemeier MM, Downs DS, Feinberg ME, et al. Improving women’s preconceptional health: findings from a randomized trial of the Strong Healthy Women intervention in the Central Pennsylvania women’s health study. Womens Health Issues. 2008;18(6:Suppl):S87-S96. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 19059553].
Hind D, Scott EJ, Copeland R, et al. A randomised controlled trial and cost-effectiveness evaluation of "booster" interventions to sustain increases in physical activity in middle-aged adults in deprived urban neighbourhoods. BMC Public Health. 2010;10:3 U. PDATE_OVID_EMBASE. Exclude: Does not report health outcomes. [pmid: 20047672].
Hodges LC, Harper TS, Hall-Barrow J, et al. Reducing overall health care costs for a city municipality: a real life community based learning model. AAOHN J. 2004;52(6):247-53. OVID-Medline. Exclude: No comparison group. [pmid: 15219111].
Horgan JMP, Blenkinsopp A, McManus RJ. Evaluation of a cardiovascular disease opportunistic risk assessment pilot (‘Heart MOT’ service) in community pharmacies. Journal of Public Health. 2010;32(1):110-6. OVID-Embase. Exclude: Does not report health outcomes. [pmid: 19864496].
Hornsby PP, Reeve RH, Gwaltney JM Jr, et al. The University of Virginia health promotion and disease prevention program. Am J Prev Med. 1997;13(1):36-44. OVID-Medline. [pmid: 9037340].
Horvath M, Frantik E, Kozena L. Work stress and health in research and development personnel. Homeost Health Dis. 1997;38(2):73-82. OVID-PsycINFO.
Hsu SW, Lin JD, Lee KT, et al. Employees’ perception of workplace health promotion initiatives in Taiwan: a cross-sectional survey of 30 worksites. Ind Health. 2009;47(5):551-9. OVID-Medline. Exclude: Self reported information not provided to participants. [pmid: 19834265].
Hung DY. Improving the delivery of preventive care services. Manag Care Interface. 2000;20(5):38-44. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 17626591].
Hunt MK, Harley AE, Stoddard AM, et al. Elements of External Validity of Tools for Health: An Intervention for Construction Laborers. Am J Health Promot. 2010;24(5):e11-e20. Hand search. Exclude: Does not report health outcomes. [pmid: 20569107].
Hunt MK, Lederman R, Stoddard A, et al. Process tracking results from the Treatwell 5-a-Day Worksite Study. Am J Health Promot. 2000;14(3):179-87. OVID-Medline. Exclude: No feedback provided to participants. [pmid: 10787771].
Hunt MK, Lobb R, Delichatsios HK, et al. Process evaluation of a clinical preventive nutrition intervention. Prev Med. 2001;33(2,Pt.1of2):82-90. OVID-PsycINFO. Exclude: Does not report health outcomes. [pmid: 11493040].
Hurling R, Catt M, De Boni M, et al. Using Internet and mobile phone technology to deliver an automated physical activity program: Randomized controlled trial. Journal of Medical Internet Research. 2007;9(2):1-12. OVID-PsycINFO. Exclude: Self reported information not provided to participants.
Hyner GC, Petri CJ, Melby CL. The effects of different health risk appraisal feedback on health-related behaviors in a worksite population. Health Educ Res. 1987;2(2):161-4. OVID-Embase. Exclude: Does not report health outcomes.
Iliffe S, Kharicha K, Harari D, et al. User involvement in the development of a health promotion technology for older people: Findings from the SWISH project. Health & Social Care in the Community. 2000;18(2):147-59. OVID-PsycINFO. Exclude: Does not report health outcomes. [pmid: 19708867].
Iliffe S, Kharicha K, Harari D, et al. Health risk appraisal for older people in general practice using an expert system: a pilot study. Health & Social Care in the Community. 2010;13(1):21-9. OVID-Medline. Exclude: No comparison group. [pmid: 15717903].
Jette M, Quenneville J, Sidney K. Fitness testing and counselling in health promotion. Can J Sport Sci. 1992;17(3):194-8. OVID-Medline. Exclude: Individualized recommendation not provided. [pmid: 1325258].
Johnson CC, Lai YL, Rice J, et al. ACTION Live: Using process evaluation to describe implementation of a worksite wellness program. J Occup Environ Med. 2010;52(Suppl 1):S14-S21 U. PDATE_OVID_PsycINFO. Exclude: Does not report health outcomes. [pmid: 20061882].
Johnson LT, Ralston PA, Jones E. Beauty salon health intervention increases fruit and vegetable consumption in African-American women. J Am Diet Assoc. 2010;110(6):941-5. UPDATE_OVID_EMBASE. Exclude: No feedback provided to participants. [pmid: 20497787].
Johnston CA, Tyler C, McFarlin BK, et al. Effects of a school-based weight maintenance program for mexican-american children: Results at 2 years. Obesity. 2010;18(3):542-7. UPDATE_OVID_EMBASE. Exclude: No feedback provided to participants. [pmid: 19661957].
Jones DE, Weaver MT, Friedmann E. Promoting heart health in women: a workplace intervention to improve knowledge and perceptions of susceptibility to heart disease. AAOHN J. 2007;55(7):271-6. OVID-Medline. Exclude: No feedback provided to participants. [pmid: 17665824].
Jones RC, Bly JL, Richardson JE. A study of a work site health promotion program and absenteeism. J Occup Med. 1990;32(2):95-9. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 2303925].
Kaczorowski J, Chambers LW, Karwalajtys T, et al. Cardiovascular Health Awareness Program (CHAP): A community cluster-randomised trial among elderly Canadians. Prev Med. 2008;46(6):537-44. OVID-Embase. Exclude: Does not report health outcomes. [pmid: 18372036].
Kaijser CF. Health promotion in occupational health. Methods Inf Med. 2005;44(2):285-7. OVID-Medline. Exclude: Self reported information not provided to participants. [pmid: 15924193].
Kaphingst KA, Lobb R, Fay ME, et al. Impact of intervention dose on cancer-related health behaviors among working-class, multiethnic, community health center patients. Am J Health Promot. 2007;21(4):262-6. Hand search. Exclude: Self reported information not provided to participants. [pmid: 17375492].
Kaplan LH, Burch-Minakan L. Reach out for health: a corporation’s approach to health promotion. Am J Occup Ther. 1986;40(11):777-80. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 3789071].
Kashani IA, Kaplan RM, Criqui MH, et al. Cardiovascular risk factor assessment of medical students as an educational tool. Am J Prev Med. 1992;8(6):384-8. OVID-Embase. Exclude: Individualized recommendation not provided. [pmid: 1482580].
Kashima SR. Transitioning from a pen-and-paper health risk appraisal to an online health risk appraisal at a petroleum company. Health Promotion Practice. 2006;7(4):450-8. OVID-Medline. Exclude: No comparison group. [pmid: 16840773].
Kashima SR. A petroleum company’s experience in implementing a comprehensive medical fitness for duty program for professional truck drivers. Journal of Occupational & Environmental Medicine. 2003;45(2):185-96. OVID-Medline. Exclude: No feedback provided to participants. [pmid: 12625233].
Kellerman ST, Felts WM, Chenier TC. The impact on factory workers of health risk appraisal and counseling in health promotion. Am J Prev Med. 1992;8(1):37-42. OVID-Medline. Exclude: Could not be retrieved. [pmid: 1575999].
Kelly RB. Controlled trial of a time-efficient method of health promotion. Am J Prev Med. 1988;4(4):200-7. OVID-Embase. Exclude: Does not report health outcomes. [pmid: 3166825].
Kenkel PJ. Financial incentives in wellness plans aimed at reducing insurance costs by helping workers shed unhealthy habits. Mod Healthc. 1992;22(3):38. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 10115828].
Kenny JC, Purvis P. Computerized health risk assessment at the work site. Home Healthc Nurse. 1988;6(1):17-24. OVID-Medline. Exclude: Individualized recommendation not provided. [pmid: 3343138].
Keyserling TC, Samuel Hodge CD, Jilcott SB, et al. Randomized trial of a clinic-based, community-supported, lifestyle intervention to improve physical activity and diet: The North Carolina enhanced WISEWOMAN project. Prev Med. 2008;46(6):499-510. OVID-Embase. Exclude: Self reported information not provided to participants. [pmid: 18394692].
Kim CG, June KJ, Song R. Effects of a health-promotion program on cardiovascular risk factors, health behaviors, and life satisfaction in institutionalized elderly women. Int J Nurs Stud. 2003;40(4):375-81. OVID-PsycINFO. Exclude: Individualized recommendation not provided. [pmid: 12667514].
King DK, Estabrooks PA, Strycker LA, et al. Outcomes of a multifaceted physical activity regimen as part of a diabetes self-management intervention. Ann Behav Med. 2006;31(2):128-37. OVID-Medline. Exclude: Self reported information not provided to participants. [pmid: 16542127].
Klerman LV, Ramey SL, Goldenberg RL. A randomized trial of augmented prenatal care for multiple-risk, Medicaid-eligible African American women. Am J Public Health. 2001;91(1):105-11. CSA-SocialScienceAbstracts. Exclude: Self reported information not provided to participants. [pmid: 11189800].
Koku RV. Severity of low back pain: A comparison between participants who did and did not receive counseling. AAOHN J. 1992;40(2):84-9. OVID-Embase. Exclude: Self reported information not provided to participants. [pmid: 1531591].
Komarek L, Kebza V, Lhotska L, et al. ‘Healthy Dubec’ - Design of a joint Czech-American community project for the reduction of cardiovascular and cerebrovascular disease (adapted from American experience). Cent Eur J Public Health. 1995;3(4):230-3. OVID-Embase. Exclude: Does not report health outcomes. [pmid: 8903527].
Kottke TE, Roger VL, Nguyen TT, et al. CardioVision 2020: A multidisciplinary cardiovascular disease prevention project. European Heart Journal, Supplement. 1999;1(S):S14-S18 O. VID-Embase. Exclude: No feedback provided to participants.
Krebs P, Prochaska JO, Rossi JS. A meta-analysis of computer-tailored interventions for health behavior change. Prev Med. 2010;51(3–4):214-21. UPDATE_OVID_EMBASE. Exclude: Does not report health outcomes. [pmid: 20558196].
Kreuter MW, Strecher VJ. Changing inaccurate perceptions of health risk: results from a randomized trial. Health Psychol. 1995;14(1):56-63. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 7737074].
Kreuter MW, Bull FC, Clark EM, et al. Understanding how people process health information: A comparison of tailored and nontailored weight-loss materials. Health Psychol. 1999;18(5):487-94. OVID-PsycINFO. Exclude: Does not report health outcomes. [pmid: 10519465].
Kristal AR, Curry SJ, Shattuck AL, et al. A randomized trial of a tailored, self-help dietary intervention: The puget sound eating patterns study. Prev Med. 2000;31(4):380-9. OVID-Embase. Exclude: Self reported information not provided to participants. [pmid: 11006063].
Kronenfeld JJ, Jackson KL, Davis KE, et al. Changing health practices: the experience from a worksite health promotion project. Social Science & Medicine. 1988;26(5):515-23. OVID-Medline. Exclude: Individualized recommendation not provided. [pmid: 3353760].
LaDou J, Sherwood JN, Hughes L. Health hazard appraisal counseling--continuing evaluation. West J Med. 1979;130(3):280-5. OVID-Medline. Exclude: No comparison group. [pmid: 425518].
LaDou J, Sherwood JN, Hughes L. Health hazard appraisal in patient counseling. West J Med. 1975;122(2):177-80. OVID-Medline. Exclude: No comparison group. [pmid: 1114813].
Larson CO, Stroebel CK, Perkey BN. Merging education with measurement: A focus on the hispanic community. J Ambulatory Care Manage. 2001;24(3):27-36. OVID-Embase. Exclude: Does not report health outcomes. [pmid: 11433553].
Larsson A, Karlqvist L, Gard G. Effects of work ability and health promoting interventions for women with musculoskeletal symptoms: a 9-month prospective study. BMC Musculoskeletal Disorders. 2008;9:105. OVID-Medline. Exclude: Self reported information not provided to participants. [pmid: 18644154].
Laszlo CA, Varga LE. A computerized health hazard appraisal system (CHAMP). Methods Inf Med. 1981;20(3):147-56. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 7278692].
Latimer AE, Williams-Piehota P, Katulak NA, et al. Promoting fruit and vegetable intake through messages tailored to individual differences in regulatory focus. Ann Behav Med. 2000;35(3):363-9. OVID-Embase. Exclude: Self reported information not provided to participants. [pmid: 18670833].
Lauritzen T, Leboeuf-Yde C, Lunde IM, et al. Ebeltoft project: Baseline data from a five-year randomized, controlled, prospective health promotion study in a Danish population. Br J Gen Pract. 1995;45(399):542-7. OVID-Embase. Exclude: Does not report health outcomes. [pmid: 7492424].
Lave JR, Ives DG, Traven ND, et al. Participation in health promotion programs by the rural elderly. Am J Prev Med. 1995;11(1):46-53. OVID-Embase. Exclude: Does not report health outcomes. [pmid: 7748586].
Lave JR, Ives DG, Traven ND, et al. Evaluation of a health promotion demonstration program for the rural elderly. Health Serv Res. 1996;31(3):261-81. OVID-Medline. Exclude: Self reported information not provided to participants. [pmid: 8698585].
Leeman-Castillo B, Beaty B, Raghunath S, et al. LUCHAR: using computer technology to battle heart disease among Latinos. Am J Public Health. 2010;100(2):272-5. OVID-Embase. Exclude: Individualized recommendation not provided. [pmid: 20019305].
Leslie JH, Hughes CK, Braun KL. Engaging participants in design of a Native Hawaiian worksite wellness program. Progress in community health partnerships : research, education, and action. 2010;4(2):121-30. UPDATE_OVID_EMBASE. Exclude: Does not report health outcomes.
Leslie WS, Lean ME, Baillie HM, et al. Weight management: a comparison of existing dietary approaches in a work-site setting. Int J Obes Relat Metab Disord. 2002;26(11):1469-75. SR Reference. Exclude: Self reported information not provided to participants. [pmid: 12439649].
Leurs MT, Schaalma HP, Jansen MW, et al. Development of a collaborative model to improve school health promotion in The Netherlands. Health Promotion International. 2005;20(3):296-305. OVID-Medline. Exclude: Self reported information not provided to participants. [pmid: 15797902].
Levenkron JC, Greenland P. Patient priorities for behavioral change: selecting from multiple coronary disease risk factors. J Gen Intern Med. 1988;3(3):224-9. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 3379491].
Lewis BA, Williams DM, Neighbors CJ, et al. Cost analysis of Internet vs. print interventions for physical activity promotion. Psychology of Sport and Exercise. 2010;11(3):246-9. OVID-PsycINFO. Exclude: Does not report health outcomes. [pmid: 20401164].
Lewis RJ, Huebner WW, Yarborough CM III. Characteristics of participants and nonparticipants in worksite health promotion. Am J Health Promot. 1996;11(2):99-106. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 10163602].
Liaw T, Lawrence M, Rendell J. The effect of a computer-generated patient-held medical record summary and/or a written personal health record on patients’ attitudes, knowledge and behaviour concerning health promotion. Fam Pract. 2000;13(3):289-93. OVID-Embase. Exclude: Does not report health outcomes. [pmid: 8671137].
Licciardone JC. The planning, development, and implementation of a work-site health promotion program: a case study. J Am Osteopath Assoc. 1992;92(2):213-8. OVID-Medline. [pmid: 1544824].
Lindberg NM, Stevens VJ, Smith KS, et al. A brief intervention designed to increase breast cancer self-screening. Am J Health Promot. 2009;23(5):320-3. Hand search. Exclude: Does not report health outcomes. [pmid: 19445434].
Lindstrom J, llanne-Parikka P, Peltonen M, et al. Sustained reduction in the incidence of type 2 diabetes by lifestyle intervention: Follow-up of the Finnish Diabetes Prevention Study. The Lancet. 2006;368(9548):1673-9. OVID-PsycINFO. Exclude: Self reported information not provided to participants.
Lingfors H, Lindstrom K, Persson L-G, et al. Evaluation of "live for life", a health promotion programme in the County of Skaraborg, Sweden. J Epidemiol Community Health. 2001;55(4):277-82. OVID-Embase. Exclude: No comparison group. [pmid: 11238584].
Linnan LA, Harden EA, Bucknam L, et al. Marketing cardiovascular disease risk reduction programs at the workplace. The Pawtucket Heart Health Program Experience. AAOHN J. 2008;38(9):409-18. OVID-Embase. Exclude: Does not report health outcomes. [pmid: 2397012].
Lipkus IM, Skinner CS, Green LSG, et al. Modifying attributions of colorectal cancer risk. Cancer Epidemiology Biomarkers and Prevention. 2004;13(4):560-6. OVID-Embase. Exclude: Does not report health outcomes.
Lippman H. A fast drive to good health: supermarket staffers reap the rewards of a wellness program that rolls up to the door of their store, complete with counselors and coaches. Business & Health. 1999;17(4):17-8. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 10351242].
lliffe S, Swift C, Harari D, et al. Health promotion in later life: Public and professional perspectives on an expert system for health risk appraisal. Primary Health Care Research and Development. 2010;11(2):187-96. UPDATE_OVID_PsycINFO. Exclude: Does not report health outcomes.
Lobach DF, Silvey GM, Willis JM, et al. Coupling direct collection of health risk information from patients through kiosks with decision support for proactive care management. AMIA 2008;Annual:Symposium-33. [pmid: 18999181]. OVID-Medline. Exclude: Does not report health outcomes.
Loeppke R, Nicholson S, Taitel M, et al. The impact of an integrated population health enhancement and disease management program on employee health risk, health conditions, and productivity. Population Health Management. 2008;11(6):287-96. OVID-Medline. Exclude: Could not be retrieved. [pmid: 19108644].
Long DA, Perry TL. An application of survival analysis to population health management program evaluation. Am J Health Promot. 2007;21(6):529-33. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 17674641].
Lux KM. Health risk appraisals as a risk management tool. Perspect Healthc Risk Manage. 1992;12(1):25-8. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 10116281].
Lynch WD, Golaszewski TJ, Clearie A, et al. Characteristics of self-selected responders to a health risk appraisal: generalizability of corporate health assessments. Am J Public Health. 1989;79(7):887-8. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 2735480].
Mackey T, Adams J. The use of health risk appraisal in a nursing center: costs and benefits. NLN Publ. 1994;(41-2629):253-65. OVID-Medline. Exclude: Could not be retrieved. [pmid: 7596802].
MacStravic S. Wellness: piecemeal or personalized?. Health Care Strateg Manage. 2004;22(2):1-5. OVID-Medline. Exclude: Self reported information not provided to participants. [pmid: 15005072].
Maes L, Lievens J. Can the school make a difference? A multilevel analysis of adolescent risk and health behaviour. Soc Sci Med. 2003;56(3):517-29. OVID-Embase. Exclude: Does not report health outcomes. [pmid: 12570971].
Maffeo C, Chase P, Brown B, et al. My First Patient Program to introduce first-year pharmacy students to health promotion and disease prevention. Am J Pharm Educ. 2009;73(6):97. OVID-Medline. Exclude: No comparison group. [pmid: 19885066].
Mangunkusumo R, Brug J, Duisterhout J, et al. Feasibility, acceptability, and quality of Internet-administered adolescent health promotion in a preventive-care setting. Health Educ Res. 2007;22(1):1-13. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 16714366].
Marcus BH, Emmons KM, Simkin-Silverman LR, et al. Evaluation of motivationally tailored vs. standard self-help physical activity interventions at the workplace. Am J Health Promot. 1998;12(4):246-53. OVID-Medline. Exclude: No feedback provided to participants. [pmid: 10178617].
Marcus BH, Napolitano MA, King AC, et al. Examination of print and telephone channels for physical activity promotion: Rationale, design, and baseline data from Project STRIDE. Contemporary Clinical Trials. 2007;28(1):90-104. OVID-Embase. Exclude: Does not report health outcomes. [pmid: 16839823].
Marcus BH, Forsyth LH. Tailoring interventions to promote physically active lifestyles in women. Women’s Health Issues. 1998;8(2):104-11. OVID-Embase. Exclude: Does not report health outcomes. [pmid: 9542465].
Marlowe M, Adams J. Individual and organizational health at Rockwell International. Corp Comment. 1985;1(4):14-21. OVID-Medline. Exclude: Could not be retrieved. [pmid: 10272147].
Marshall AL, Booth ML, Bauman AE. Promoting physical activity in Australian general practices: A randomised trial of health promotion advice versus hypertension management. Patient Educ Couns. 2005;56(3):283-90. OVID-Embase. Exclude: Self reported information not provided to participants. [pmid: 15721970].
Martens M, van Assema P, Knibbe R, et al. Family environmental factors do not explain differences in the behavioral effect of a healthy diet promotion program in lower vocational schools among 12- to 14-year-old adolescents. Am J Health Promot. 2010;24(3):182-5. UPDATE_OVID_PsycINFO. [pmid: 20073384].
Matloff ET, Shannon KM, Moyer A, et al. Should menopausal women at increased risk for breast cancer use tamoxifen, raloxifene, or hormone therapy?: A framework for personalized risk assessment and counseling. J Cancer Educ. 2007;22(1):10-4. OVID-Embase. Exclude: Does not report health outcomes. [pmid: 17570802].
Maynard LJ. Short-term impact of a voluntary health intervention on overall vs. preventive healthcare consumption. International Journal of Consumer Studies. 2008;32(3):296-302. OVID-PsycINFO. Exclude: Does not report health outcomes.
McAlister AL, Ramirez AG, Amezcua C, et al. Smoking cessation in Texas-Mexico border communities: a quasi-experimental panel study. Am J Health Promot. 1992;6(4):274-9. Hand search. Exclude: Self reported information not provided to participants. [pmid: 10148752].
McClure JB, Ludman E, Grothaus L, et al. Immediate and short-term impact of a brief motivational smoking intervention using a biomedical risk assessment: the Get PHIT trial. Nicotine & Tobacco Research. 2009;11(4):394-403. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 19299409].
McCoy MR, Couch D, Duncan ND, et al. Evaluating an internet weight loss program for diabetes prevention. Health Promotion International. 2005;20(3):221-8. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 15797900].
McMahon A, Kelleher CC, Helly G, et al. Evaluation of a workplace cardiovascular health promotion programme in the Republic of Ireland. Health Promotion International. 2002;17(4):297-308. OVID-Medline. Exclude: No feedback provided to participants. [pmid: 12406918].
McNeil DA, Wilson BN, Siever JE, et al. Connecting children to recreational activities: results of a cluster randomized trial. Am J Health Promot. 2009;23(6):376-87. Hand search. Exclude: No feedback provided to participants. [pmid: 19601477].
McWilliam CL, Stewart M, Brown JB, et al. Home-based health promotion for chronically ill older persons: Results of a randomized controlled trial of a critical reflection approach. Health Promotion International. 1999;14(1):27-41. OVID-Embase. Exclude: Self reported information not provided to participants.
Meng H, Wamsley B, Liebel D, et al. Urban-rural differences in the effect of a Medicare health promotion and disease self-management program on physical function and health care expenditures. The Gerontologist. 2009;49(3):407-17. OVID-PsycINFO. Exclude: Self reported information not provided to participants. [pmid: 19401357].
Merrill RM, Aldana SG, Ellrodt G, et al. Efficacy of the Berkshire Health System Cardiovascular Health Risk Reduction Program. Journal of Occupational & Environmental Medicine. 2009;51(9):1024-31. OVID-Medline. Exclude: No comparison group. [pmid: 19687756].
Metcalfe LL. Campbell Soup Company’s Turnaround Health and Fitness Program. Am J Health Promot. Fall. 1986:58-68. Hand search. Exclude: No comparison group. [pmid: 22208210].
Milani RV, Lavie CJ. Impact of Worksite Wellness Intervention on Cardiac Risk Factors and One-Year Health Care Costs. Am J Cardiol. 2009;104(10):1389-92. OVID-Embase. Exclude: Does not report health outcomes. [pmid: 19892055].
Mills PR. The development of a new corporate specific health risk measurement instrument, and its use in investigating the relationship between health and well-being and employee productivity. Environmental Health: A Global Access Science Source. 2005;4(1):1. OVID-Medline. Exclude: No feedback provided to participants. [pmid: 15679885].
Moe EL, Elliot DL, Goldberg L, et al. Promoting Healthy Lifestyles: Alternative Models’ Effects (PHLAME). Health Educ Res. 2002;17(5):586-96. OVID-Embase. Exclude: Does not report health outcomes. [pmid: 12408203].
Moody LE, Moriarty DG. An interactive health risk appraisal for adolescents: a developmental microcomputer model. Health Educ. 1983;14(6):42-6. OVID-Medline. Exclude: Individualized recommendation not provided. [pmid: 6443957].
Mott DS, Virgilio SJ, Warren BL. Effectiveness of a personalized fitness module on knowledge: attitude, and cardiovascular endurance of fifth-grade students: "Heart Smart". Percept Mot Skills. 1991;73:847-58. CSA-SocialScienceAbstracts. Exclude: Self reported information not provided to participants. [pmid: 1792133].
Moy FM, Ab SA, Wong ML. Dietary modification in a workplace health promotion program in Kuala Lumpur, Malaysia. Asia Pac J Public Health. 2008;20:Suppl-72. OVID-Medline. Exclude: No feedback provided to participants. [pmid: 19533877].
MSMS Future of Medicine Wellness Workgroup. A look at health risk appraisals as a tool for patients and physicians. Mich Med. 2008;107(3):19-21. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 18700400].
Muntendam P, McCall C, Sanz J, et al. The BioImage Study: Novel approaches to risk assessment in the primary prevention of atherosclerotic cardiovascular disease-study design and objectives. Am Heart J. 2010;160(1):49-57. UPDATE_OVID_EMBASE. Exclude: Does not report health outcomes. [pmid: 20598972].
Musich S, Adams L, DeWolf G, et al. A case study of 10-year health risk appraisal participation patterns in a comprehensive health promotion program. Am J Health Promot. 2001;15(4):237-40. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 11349344].
Musich S, Ignaczak A, McDonald T, et al. Self-reported utilization of preventive health services by retired employees age 65 and older. J Am Geriatr Soc. 2001;49(12):1665-72. OVID-Medline. Exclude: No comparison group. [pmid: 11844001].
Musich S, McDonald T, Hirschland D, et al. Examination of risk status transitions among active employees in a comprehensive worksite health promotion program. [Erratum appears in J Occup Environ Med. 2003 Jun;45(6):663]. Journal of Occupational & Environmental Medicine. 2003;45(4):393-9. OVID-Medline. Exclude: No comparison group. [pmid: 12708143].
Muto T, Hsieh SD, Sakurai Y. Status of health promotion programme implementation in small-scale enterprises in Japan. Occup Med. 1999;49(2):65-70. OVID-Embase. Exclude: Does not report health outcomes.
Muto T, Yamauchi K. Evaluation of a multicomponent workplace health promotion program conducted in Japan for improving employees’ cardiovascular disease risk factors. Prev Med. 2001;33(6):571-7. OVID-PsycINFO. Exclude: Self reported information not provided to participants. [pmid: 11716652].
Naydeck BL, Pearson JA, Ozminkowski RJ, et al. The impact of the highmark employee wellness programs on 4-year healthcare costs. Journal of Occupational & Environmental Medicine. 2008;50(2):146-56. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 18301171].
Ndetan H, Evans J, Felini M, et al. Chiropractic and medical use of health promotion in the management of arthritis: Analysis of the 2006 national health interview survey. J Manipulative Physiol Ther. 2010;33(6):419-24. UPDATE_OVID_EMBASE. Exclude: Does not report health outcomes. [pmid: 20732578].
Neale AV, Singleton SP, Dupuis MH, et al. The use of behavioral contracting to increase exercise activity. Am J Health Promot. 1990;4(6):441-7. OVID-Embase. Exclude: Individualized recommendation not provided. [pmid: 22204622].
Neighbor J, Scott CS, Schaad DC, et al. Assessment and counseling of coronary risk factors by family practice residents. J Fam Pract. 1991;32(3):273-81. OVID-Embase. Exclude: Does not report health outcomes. [pmid: 2002318].
Neutens JJ, Pursley RJ. A comparison of two HRAs for use in the university classroom. J Sch Health. 1985;55(10):413-7. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 3853036].
Nichols JF, Wellman E, Caparosa S, et al. Impact of a worksite behavioral skills intervention. Am J Health Promot. 2000;14(4):218-21. ii. Hand search. Exclude: No feedback provided to participants. [pmid: 10915531].
Nilsson PM, Klasson EB, Nyberg P. Life-style intervention at the worksite--reduction of cardiovascular risk factors in a randomized study. Scand J Work Environ Health. 2001;27(1):57-62. SR Reference. Exclude: No feedback provided to participants. [pmid: 11266148].
Nohammer E, Schusterschitz C, Stummer H. Determinants of employee participation in workplace health promotion. International Journal of Workplace Health Management. 2010;3(2):97-110. UPDATE_OVID_EMBASE.
O’Connell M, Lucan SC, Yeh MC, et al. Impediment Profiling for Smoking Cessation: Results of a Pilot Study. Am J Health Promot. 2003;17(5):300-3. OVID-PsycINFO. Exclude: No feedback provided to participants. [pmid: 12769044].
O’Malley SS, Jaffe AJ, Chang G, et al. Naltrexone and coping skills therapy for alcohol dependence. A controlled study. Arch Gen Psychiatry. 1992;49(11):881-7. SR Reference. Exclude: No feedback provided to participants. [pmid: 1444726].
Oldenburg B, Owen N, Parle M, et al. An economic evaluation of four work site based cardiovascular risk factor interventions. Health Educ Q. 1995;22(1):9-19. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 7721604].
Ostwald SK. Changing employees’ dietary and exercise practices: an experimental study in a small company. J Occup Med. 1989;31(2):90-7. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 2709166].
Owen N, James R, Henrikson D, et al. Community cholesterol screenings: the impact of follow-up letters and incentives on retest rates and biometric changes in follow-up screenings. Am J Health Promot. 1990;5(1):58-61. Hand search. Exclude: Does not report health outcomes. [pmid: 22188154].
Ozminkowski RJ, Goetzel RZ, Smith MW, et al. The impact of the Citibank, NA, health management program on changes in employee health risks over time. Journal of Occupational & Environmental Medicine. 2000;42(5):502-11. OVID-Medline. Exclude: No comparison group. [pmid: 10824303].
Ozminkowski RJ, Goetzel RZ, Wang F, et al. The savings gained from participation in health promotion programs for Medicare beneficiaries. Journal of Occupational & Environmental Medicine. 2006;48(11):1125-32. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 17099448].
Ozminkowski RJ, Dunn RL, Goetzel RZ, et al. A return on investment evaluation of the Citibank, N.A., health management program. Am J Health Promot. 1999;14(1):31-43. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 10621522].
Ozminkowski RJ, Goetzel RZ, Santoro J, et al. Estimating risk reduction required to break even in a health promotion program. Am J Health Promot. 2004;18(4):316-25. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 15011932].
Pai C-W, Edington DW. Association between behavioral intention and actual change for physical activity, smoking, and body weight among an employed population. J Occup Environ Med. 2008;50(9):1077-83. OVID-Embase. Exclude: No feedback provided to participants. [pmid: 18784556].
Pai CW, Hagen SE, Bender J, et al. Effect of health risk appraisal frequency on change in health status. Journal of Occupational & Environmental Medicine. 2009;51(4):429-34. OVID-Medline. Exclude: No feedback provided to participants. [pmid: 19359896].
Paine-Andrews A, Harris KJ, Fawcett SB, et al. Evaluating a statewide partnership for reducing risks for chronic diseases. J Community Health. 1997;22(5):343-59. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 9353682].
Paperny DM, Hedberg VA. Computer-assisted health counselor visits: a low-cost model for comprehensive adolescent preventive services. Archives of Pediatrics & Adolescent Medicine. 1999;153(1):63-7. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 9895001].
Park K, Choi KS, Kye SY, et al. Unwanted effects of risk notification for breast cancer regarding intention toward mammography utilizationy. Psychooncology. 2010;19(8):823-9. UPDATE_OVID_EMBASE. [pmid: 19653333].
Pate RR, Saunders RP, Ward DS, et al. Evaluation of a community-based intervention to promote physical activity in youth: Lessons from active winners. Am J Health Promot. 2003;17(3):171-82. OVID-PsycINFO. Exclude: No feedback provided to participants. [pmid: 12545585].
Pearson JA, Burkhart E, Pifalo WB, et al. A lifestyle modification intervention for the treatment of osteoporosis. Am J Health Promot. 2005;20(1):28-33. Hand search. Exclude: Individualized recommendation not provided. [pmid: 16171158].
Perez AP, Phillips MM, Cornell CE, et al. Promoting dietary change among state health employees in Arkansas through a worksite wellness program: the Healthy Employee Lifestyle Program (HELP). Preventing Chronic Disease. 2009;6(4):A123. OVID-Medline. Exclude: No comparison group. [pmid: 19754999].
Persson L-G, Lindstrom K, Lingfors H, et al. Cardiovascular risk during early adult life. Risk markers among participants in ‘Live for Life’ health promotion programme in Sweden. J Epidemiol Community Health. 1998;52(7):425-32. OVID-Embase. Exclude: No comparison group. [pmid: 9799876].
Peterson BA, Klesges RC, Kaufman EM, et al. The effects of an educational intervention on calcium intake and bone mineral content in young women with low calcium intake. Am J Health Promot. 2000;14(3):149-56. Hand search. Exclude: No feedback provided to participants. [pmid: 10787766].
Petrella RJ, Koval JJ, Cunningham DA, et al. Can Primary Care Doctors Prescribe Exercise to Improve Fitness? The Step Test Exercise Prescription (STEP) Project. Am J Prev Med. 2003;24(4):316-22. OVID-PsycINFO. Exclude: Self reported information not provided to participants. [pmid: 12726869].
Phelan EA, Williams B, Leveille S, et al. Outcomes of a community-based dissemination of the health enhancement program. J Am Geriatr Soc. 2002;50(9):1519-24. OVID-Embase. Exclude: No comparison group. [pmid: 12383149].
Pilon BA, Renfroe D. Evaluation of an employee health risk appraisal program. AAOHN J. 1990;38(5):230-5. OVID-Medline. Exclude: No comparison group. [pmid: 2331252].
Pinto BM, Friedman R, Marcus BH, et al. Effects of a computer-based, telephone-counseling system on physical activity. Am J Prev Med. 2002;23(2):113-20. OVID-Embase. Exclude: Self reported information not provided to participants. [pmid: 12121799].
Plotnikoff RC, Pickering MA, McCargar LJ, et al. Six-month follow-up and participant use and satisfaction of an electronic mail intervention promoting physical activity and nutrition. American journal of health promotion : AJHP. 2010;24(4):255-9. UPDATE_OVID_EMBASE. Exclude: No feedback provided to participants. [pmid: 20232607].
Plow MA, Mathiowetz V, Lowe DA. Comparing individualized rehabilitation to a group wellness intervention for persons with multiple sclerosis. Am J Health Promot. 2009;24(1):23-6. Hand search. Exclude: Self reported information not provided to participants. [pmid: 19750959].
Poole K, Kumpfer K, Pett M. The impact of an incentive-based worksite health promotion program on modifiable health risk factors. Am J Health Promot. 2001;16(1):21-6. OVID-PsycINFO. Exclude: No feedback provided to participants. [pmid: 11575052].
Potvin L, Haddad S, Frohlich KL. Beyond process and outcome evaluation: a comprehensive approach for evaluating health promotion programmes. WHO Regional Publications. European(92). 2001:45-62. OVID-Medline. Exclude: Self reported information not provided to participants. [pmid: 11729783].
Powell AJ, Lyons MK, Rumph JW, et al. Health risk appraisal and serum cholesterol nutrition education: an outcome study. Mil Med. 1996;161(2):70-4. OVID-Medline. Exclude: No feedback provided to participants. [pmid: 8857216].
Pratt DS, Jandzio M, Tomlinson D, et al. The 5-10-25 challenge: an observational study of a web-based wellness intervention for a global workforce. Disease Management. 2006;9(5):284-90. OVID-Medline. Exclude: No comparison group. [pmid: 17044762].
Prior JO, van Melle G, Crisinel A, et al. Evaluation of a multicomponent worksite health promotion program for cardiovascular risk factors-correcting for the regression towards the mean effect. Prev Med. 2005;40(3):259-67. OVID-Medline. Exclude: No comparison group. [pmid: 15533537].
Pronk NP, Tan AW, O’Connor P. Obesity, fitness, willingness to communicate and health care costs. Medicine & Science in Sports & Exercise. 1999;31(11):1535-43. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 10589854].
Proper KI, van der Beek AJ, Hildebrandt VH, et al. Worksite health promotion using individual counselling and the effectiveness on sick leave; results of a randomised controlled trial. Occup Environ Med. 2004;61(3):275-9. OVID-Embase. Exclude: Does not report health outcomes. [pmid: 14985524].
Proper KI, Heymans MW, Paw MJMC, et al. Promoting physical activity with people in different places-A Dutch perspective. J Sci Med Sport. 2006;9(5):371-7. OVID-Embase. Exclude: Self reported information not provided to participants. [pmid: 16901753].
Proper KI, de Bruyne MC, Hildebrandt VH, et al. Costs, benefits and effectiveness of worksite physical activity counseling from the employer’s perspective. Scand J Work Environ Health. 2004;30(1):36-46. OVID-EBM-cctr. Exclude: Does not report health outcomes. [pmid: 15018027].
Purath J, Miller AM, McCabe G, et al. A Brief Intervention to Increase Physical Activity in Sedentary Working Women. CJNR: Canadian Journal of Nursing Research. 2004;36(1):76-91. OVID-PsycINFO. Exclude: Self reported information not provided to participants.
Raines JR, Ellis LB. A conversational microcomputer-based health risk appraisal. Comput Programs Biomed. 1982;14(2):175-83. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 7044674].
Rejeski WJ, Ambrosius WT, Brubaker PH, et al. Older adults with chronic disease: Benefits of group-mediated counseling in the promotion of physically active lifestyles. Health Psychol. 2003;22(4):414-23. OVID-Embase. Exclude: No feedback provided to participants. [pmid: 12940398].
Renaud L, Kishchuk N, Juneau M, et al. Implementation and outcomes of a comprehensive worksite health promotion program. Canadian Journal of Public Health. Revue(1). 2008:73-7. OVID-Medline. Exclude: No comparison group. [pmid: 18435397].
Resnicow K, Jackson A, Wang T. A motivational interviewing intervention to increase fruit and vegetable intake through Black churches: results of the Eat for Life trial. Am J Public Health. 2001;91(10):1686-93. CSA-SocialScienceAbstracts. Exclude: No feedback provided to participants. [pmid: 11574336].
Resnicow K, Jackson A, Blissett D, et al. Results of the Healthy Body Healthy Spirit Trial. Health Psychol. 2005;24(4):339-48. OVID-PsycINFO. Exclude: Self reported information not provided to participants. [pmid: 16045368].
Rhodes KV, Lauderdale DS, Stocking CB, et al. Better health while you wait: a controlled trial of a computer-based intervention for screening and health promotion in the emergency department. Ann Emerg Med. 2001;37(3):284-91. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 11223765].
Riebe D, Blissmer B, Greene G, et al. Long-term maintenance of exercise and healthy eating behaviors in overweight adults. Prev Med. 2005;40(6):769-78. OVID-PsycINFO. Exclude: Self reported information not provided to participants. [pmid: 15850878].
Rimmer JH, Rauworth A, Wang E, et al. A randomized controlled trial to increase physical activity and reduce obesity in a predominantly African American group of women with mobility disabilities and severe obesity. Prev Med. 2009;48(5):473-9. OVID-Embase. Exclude: Self reported information not provided to participants. [pmid: 19459233].
Robbins LC, Hall JH. How to practice prospective medicine. Methodist Hospital of Indiana. Indianapolis. 1970. Exclude: Does not report health outcomes.
Robinson D, Allaway S. Health risk appraisal in the UK--some preliminary results. Methods Inf Med. 1998;37(2):143-6. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 9656654].
Robroek SJ, Bredt FJ, Burdorf A. The (cost-)effectiveness of an individually tailored long-term worksite health promotion programme on physical activity and nutrition: design of a pragmatic cluster randomised controlled trial. BMC Public Health. 2007;7:259. OVID-Medline. Exclude: Self reported information not provided to participants. [pmid: 17888161].
Roderick PJ, Brennan PJ, Meade TW. Do risk factors change in men at high risk of coronary heart disease? Observations on the effect of health promotion in primary care. J Cardiovasc Risk. 1995;2(4):353-7. OVID-Embase. Exclude: Does not report health outcomes. [pmid: 8536154].
Rodnick JE, Bubb K. Patient education and multiphasic screening: it can change behavior. J Fam Pract. 1978;6(3):599-607. OVID-Medline. Exclude: Individualized recommendation not provided. [pmid: 632772].
Rodnick JE. Health behavior changes associated with health hazard appraisal counseling in an occupational setting. Prev Med. 1982;11(5):583-94. OVID-Medline. Exclude: Individualized recommendation not provided. [pmid: 7156065].
Rosenkranz RR, Behrens TK, Dzewaltowski DA. A group-randomized controlled trial for health promotion in Girl Scouts: healthier troops in a SNAP (Scouting Nutrition & Activity Program). BMC Public Health. 2010;10:81 U. PDATE_OVID_EMBASE. Exclude: No feedback provided to participants. [pmid: 20170502].
Ruggiero L, Redding CA, Rossi JS, et al. A stage-matched smoking cessation program for pregnant smokers. Am J Health Promot. 1997;12(1):31-3. Hand search. Exclude: Does not report health outcomes. [pmid: 10170432].
Rula EY, Hobgood A. The impact of health risk awareness on employee risk levels. American Journal of Health Behavior. 2010;34(5):532-43. UPDATE_OVID_EMBASE. [pmid: 20524883].
Russell SC, Cutts T, Bailey JE. Consumer evaluation of three online health risk appraisals. Tenn Med. 2008;101(7):43-7. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 18649631].
Ryden LA, Craig MPH, Molgaard CA, et al. Benefits of a back care and light duty health promotion program in a hospital setting. J Community Health. 1988;13(4):222-30. OVID-Embase. Exclude: Individualized recommendation not provided. [pmid: 2976775].
Sackett K, Smith T, D’angelo L, et al. The Medicare health risk assessment program. [Erratum appears in Case Manager 2001 Jul–Aug;12(4):5]. Case Manager. 2000;12(3):52-5. OVID-Medline. Exclude: No feedback provided to participants. [pmid: 11351235].
Sacks JJ, Krushat WM, Newman J. Reliability of the health hazard appraisal. Am J Public Health. 1980;70(7):730-2. OVID-Medline. Exclude: Individualized recommendation not provided. [pmid: 7386712].
Sallis JF, Patrick K, Calfas KJ, et al. A multi-media behavior change program for nutrition and physical activity in primary care: PACE+ for adults. Homeost Health Dis. 1999;39(5):196-202. OVID-PsycINFO. Exclude: Does not report health outcomes.
Salminen M, Isoaho R, Vahlberg T, et al. Effects of a health advocacy, counselling, and activation programme on depressive symptoms in older coronary heart disease patients. Int J Geriatr Psychiatry. 2005;20(6):552-8. OVID-Embase. Exclude: Self reported information not provided to participants. [pmid: 15920714].
Schilling J, Lee CY, Faisst K, et al. Methods of the National Check Bus Project. Soz Praventivmed. 2001;46(3):195-206. OVID-Medline. Exclude: No comparison group. [pmid: 11565449].
Schilling J, Faisst K, Lee CY, et al. The Check Bus Project and its effectiveness on health promotion at work. Journal of Occupational Health. 2005;47(2):136-42. OVID-Medline. Exclude: No comparison group. [pmid: 15824478].
Schoenbach VJ. Appraising health risk appraisal. Am J Public Health. 1987;77:409-11. CSA-SocialScienceAbstracts. Exclude: Does not report health outcomes. [pmid: 3826457].
Schuessler L, Beyer J, Mischler E. Successful weight management in a corporate environment. Disease Management. 2007;10(SUPPL 1S). OVID-Embase.
Schultz AB, Edington DW. Metabolic syndrome in a workplace: prevalence, co-morbidities, and economic impact. Metabolic Syndrome & Related Disorders. 2009;7(5):459-68. OVID-Medline. Exclude: No feedback provided to participants. [pmid: 19450154].
Schwebel DC, McClure LA. Using virtual reality to train children in safe street-crossing skills. Inj Prev. 2010;16(1):e1-e5 U. PDATE_OVID_EMBASE. Exclude: Does not report health outcomes. [pmid: 20179024].
Sciacca J, Seehafer R, Reed R, et al. The impact of participation in health promotion on medical costs: a reconsideration of the Blue Cross and Blue Shield of Indiana study. Am J Health Promot. 1993;7(5):374-83. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 10148713].
Serxner S, Gold D, Anderson D, et al. The impact of a worksite health promotion program on short-term disability usage. Journal of Occupational & Environmental Medicine. 2001;43(1):25-9. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 11201766].
Serxner SA, Gold DB, Grossmeier JJ, et al. The relationship between health promotion program participation and medical costs: a dose response. [Review] [13 refs]. Journal of Occupational & Environmental Medicine. 2003;45(11):1196-200. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 14610401].
Shahar DR, Henkin Y, Rozen GS, et al. A controlled intervention study of changing health-providers’ attitudes toward personal lifestyle habits and health-promotion skills. Nutrition. 2009;25(5):532-9. OVID-Embase. Exclude: No feedback provided to participants. [pmid: 19230614].
Sheehan G. Health-risk appraisals. Physician and Sportsmedicine. 1991;19(5):41 O. VID-Embase. Exclude: Does not report health outcomes.
Sheffer CE, Stitzer M, Payne TJ, et al. Treatment for tobacco dependence for rural, lower-income smokers: outcomes, predictors, and measurement considerations. Am J Health Promot. 2009;23(5):328-38. Hand search. Exclude: No feedback provided to participants. [pmid: 19445436].
Shephard RJ. Long term impact of a fitness programme--the Canada Life Study. [Review] [13 refs]. Ann Acad Med Singapore. 1992;21(1):63-8. OVID-Medline. Exclude: No feedback provided to participants. [pmid: 1590660].
Shephard RJ, Corey P, Renzland P, et al. The impact of changes in fitness and lifestyle upon health care utilization. Canadian Journal of Public Health. 1983;74(1):51-4. OVID-Embase. Exclude: Does not report health outcomes. [pmid: 6406030].
Sherwood NE, Jeffery RW, Welsh EM, et al. The drop it at last study: six-month results of a phone-based weight loss trial. Am J Health Promot. 2010;24(6):378-83. Hand search. Exclude: No feedback provided to participants. [pmid: 20594094].
Shimizu T, Nagashima S, Mizoue T, et al. A psychosocial-approached health promotion program at a Japanese worksite. Journal of Uoeh. 2003;25(1):23-34. OVID-Medline. Exclude: No comparison group. [pmid: 12669625].
Shirazi KK, Wallace LM, Niknami S, et al. A home-based, transtheoretical change model designed strength training intervention to increase exercise to prevent osteoporosis in Iranian women aged 40–65 years: A randomized controlled trial. Health Educ Res. 2007;22(3):305-17. OVID-PsycINFO. Exclude: No feedback provided to participants. [pmid: 16928779].
Shortt AL, Fealy S, Toumbourou JW. The mental health Risk Assessment and Management Process (RAMP) for schools: II. Process evaluation. AeJAMH (Australian e-Journal for the Advancement of Mental Health). 2006;5. (Australian e-Journal for the Advancement of Mental Health):Dec-12 OVID-PsycINFO. Exclude: Self reported information not provided to participants.
Shoveller JA, Langille DB. Cooperation and collaboration between a public health unit and midsized private industry in health promotion programming: the Polymer Heart Health Program experience. Canadian Journal of Public Health. Revue(3). 1993:170-3. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 8358691].
Shovic AC, Harris PR. Nutrition components and assessment procedures of a university employee wellness program: a case study. J Am Diet Assoc. 1991;91(1):79-82. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 1869763].
Simons-Morton DG, Blair SN, King AC, et al. Effects of physical activity counseling in primary care: The Activity Counseling Trial: A randomized controlled trial. JAMA: Journal of the American Medical Association. 2001;286(6):677-87. OVID-PsycINFO. Exclude: Self reported information not provided to participants.
Slawta J, Bentley J, Smith J, et al. Promoting healthy lifestyles in children: A pilot program of be a fit kid. Health Promotion Practice. 1990;9(3):305-12. OVID-PsycINFO. Exclude: Individualized recommendation not provided. [pmid: 16803930].
Sloan RP, Gruman JC. Participation in workplace health promotion programs: the contribution of health and organizational factors. Health Educ Q. 1988;15(3):269-88. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 3192406].
Sorensen G, Morris DM, Hunt MK, et al. Work-site nutrition intervention and employees’ dietary habits: the Treatwell program. Am J Public Health. 1992;82(6):877-80. OVID-Medline. Exclude: No feedback provided to participants. [pmid: 1316722].
Sorensen G, Stoddard A, Hunt MK, et al. The effects of a health promotion-health protection intervention on behavior change: The wellworks study. Am J Public Health. 1998;88(11):1685-90. OVID-Embase. Exclude: No feedback provided to participants. [pmid: 9807537].
Sorensen G, Himmelstein JS, Hunt MK, et al. A model for worksite cancer prevention: integration of health protection and health promotion in the WellWorks Project. Am J Health Promot. 1995;10(1):55-62. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 10155659].
Sorensen G, Hunt MK, Morris DH, et al. Promoting healthy eating patterns in the worksite: The Treatwell intervention model. Health Educ Res. 2000;5(4):505-15. OVID-Embase. Exclude: Does not report health outcomes.
Spilman MA, Goetz A, Schultz J, et al. Effects of a corporate health promotion program. J Occup Med. 1986;28(4):285-9. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 3084731].
Spittaels H, De BI, Brug J, et al. Effectiveness of an online computer-tailored physical activity intervention in a real-life setting. Health Educ Res. 2007;22(3):385-96. OVID-Medline. Exclude: Self reported information not provided to participants. [pmid: 16971674].
Stachnik T, Brown B, Hinds W, et al. Goal setting, social support, and financial incentives in stress management programs: A pilot study of their impact on adherence. Am J Health Promot. 1990;5(1):24-9. OVID-Embase. Exclude: Does not report health outcomes. [pmid: 22188149].
Stange KC, Strecher VJ, Schoenbach VJ, et al. Psychosocial predictors of participation in a work site health-promotion program. J Occup Med. 1991;33(4):479-85. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 2037903].
Steele R, Mummery WK, Dwyer T. Using the Internet to promote physical activity: A randomized trial of intervention delivery modes. Journal of physical activity & health. 2007;4(3):245-60. OVID-PsycINFO. Exclude: Could not be retrieved. [pmid: 17846455].
Stein AD, Shakour SK, Zuidema RA. Financial incentives, participation in employer-sponsored health promotion, and changes in employee health and productivity: HealthPlus Health Quotient Program. Journal of Occupational & Environmental Medicine. 2000;42(12):1148-55. OVID-Medline. Exclude: No comparison group. [pmid: 11125677].
Steptoe A, Kerry S, Rink E. The impact of behavioral counseling on stage of change in fat intake, physical activity, and cigarette smoking in adults at increased risk of coronary heart disease. Am J Public Health. 2001;91(2):265-9. CSA-SocialScienceAbstracts. Exclude: Does not report health outcomes. [pmid: 11211636].
Stevens MM, Olson AL, Gaffney CA, et al. A pediatric, practice-based, randomized trial of drinking and smoking prevention and bicycle helmet, gun, and seatbelt safety promotion. Pediatrics. 2002;109(3):490-7. OVID-Embase. Exclude: Self reported information not provided to participants. [pmid: 11875146].
Stonecipher LJ, Hyner GC. The effects of a comprehensive health risk appraisal, basic screening, and interpretation session on employee health practices: differences between participants and nonparticipants. Am J Health Promot. 1993;7(3):167-9. OVID-Medline. Exclude: Individualized recommendation not provided. [pmid: 10146809].
Stonecipher LJ, Hyner GC. Practitioners forum: the effects of a comprehensive health risk appraisal, basic screening, and interpretation session on employee health practices: Differences between participants and nonparticipants. Am J Health Promot. 1993;7(3):167-9. OVID-Embase. [pmid: 10146809].
Stuck AE, Elkuch P, Dapp U, et al. Feasibility and yield of a self-administered questionnaire for health risk appraisal in older people in three European countries. Age & Ageing. 2002;31(6):463-7. OVID-Medline. Exclude: No comparison group. [pmid: 12446293].
Stuck AE, Kharicha K, Dapp U, et al. Development, feasibility and performance of a health risk appraisal questionnaire for older persons. BMC Medical Research Methodology. 2007;7:1. OVID-Medline. Exclude: No comparison group. [pmid: 17217545].
Sugarman JR, Warren CW, Oge L. Using the Behavioral Risk Factor Surveillance System to monitor Year 2000 objectives among American Indians. Public Health Rep. 1992;107:449-56. CSA-SocialScienceAbstracts. Exclude: No feedback provided to participants. [pmid: 1641442].
Suggs LS, McIntyre C. Are we there yet? An examination of online tailored health communication. Health Education & Behavior. 2009;36(2):278-88. OVID-Medline. Exclude: Self reported information not provided to participants. [pmid: 17620667].
Suggs LS, McIntyre C. Are we there yet? An examination of online tailored health communication. Health Education & Behavior. 2000;36(2):278-88. OVID-PsycINFO. Exclude: Does not report health outcomes. [pmid: 17620667].
Suka M, Yoshida K. Health Risk Appraisal using Internet technology. Methods Inf Med. 2005;44(2):310-4. OVID-Medline. Exclude: No comparison group. [pmid: 15924198].
Tennant GP, Sperry L. Work-Family Balance: Counseling Strategies to Optimize Health. The Family Journal. 2003;11(4):404-8. OVID-PsycINFO. Exclude: Does not report health outcomes.
Tershakovec AM, Shannon BM, Achterberg CL. One-year follow-up of nutrition education for hypercholesterolemic children. Am J Public Health. 1998;88(2):258-61. CSA-SocialScienceAbstracts. Exclude: No feedback provided to participants. [pmid: 9491017].
Thompson BL, Nelson DE, Caldwell B, et al. Assessment of health risk behaviors. A tool to inform consumers, providers, health care organizations, and purchasers. Am J Prev Med. 1999;16(1):48-59. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 9894556].
Tilley BC, Vernon SW, Glanz K, et al. Worksite cancer screening and nutrition intervention for high-risk auto workers: design and baseline findings of the Next Step Trial. Prev Med. 1997;26(2):227-35. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 9085392].
Tucker LA, Cook AJ, Nokes NR, et al. Telephone-based diet and exercise coaching and a weight-loss supplement result in weight and fat loss in 120 men and women. Am J Health Promot. 2008;23(2):121-9. Hand search. Exclude: Self reported information not provided to participants. [pmid: 19004162].
Uskul AK, Oyserman D. When message-frame fits salient cultural-frame, messages feel more persuasive. Psychology and Health. 2010;25(3):321-37. UPDATE_OVID_EMBASE. Exclude: Does not report health outcomes. [pmid: 20204971].
van Ryn M, Lytle LA, Kirscht JP. A test of the theory of planned behavior for two health-related practices. Journal of Applied Social Psychology. 1996;26(10):871-83. OVID-PsycINFO. Exclude: Individualized recommendation not provided.
Vinberg S. Workplace health interventions in small enterprises: A Swedish longitudinal study. Work. 2008;30(4):473-82. OVID-Embase. Exclude: Does not report health outcomes. [pmid: 18725710].
Wakai K, Naito M, Naito T, et al. Longitudinal Evaluation of Multi-phasic, Odontological and Nutritional Associations in Dentists (LEMONADE Study): study design and profile of nationwide cohort participants at baseline. J Epidemiol. 2009;19(2):72-80. OVID-Medline. Exclude: No feedback provided to participants. [pmid: 19265274].
Walker Z, Townsend J, Oakley L, et al. Health promotion for adolescents in primary care: Randomised controlled trial. Br Med J. 2002;325(7363):524-7. OVID-Embase. Exclude: No feedback provided to participants. [pmid: 12217993].
Wall M, Hayes R, Moore D, et al. Evaluation of community level interventions to address social and structural determinants of health: A cluster randomised controlled trial. BMC Public Health. 2009;9:2009. Article Number: 207. Date of Publication: 2009.: OVID-Embase. Exclude: Does not report health outcomes.
Walton C, Timms J. Providing worksite health promotion through university-community partnerships. The South Carolina DOT project. AAOHN J. 1999;47(10):449-55. OVID-Medline. Exclude: No comparison group. [pmid: 10818824].
Wan Q, Harris MF, Zwar N, et al. Prerequisites for implementing cardiovascular absolute risk assessment in general practice: A qualitative study of Australian general practitioners’ and patients’ views. J Eval Clin Pract. 2010;16(3):580-4. UPDATE_OVID_EMBASE. Exclude: Does not report health outcomes. [pmid: 20438609].
Watkins SA, Hoffman A, Burrows R, et al. Colorectal cancer and cardiac risk reduction using computer-assisted dietary counseling in a low-income minority population. J Natl Med Assoc. 1994;86(12):909-14. OVID-PsycINFO. Exclude: No comparison group. [pmid: 7861469].
Wear RF Jr. The campbell Soup Company program. Prev Med. 1983;12(5):667-71. OVID-Medline. Exclude: Individualized recommendation not provided. [pmid: 6657632].
Wellman NS, Kamp B, Kirk-Sanchez NJ, et al. Eat better and move more: A community-based program designed to improve diets and increase physical activity among older Americans. Am J Public Health. 2007;97(4):710-7. OVID-PsycINFO. Exclude: No feedback provided to participants. [pmid: 17329647].
Welty TK, Zephier N, Schweigman K, et al. Cancer risk factors in three Sioux tribes. Use of the Indian-specific health risk appraisal for data collection and analysis. Alaska Med. 1993;35(4):265-72. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 8160919].
Werch CE, Schroeder DA, Matthews LL. The health fair as a health promotion strategy: Effects on health risk behaviors and the utility of specific health fair activities. J Am Coll Health. 1986;35(2):74-9. OVID-PsycINFO. Exclude: Could not be retrieved. [pmid: 3771942].
Werkman A, Schuit AJ, Kwak L, et al. Study protocol of a cluster randomised controlled trial investigating the effectiveness of a tailored energy balance programme for recent retirees. BMC Public Health. 2006;6:293. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 17147832].
Wiesemann A, Metz J, Nuessel E, et al. Four years of practice-based and exercise-supported behavioural medicine in one community of the German CINDI area. Int J Sports Med. 1997;18(4):308-15. OVID-Embase. Exclude: Self reported information not provided to participants. [pmid: 9231850].
Wilbur CS. The Johnson & Johnson program. Prev Med. 1983;12(5):672-81. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 6657633].
Williams A, Mason A, Wold J. Cultural sensitivity and day care workers. Examination of a worksite based cardiovascular disease prevention project. AAOHN J. 2001;49(1):35-43. OVID-Medline. Exclude: No comparison group. [pmid: 11760276].
Williams A, Wold J, Dunkin J, et al. CVD prevention strategies with urban and rural African American women. Appl Nurs Res. 2004;17(3):187-94. OVID-Medline. Exclude: No comparison group. [pmid: 15343552].
Winter C, Ahrendt L, Clarke J, et al. Tobacco use among South Dakotans. South Dakota Medicine: The Journal of the South Dakota State Medical Association. 2009;(Spec:No-22). OVID-Medline. Exclude: No feedback provided to participants. [pmid: 19363889].
Wittmann A. Body composition in an employee health improvement program. Coll Antropol. 1998;22(2):447-50. OVID-Medline. Exclude: No comparison group. [pmid: 9887600].
Wold JL, Williams AM. Student/faculty practice and research in occupational health: Health promotion and outcome evaluation. AAOHN J. 1997;45(2):76-82. OVID-Embase. Exclude: Does not report health outcomes. [pmid: 9146107].
Wolf RL, Lepore SJ, Vandergrift JL, et al. Tailored telephone education to promote awareness and adoption of fruit and vegetable recommendations among urban and mostly immigrant black men: A randomized controlled trial. Prev Med. 2009;48(1):32-8. OVID-Embase. Exclude: Self reported information not provided to participants. [pmid: 19010349].
Wolf TM, Randall HM, Faucett JM. A health promotion program for medical students: Louisiana State University Medical Center. Am J Health Promot. 1990;4(3):193-202. OVID-Embase. Exclude: Does not report health outcomes. [pmid: 22204465].
Woolf SH, Glasgow RE, Krist A, et al. Putting it together: finding success in behavior change through integration of services. Ann Fam Med. 2005;3. Suppl-7. OVID-Medline. Exclude: Self reported information not provided to participants. [pmid: 16049077].
Woolf SH, Krist AH, Johnson RE, et al. A Practice-Sponsored Web Site to Help Patients Pursue Healthy Behaviors: An ACORN Study. Ann Fam Med. 2006;4(2):148-52. OVID-PsycINFO. Exclude: Self reported information not provided to participants. [pmid: 16569718].
Xiangyang T, Lan Z, Xueping M, et al. Beijing health promoting universities: Practice and evaluation. Health Promotion International. 2003;18(2):107-13. OVID-Embase. Exclude: Self reported information not provided to participants. [pmid: 12746382].
Yap TL, Davis LS, Gates DM, et al. The effect of tailored e-mails in the workplace. Part II. Increasing overall physical activity. AAOHN J. 2009;57(8):313-9. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 19650604].
Yoo J, Slack KS, Holl JL. The impact of health-promoting behaviors on low-income children’s health: a risk and resilience perspective. Health & Social Work. 2010;35(2):133-43. UPDATE_OVID_EMBASE. Exclude: No feedback provided to participants. [pmid: 20506867].
Yoshida K, Okazaki N, Hinohara S, et al. Health-risk appraisal applied to ordinary AMHTS. Methods Inf Med. 1993;32(3):260-3. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 8341164].
Zimmerman EM, Horton-La Forge B. Detection and prevention of cardiac risk factors: health risk assessment and targeted follow-up in a managed care population. J Cardiovasc Nurs. 1996;11(1):27-38. OVID-Medline. Exclude: Does not report health outcomes. [pmid: 9069029].