# Screening Forms

QUALITY SCORE FOR JADAD SCALE AND FOR MODIFIED JADAD SCALE

Newcastle-Ottawa Scale (NOS)

Screening Questions for HRA