# Search Terms

## Detailed Search Strategies

OVID-Medline

June 15 2010

1. health risk assessment?.tw.
2. health risk appraisal?.tw.
3. health hazard appraisal?.tw.
4. (health adj3 assessment? adj15 (feedback or counsel* or personal* or individual or individualized or self report* or tailor*)).tw.
5. (feedback or counsel* or personal* or individual or individualized or self report* or tailor*).tw.
6. ((assessment? or appraisal?) adj4 health risk?).tw.
7. 5 and 6
8. *Health Promotion/
9. *Work/
10. *Workplace/
11. *Occupational Health/
12. *Occupational Health Services/
13. or/9–12
14. 8 and 13
15. (feedback or counsel* or personal* or individual or individualized or tailor* or self report).tw.
16. 14 and 15
17. (comprehensive adj9 health promotion).tw.
18. 16 or 17
19. 1 or 2 or 3 or 4 or 7
20. 18 or 19
21. limit 20 to english language
22. limit 21 to (comment or editorial or letter)
23. 21 not 22

OVID-Embase

June 15 2010

1. health risk assessment?.tw.
2. health risk appraisal?.tw.
3. health hazard appraisal?.tw.
4. (health adj3 assessment? adj15 (feedback or counsel* or personal* or individual or individualized or self report* or tailor* or consultation?)).tw.
5. (feedback or counsel* or personal* or individual or individualized or tailor* or self report or consultation?).tw.
6. ((assessment? or appraisal?) adj4 health risk?).tw.
7. 5 and 6
8. 1 or 2 or 3 or 4 or 7
9. (employee and health program).tw.
10. *Health Promotion/
11. *risk assessment/
12. 10 and 11
13. health risk intervention.tw.
14. (work* and health intervention).tw.
15. (comprehensive adj9 health promotion).tw.
16. occupational health service/
17. 10 and 16
18. (feedback or counsel* or personal* or individual or individualized or tailor* or self report or consultation?).tw.
19. 10 and 18
20. 11 and 18
21. 8 or 9 or 12 or 13 or 14 or 15 or 17 or 19 or 20
22. limit 21 to english language
23. limit 22 to human
24. limit 23 to (book or book series or editorial or letter or note)
25. 23 not 24

OVID-Cochrane Controlled Trials Registry

June 15 2010

1. health risk assessment?.tw.
2. health risk appraisal?.tw.
3. health hazard appraisal?.tw.
4. (health adj3 assessment? adj15 (feedback or counsel* or personal* or individual or individualized or self report* or tailor*)).tw.
5. (feedback or counsel* or personal* or individual or individualized or self report* or tailor*).tw.
6. ((assessment? or appraisal?) adj4 health risk?).tw.
7. 5 and 6
8. *Health Promotion/
9. *Work/
10. *Workplace/
11. *Occupational Health/
12. *Occupational Health Services/
13. or/9–12
14. 8 and 13
15. (feedback or counsel* or personal* or individual or individualized or tailor* or self report).tw.
16. 14 and 15
17. (comprehensive adj9 health promotion).tw.
18. 16 or 17
19. 1 or 2 or 3 or 4 or 7
20. 18 or 19

OVID-PsycINFO

June 15 2010

1. health risk assessment?.tw.
2. health risk appraisal?.tw.
3. health hazard appraisal?.tw.
4. (health adj3 assessment? adj15 (feedback or counsel* or personal* or individual or individualized or self report* or tailor*)).tw.
5. (feedback or counsel* or personal* or individual or individualized or self report* or tailor*).tw.
6. ((assessment? or appraisal?) adj4 health risk?).tw.
7. 5 and 6
8. *Health Promotion/
9. *Occupational Health/
10. professional consultation/
11. *risk assessment/ or *risk management/
12. (feedback or counsel* or personalized or individualized or self report* or tailor*).tw.
13. or/9–12
14. 8 and 13
15. (comprehensive adj9 health promotion).tw.
16. "health risk appraisals".id.
17. 1 or 2 or 3 or 4 or 7 or 14 or 15 or 16
18. limit 17 to english language
19. limit 18 to (("0200 book" or "0240 authored book" or "0280 edited book" or "0300 encyclopedia" or "0400 dissertation abstract") and (chapter or "column/opinion" or "comment/reply" or dissertation or editorial or encyclopedia entry or letter or review-book))
20. 18 not 19

Cambridge Scientific Abstracts-Social Science Abstracts

June 15 2010

Last Search Query: ((health risk assessment*) or (health risk appraisal*) or (health hazard appraisal*)) or((health promotion) and (feedback or tailored or personalized)) or((health promotion) and (counsel* or individualized or (self report*))) or((health promotion) and (counsel* or individualized or (self report*))) or((health promotion) and (feedback or personalized or tailored)) or((health promotion) and personalised) or((health promotion) and comprehensive)