# List of Abbreviations

AB: aminobiphenyl
AC: adenylyl cyclase
ACH: air changes per hour
ACS: American Cancer Society
ADA: Americans with Disabilities Act of 1990
AHA: American Heart Association
AHU: air handling unit
ALA: American Lung Association
ALL: acute lymphocytic leukemia
ALSPAC: Avon Longitudinal Study of Pregnancy and Childhood
AMA: American Medical Association
ANR: American Nonsmokers’ Rights
AOD: airway obstructive disease
AOM: acute otitis media
AOR: adjusted odds ratio
ARB: Air Resources Board
ARIC: Atherosclerosis Risk in Communities
ASHRAE: American Society of Heating, Refrigerating and Air-Conditioning Engineers
ASSIST: American Stop Smoking Intervention Study for Cancer Prevention
ATP: adenosine triphosphate
BALF: bronchoalveolar lavage fluid
B[ a ]P: benzo[a]pyrene
BAS: building automation system
BHR: bronchial hyperreactivity
BL: bronchiolitis
BMI: body mass index
BR: bronchitis
BRFSS: Behavioral Risk Factor Surveillance System
BSID: Bayley Scales of Infant Development
Ca: calcium
CAB: Civil Aeronautics Board
Cal/EPA: California Environmental Protection Agency
CAT: California Achievement Test
C/Co: concentration of contaminant
Cd: cadmium
CDC: Centers for Disease Control and Prevention
CFD: computational fluid dynamics
CHD: coronary heart disease
CI: confidence interval
CIN: cervical intraepithelial neoplasia
cm: centimeter
cm^3^: cubic centimeter
CNS: central nervous system
CO: carbon monoxide
CO 2: carbon dioxide
COMMIT: Community Intervention Trial for Smoking Cessation
COPD: chronic obstructive pulmonary disease
CPS: Current Population Survey
CPS-I: Cancer Prevention Study I
CPS-II: Cancer Prevention Study II
CT: computed tomography
df: degrees of freedom
EC: European Communities
EEFR: end-expiratory flow rate
EIA: enzyme-linked immunoassay
ELISA: Enzyme-Linked ImmunoSorbent Assay
ENT: ear, nose, and throat
ENU: ethylnitrosourea
EP: ethenyl pyridine
EPA: Environmental Protection Agency
ETS: environmental tobacco smoke
FAA: Federal Aviation Administration
FEF: forced expiratory flow
FEFR: forced expiratory flow rate
FEV_1_: forced expiratory volume in one second
fmol: femtomole
FPM: fluorescing particulate matter
FRC: functional residual capacity
ft^2^: square feet
ft^3^: cubic feet
FVC: forced vital capacity
g: gram
GASP: Group Against Smoking Pollution
GC–MS: gas chromatography–mass spectrometry
GLC: gas-liquid chromatography
Gluc: glucuronide
GM-CSF: granulocyte-macrophage colony-stimulating factor
GSTM1: glutathione S-transferase form M1
Hb: hemoglobin
HCFA: Health Care Financing Administration
HDL: high-density lipoprotein
HEPA: high-efficiency particulate air
hMG: human menopausal gonadotropin
1-HOP: 1-hydroxypyrene
HPB: 4-hydroxy-1-(3-pyridyl)-1-butanone
HPLC: high-performance liquid chromatography
HVAC: heating, ventilating, and air-conditioning
IARC: International Agency for Research on Cancer
IBD: inflammatory bowel disease
ICC: Interstate Commerce Commission
ICD: International Classification of Diseases
IFN-γ: interferon gamma
IgE: immunoglobulin E
IgG1: immunoglobulin G1
IHD: ischemic heart disease
IL: interleukin
IMT: intimal medial thickness
ISAAC: International Study of Asthma and Allergy in Childhood
IU: International Units
IUGR: intrauterine growth retardation
JCAHO: Joint Commission on Accreditation of Healthcare Organizations
JPHC: Japan Public Health Center
L: liter
LBW: low birth weight
LC: liquid chromatography
LD: less than detectable
LDL: low-density lipoprotein
LPS: lipopolysaccharide
LRI: lower respiratory illness
L/S: lectin/sphyngomyelin
m^2^: square meter
m^3^: cubic meter
MAPK: mitogen-activated protein kinase
MDI: Mental Development Index
MEE: middle ear effusion
MEFR: mid-expiratory flow rate
MeSH: Medical Subject Headings
mg: milligram
MI: myocardial infarction
mL: milliliter
MMEF: mean mid-expiratory flow
MRC: Medical Research Council
MRI: magnetic resonance imaging
MSCA: McCarthy Scales of Children’s Abilities
MTA: Metropolitan Transportation Authority
μ: micron
μg: microgram
μL: microliter
μm: micrometer
μmol: micromole
nAChR: nicotinic acetylcholine receptor
NAT: N-acetyltransferase
NCHS: National Center for Health Statistics
NCI: National Cancer Institute
ng: nanogram
NHANES: National Health and Nutrition Examination Survey
NHAPS: National Human Activity Pattern Survey
NHIS: National Health Interview Survey
NHMRC: National Health and Medical Research Council
NHS: Nurses Health Study
NIH: National Institutes of Health
NIOSH: National Institute for Occupational Safety and Health
NMFS: National Mortality Followback Survey
NNAL: 4-(methylnitrosamino)-1-(3-pyridyl)-1-butanol
NNAL-Gluc: glucuronide conjugate of NNAL
NNK: 4-(methylnitrosamino)-1-(3-pyridyl)-1-butanone
NNN: N′-nitrosonornicotine
NO: nitric oxide
NOS: nitric oxide synthase
NPC: nasopharyngeal carcinoma
NPD: nitrogen-phosphorus specific detector
NR: data were not reported
NRC: National Research Council
NS: not significant
NTS: nucleus tractus solitarius
O_3_: ozone
8-OH-dG: 8-hydroxydeoxyguanosine
OM: otitis media
OME: otitis media with effusion
OPPS: Ottawa Prenatal Prospective Study
OR: odds ratio
OSH: Office on Smoking and Health
OSHA: Occupational Safety and Health Administration
OVA: ovalbumen
PAF-AH: platelet-activating factor acetylhydrolase
PAH: polycyclic aromatic hydrocarbon
PEF: peak expiratory flow
PFT: pulmonary function test
pg: picogram
PIF: peak inspiratory flow
PK-C: protein kinase C
PM: particulate matter
PMA: phorbol 12-myristate 13-acetate
pmol: picomole
PMN: polymorphonuclear leukocyte
PN: pneumonia
POR: prevalence odds ratio
ppb: parts per billion
ppm: parts per million
PPVT: Peabody Picture Vocabulary Test
RAST: Radioallergosorbent Test
RAVEN: Raven Colored Progressive Matrices Test
RDD: random-digit telephone dialing
RIA: radioimmunoassay
ROM: recurrent otitis media
RPM: respirable particulate matter
RR: relative risk
RSP: respirable suspended particles
RSV: respiratory syncytial virus
SCAN: central auditory processing task
SCI: silent cerebral infarction
SD: standard deviation
SEER: Surveillance, Epidemiology, and End Results
SES: socioeconomic status
SGA: small for gestational age
sGaw: specific airway conductance
sGaw_EE_: specific airway conductance at end expiration
SHEEP: Stockholm Heart Epidemiology Program
SHPPS: School Health Policies and Programs Study
SIDRIA: Italian Studies on Respiratory Disorders in Childhood and the Environment
SIDS: sudden infant death syndrome
s/kPa: kilopascal
SO_2_: sulfur dioxide
SolPM: solanesol particulate matter
SPT: skin-prick test
^99m^Tc-DTPA: technetium^99m^ labeled diethylenetriamine penta-acetate
TEA: thermal energy analyzer
Th: T-helper
TIA: transient ischemic attack
TNF: tumor necrosis factor
T_PTEF_:T_E_: the ratio of time to peak tidal expiratory flow to expiratory time
TSNA: tobacco-specific nitrosamine
tt-MA: trans,trans-muconic acid
URI: upper respiratory illness
USDHEW: U.S. Department of Health, Education, and Welfare
USDHHS: U.S. Department of Health and Human Services
USDOC: U.S. Department of Commerce
USDOD: U.S. Department of Defense
USDOJ: U.S. Department of Justice
USVA: U.S. Department of Veteran Affairs
UV: ultraviolet
UVPM: ultraviolet-absorbing particulate matter
Vmax_FRC_: maximal forced expiratory flow at functional residual capacity
VOCs: volatile organic compounds
WHO: World Health Organization
WISC: Weschler Intelligence Scale for Children