# Appendix

Publication lags, even short ones, prevent an up to-the-minute inclusion of all recently published articles and data. Therefore, by the time the public reads this report, there may be additional published studies or data. To provide published information as current as possible, this Appendix lists more recent studies that represent major additions to the literature.

## Chapter 2 Toxicology of Secondhand Smoke

Bradley TP, Golden AL. Tobacco and carcinogens in the workplace. Clinics in Occupational and Environmental Medicine 2006:5(1):117–37.

Hecht SS. Carcinogenicity studies of inhaled cigarette smoke in laboratory animals: old and new. Carcinogenesis 2005;26(9):1488–92.

Hecht SS, Carmella SG, Le K-A, Murphy SE, Boettcher AJ, Le C, Koopmeiners J, An L, Hennrikus DJ. 4-(Methylnitrosamino)-1-(3-pyridyl)-1-butanol and its glucuronides in the urine of infants exposed to environmental tobacco smoke. Cancer Epidemiology, Biomarkers & Prevention 2006;15(5):988–92.

Houston TK, Person SD, Pletcher MJ, Liu K, Iribarren C, Kiefe CI. Active and passive smoking and development of glucose intolerance among young adults in a prospective cohort: CARDIA study. British Medical Journal 2006; doi:10.1136/bmj.38779.584028.55.

Husgafvel-Pursiainen K. Genotoxicity of environmental tobacco smoke: a review. Mutation Research 2004;567(2–3):427–45.

Neff RA, Simmens SJ, Evans C, Mendelowitz D. Prenatal nicotine exposure alters central cardiorespiratory responses to hypoxia in rats: implications for sudden infant death syndrome. Journal of Neuroscience 2004;24(42):9261–8.

Slikker W Jr, Xu ZA, Levin ED, Slotkin TA. Mode of action: disruption of brain cell replication, second messenger, and neurotransmitter systems during development leading to congnitive dysfunction—developmental neurotoxicity of nicotine. Critical Reviews in Toxicology 2005;35(8–9):703–11.

van der Vaart H, Postma DS, Timens W, Hylkema MN, Willemse BWM, Boezen HM, Vonk JM, de Reus DM, Kauffman HF, ten Hacken NHT. Acute effects of cigarette smoking on inflammation in healthy intermittent smokers. Respiratory Research 2005;6(1):22.

Wang Y, Zhang Z, Lubet R, You M. Tobacco smoke-induced lung tumorigenesis in mutant A/J mice with alterations in K-ras, p53, or Ink4a/Arf. Oncogene 2005;24(18):3042–9.

## Chapter 3 Assessment of Exposure to Secondhand Smoke

Centers for Disease Control and Prevention. Indoor air quality in hospitality venues before and after implementation of a clean indoor air law—Western New York, 2003. Morbidity and Mortality Weekly Report 2004;53(44):1038–41.

Murphy SE, Link CA, Jensen J, Le C, Puumala SS, Hecht SS, Carmella SG, Losey L, Hatsukami DK. A comparison of urinary biomarkers of tobacco and carcinogen exposure in smokers. Cancer Epidemiology, Biomarkers & Prevention 2004;13(10):1617–23.

Repace J, Al-Delaimy WK, Bernert JT. Correlating atmospheric and biological markers in studies of secondhand tobacco smoke exposure and dose in children and adults. Journal of Occupational and Environmental Medicine 2006;48(2):181–94.

## Chapter 4 Prevalence of Exposure to Secondhand Smoke

Blackburn CM, Bonas S, Spencer NJ, Coe CJ, Dolan A, Moy R. Parental smoking and passive smoking in infants: fathers matter too. Health Education Research 2005;20(2):185–94.

Panagiotakos DB, Pitsavos C, Chrysohoou C, Skoumas J, Masoura C, Toutouzas P, Stefanadis C. Effect of exposure to secondhand smoke on markers of inflammation: the ATTICA study. American Journal of Medicine 2004;116(3):145–50.

## Chapter 5 Reproductive and Developmental Effects from Exposure to Secondhand Smoke

Kharrazi M, DeLorenze GN, Kaufman FL, Eskenazi B, Bernert JT Jr, Graham S, Pearl M, Pirkle J. Environmental tobacco smoke and pregnancy outcome. Epidemiology 2004;15(6):660–70.

McMartin KI, Platt MS, Hackman R, Klein J, Smialek JE, Vigorito R, Koren G. Lung tissue concentrations of nicotine in sudden infant death syndrome (SIDS). Journal of Pediatrics 2002;140(2):205–9.

Slotkin TA. Cholinergic systems in brain development and disruption by neurotoxicants: nicotine, environmental tobacco smoke, organophosphates. Toxicology and Applied Pharmacology 2004;198(2):132–51.

Wisborg K, Kesmodel U, Henriksen TB, Olsen SF, Secher NJ. Exposure to tobacco smoke in utero and the risk of stillbirth and death in the first year of life. American Journal of Epidemiology 2001;154(4):322–7.

## Chapter 6 Respiratory Effects in Children from Exposure to Secondhand Smoke

Alati R, Al Mamun A, O’Callaghan M, Najman JM, Williams GM. In utero and postnatal maternal smoking and asthma in adolescence. Epidemiology 2006;17(2):138–44.

DiFranza JR, Aligne CA. Weitzman M. Prenatal and postnatal environmental tobacco smoke exposure and children’s health. Pediatrics 2004;113 (4 Suppl):1007–15.

Gilliland FD, Berhane K, Li Y-F, Rappaport EB, Peters JM. Effects of early onset asthma and in utero exposure to maternal smoking on childhood lung function. American Journal of Respiratory and Critical Care Medicine 2003;167(6):917–24.

Gilliland FD, Li Y-F, Dubeau L, Berhane K, Avol E, McConnell R, Gauderman WJ, Peters JM. Effects of glutathione S-transferase M1, maternal smoking during pregnancy, and environmental tobacco smoke on asthma and wheezing in children. American Journal of Respiratory and Critical Care Medicine 2002;166(4):457–63.

Gilliland FD, Li Y-F, Peters JM. Effects of maternal smoking during pregnancy and environmental tobacco smoke on asthma and wheezing in children. American Journal of Respiratory and Critical Care Medicine 2001;163(2):429–36.

Gilmour MI, Jaakkola MS, London SJ, Nel AE, Rogers CA. How exposure to environmental tobacco smoke, outdoor air pollutants, and increased pollen burdens influences the incidence of asthma. Environmental Health Perspectives 2006;114(4): 627–33.

Jaakkola JJK, Nafstad P, Magnus P. Environmental tobacco smoke, parental atopy, and childhood asthma. Environmental Health Perspectives 2001;109(6):579–82.

Jaakkola MS, Piipari R, Jaakkola N, Jaakkola JJK. Environmental tobacco smoke and adult-onset asthma: a population-based incident case-control study. American Journal of Public Health 2003;93(12): 2055–60.

Lannerö E, Wickman M, Pershagen G, Nordvall L. Maternal smoking during pregnancy increases the risk of recurrent wheezing during the first years of life (BAMSE). Respiratory Research 2006;7(1):3.

Mannino DM, Moorman JE, Kingsley B, Rose D, Repace J. Health effects related to environmental tobacco smoke exposure in children in the United States: data from the Third National Health and Nutrition Examination Survey. Archives of Pediatrics and Adolescent Medicine 2001;155(1):36–41.

Moshammer H, Hoek G, Luttmann-Gibson H, Neuberger MA, Antova T, Gehring U, Hruba F, Pattenden S, Rudnai P, Slachtova H, et al. Parental smoking and lung function in children: an international study. American Journal of Respiratory and Critical Care Medicine 2006; doi:10.1164/rccm.200510-1552OC.

Zlotkowska R, Zejda JE. Fetal and postnatal exposure to tobacco smoke and respiratory health in children. European Journal of Epidemiology 2005;20(8):719–27.

## Chapter 7 Cancer Among Adults from Exposure to Secondhand Smoke

Anderson KE, Carmella SG, Ye M, Bliss RL, Le C, Murphy L, Hecht SS. Metabolites of a tobacco-specific lung carcinogen in nonsmoking women exposed to environmental tobacco smoke. Journal of the National Cancer Institute 2001;93(5):378–81.

Brennan P, Buffler PA, Reynolds P, Wu AH, Wichmann HE, Agudo A, Pershagen G, Jöckel K-H, Benhamou S, Greenberg RS, et al. Secondhand smoke exposure in adulthood and risk of lung cancer among never smokers: a pooled analysis of two large studies. International Journal of Cancer 2004;109(1):125–31.

Brownson RC, Figgs LW, Caisley LE. Epidemiology of environmental tobacco smoke exposure. Oncogene 2002;21(48):7341–8.

deAndrade M, Ebbert JO, Wampfler JA, Miller DL, Marks RS, Croghan GA, Jatoi A, Finke EE, Sellers TA, Yang P. Environmental tobacco exposure in women with lung cancer. Lung Cancer 2004;43(2):127–34.

Enstrom JE, Kabat GC. Environmental tobacco smoke and tobacco related mortality in a prospective study of Californians, 1960–98. British Medical Journal 2003;326(7398):1057.

Kreuzer M, Gerken M, Kreienbrock L, Wellmann J, Wichmann HE. Lung cancer in lifetime nonsmoking men—results of a case-control study in Germany. British Journal of Cancer 2001;84(1):134–40.

Vineis P, Airoldi L, Veglia F, Olgiati L, Pastorelli R, Autrup H, Dunning A, Garte S, Gormally E, Hainaut P, et al. Environmental tobacco smoke and risk of respiratory cancer and chronic obstructive pulmonary disease in former smokers and never smokers in the EPIC prospective study. British Medical Journal 2005;330(7486):277.

## Chapter 8 Cardiovascular Diseases from Exposure to Secondhand Smoke

Hill S, Blakely T, Kawachi I, Woodward A. Mortality among never smokers living with smokers: two cohort studies, 1981–4 and 1996–9. British Medical Journal 2004;328(7446);988–9.

Iribarren C, Darbinian J, Klatsky AL, Friedman GD. Cohort study of exposure to environmental tobacco smoke and risk of first ischemic stroke and transient ischemic attack. Neuroepidemiology 2004;23 (1–2):38–44.

Kamholz SL. Pulmonary and cardiovascular consequences of smoking. Clinics in Occupational and Environmental Medicine 2006;5(1):157–71.

Kaur S, Cohen A, Dolor R, Coffman CJ, Bastian BA. The impact of environmental tobacco smoke on women’s risk of dying from heart disease: a meta-analysis. Journal of Women’s Health 2004;13(8): 888–97.

Kiechl S, Werner P, Egger G, Oberhollenzer F, Mayr M, Xu Q, Poewe W, Willeit J. Active and passive smoking, chronic infections, and the risk of carotid atherosclerosis: prospective results from the Bruneck Study. Stroke 2002;33(9):2170–6.

McGhee SM, Ho SY, Schooling M, Ho LM, Thomas GN, Hedley AJ, Mak KH, Peto R, Lam TH. Mortality associated with passive smoking in Hong Kong. British Medical Journal 2005;330(7486):287–8.

Qureshi AI, Suri MF, Kirmani JF, Divani AA. Cigarette smoking among spouses: another risk factor for stroke in women. Stroke 2005;36(9):e74–e76.

Whincup PH, Gilg JA, Emberson JR, Jarvis MJ, Feyerabend C, Bryant A, Walker M, Cook DG. Passive smoking and risk of coronary heart disease and stroke: prospective study with cotinine measurement. British Medical Journal 2004;329(7459):200–5.

Zhang X, Shu XO, Yang G, Li HL, Xiang YB, Gao Y-T, Li Q, Zheng W. Association of passive smoking by husbands with prevalence of stroke among Chinese women nonsmokers. American Journal of Epidemiology 2005;161(3):213–8.

## Chapter 9 Respiratory Effects in Adults from Exposure to Secondhand Smoke

Dhala A, Pinsker K, Prezant DJ. Respiratory health consequences of environmental tobacco smoke. Clinics in Occupational and Environmental Medicine 2006;5(1):139–56.

Eisner MD. Environmental tobacco smoke exposure and pulmonary function among adults in NHANES III: impact on the general population and adults with current asthma. Environmental Health Perspectives 2002;110(8):765–70.

Eisner MD, Klein J, Hammond SK, Koren G, Lactao G, Iribarren C. Directly measured second hand smoke exposure and asthma health outcomes. Thorax 2005;60(10):814–21.

Gilmour MI, Jaakkola MS, London SJ, Nel AE, Rogers CA. How exposure to environmental tobacco smoke, outdoor air pollutants, and increased pollen burdens influences the incidence of asthma. Environmental Health Perspectives 2006;114(4):627–33.

Jaakkola MS, Piipari R, Jaakkola N, Jaakkola JJK. Environmental tobacco smoke and adult-onset asthma: a population-based incident case-control study. American Journal of Public Health 2003;93(12): 2055–60.

Maziak W, Ward KD, Rastam S, Mzayek F, Eissenberg T. Extent of exposure to environmental tobacco smoke (ETS) and its dose-response relation to respiratory health among adults. Respiratory Research 2005;6(1):13.

Skorge TD, Eagan TML, Eide GE, Gulsvik A, Bakke PS. The adult incidence of asthma and respiratory symptoms by passive smoking in utero or in childhood. American Journal of Respiratory and Critical Care Medicine 2005;172(1):61–6.

Svanes C, Omenaas E, Jarvis D, Chinn S, Gulsvik A, Burney P. Parental smoking in childhood and adult obstructive lung disease: results from the European Community Respiratory Health Survey. Thorax 2004;59(4):295–302.

Upton MN, Smith GD, McConnachie A, Hart CL, Watt GC. Maternal and personal cigarette smoke synergize to increase airflow limitation in adults. American Journal of Respiratory and Critical Care Medicine 2004;169(4):479–87.

## Chapter 10 Control of Secondhand Smoke Exposure

Anderson PA, Buller DB, Voeks JH, Borland R, Helme D, Bettinghaus EP, Young WF. Predictors of support for environmental tobacco smoke bans in state government. American Journal of Preventive Medicine 2006;30(4):292–9.

Centers for Disease Control and Prevention. Indoor air quality in hospitality venues before and after implementation of a clean indoor air law—Western New York, 2003. Morbidity and Mortality Weekly Report 2004;53(44):1038–41.

Centers for Disease Control and Prevention. Survey of airport smoking policies—United States, 2002. Morbidity and Mortality Weekly Report 2004;53(50): 1175–8.

Javitz HA, Zbikowski SM, Swan GE, Jack LM. Financial burden of tobacco use: an employer’s perspective. Clinics in Occupational and Environmental Medicine 2006;5(1):9–29.

Johnsson T, Tuomi T, Riuttala H, Hyvärinen M, Rothberg M, Reijula K. Environmental tobacco smoke in Finnish restaurants and bars before and after smoking restrictions were introduced. Annals of Occupational Hygiene 2006; doi:10.1093/annhyg/me1011.

McMillen RC, Gresham K, Valentine N, Chambers C, Frese W, Cosby AG. The National Social Climate of Tobacco Control, 2000–2005, 2006; <http://www.ssrc.msstate.edu/socialclimate/reports/2005_National_Report.pdf >; accessed: May 10, 2006.

Siegel M, Barbeau EM, Osinubi OY. The impact of tobacco use and secondhand smoke on hospitality workers. Clinics in Occupational and Environmental Medicine 2006;5(1):31–42.

Winickoff JP, McMillen RC, Carroll BC, Klein JD, Rigotti NA, Tanski SE, Weitzman M. Addressing parental smoking in pediatrics and family practice: a national survey of parents. Pediatrics 2003;112(5):114–651.