# Definitions and Alternative Nomenclature of Genetic Symbols Used in This Report

Throughout this report, genes are represented by their abbreviations in italics. In many cases, proteins and enzymes related to these genes have the same abbreviation, presented in roman type. Definitions, alternative genetic symbols, related proteins and enzymes, and polymorphisms and variant genotypes are listed alphabetically by gene abbreviation.

Gene symbol used in this report | Definition | Alternative gene symbol | Related protein/enzyme | Polymorphism/variant genotype
5HTT | serotonin transporter | SLC6A4, 5HTTLPR | 5HTT, SERT, SLC6A4 | LPR; VNTR; 5HTTLPR
ADPRT | poly (ADP-ribose) polymerase family, member 1 | PARP1 | ADPRT; PARP1 | VAL762ALA; PRO882LEU; CYS908TYR
AGT | O^6^-alkylguanine–DNA alkyltransferase | | AGT | ILE143VAL; GLY160ARG
ANKK1 | ankyrin repeat and kinase domain containing 1 | | ANKK1, protein kinase PKK2 | GLU713LYS (caused by DRD2 *TAQ1A system)
APAF1 | apoptotic peptidase activating factor 1 | | APAF1
APEX1 | APEX nuclease (multifunctional DNA repair enzyme) 1 | | APEX1 | GLU148ASP (T11865G)
AREG | amphiregulin (schwannoma- derived growth factor) | SDGF | AREG, SDGF, CRDGF (colorectum cell-derived growth factor)
ARP | arginine-rich protein | ARMET | ARP, ARMET (arginine-rich mutated in early stage tumors)
ATM | ataxia telangiectasia mutated | TEL1 | ATM; TEL1 (telomere maintenance 1)
BAX | BCL2-associated X protein | | BAX
BRAF | v-raf murine sarcoma viral onco homolog B1 | | BRAF, B-RAF proto-oncogene serine/threonine-protein kinase (p94)
BRCA2 | breast cancer 2, early onset | | BRCA2, breast cancer susceptibility protein | HIS372ASN (T27113G), ILE3412VAL (G93268A)
C-FOS | v-fos FBJ murine osteosarcoma viral oncogene homolog | FOS | FOS, C-FOS
C4A | complement component 4A (Rodgers blood group) | | C4A | haplotype
C4B | complement component 4B (Childo blood group) | | C4B | haplotype
CASPASE-3 | cysteine-aspartic acid protease-3 | | CASPASE-3
CASPASE-8 | cysteine-aspartic acid protease-8 | | CASPASE-8
CCK | cholecystokinin | | CCK | C-45T promoter polymorphism in SP1 binding region of CCK gene
CCKAR | cholecystokinin A receptor | CCK1-R | CCKAR, CCK1-R (cholecystokinin-1 receptor) | T779C, VAL365ILE
CCND1 | G1/S-specific cyclin D1 | | CCND1 | G870A, *A/*A, *G/*A, *G/*G
CCNH | cyclin H | | CCNH, cyclin-dependent kinase-activating kinase | VAL270ALA
CD14 | CD14 molecule | | CD14 molecule; CD14 antigen | C-159T (promoter polymorphism)
CDK4 | cyclin-dependent kinase 4 | | CDK4, cell division kinase 4
CDKN2A | cyclin-dependent kinase inhibitor 2A | | CDKN2A, P16
C-HA-RAS | v-Ha-ras Harvey rat sarcoma viral oncogene homolog | C-HRAS, HRAS | C-HRAS, HRAS1 proto-oncoprotein
CHFR | checkpoint with forkhead and ring finger domains | | CHFR, mitotic checkpoint protein
CHRNA3 | cholinergic receptor, nicotinic, α3 | | CHRNA3
CHRNA4 | cholinergic receptor, nicotinic, α4 | | CHRNA4, α4 nAChR, nicotinic acetylcholine receptor α4 subunit | SNP RS3746372 (*1); haplotype
CHRNA5 | cholinergic receptor, nicotinic, α5 | | CHRNA5, nicotinic acetylcholine receptor α5 subunit, α5 nAChR | SNP RS16969968 (CHRNA5); SNPs RS8023462 and RS1948 (CHRNA5/A3/B4 cluster)
CHRNA7 | cholinergic receptor, nicotinic, α7 | | CHRNA7, nicotinic acetylcholine receptor α7 subunit, α7 nAChR | D15S1360 (a microsatellite polymorphic marker in INTRON 2) exhibited seven different dinucleotide repeat lengths (99, 109, 111, 113, 115, 117, and 125 bp), the major alleles are *113 and *115 (*113/*113, *113/*115, *115/*115)
CHRNB2 | cholinergic receptor, nicotinic, β2 (neuronal) | | CHRNB2, nicotinic acetylcholine receptor β2 subunit, β2 nAChR | multiple SNPs; haplotype
CHRNB3 | cholinergic receptor, nicotinic, β3 | | CHRNB3
CHRNB4 | cholinergic receptor, nicotinic, β4 | | CHRNB4
C-MYC | avian myelocytomatosis viral oncogene homolog | MYC | C-MYC, myc proto-oncogene protein
COMT | catechol-O-methyltransferase | | COMT | A1947G, *A, *G, VAL158MET
COX-1 | cyclooxygenase-1 | | COX-1
COX-2 | cyclooxygenase-2 | | COX-2
CYP17A1 | cytochrome P-450, family 17, subfamily A, polypeptide 1 | | CYP17A1
CYP1A1 | cytochrome P-450, family 1, subfamily A, polypeptide 1 | | CYP1A1, MSPI | *MSPI (*A/*a, *a/*a), ILE462VAL
CYP2A13 | cytochrome P-450, family 2, subfamily A, polypeptide 13 | | CYP2A13 | ARG257CYS (C3375T, *C/*T, *T/*T)
CYP2A6 | cytochrome P-450, family 2, subfamily A, polypeptide 6 | | CYP2A6 | *1 (wild type), *1A, *1B, *2, *3, *4, *4A, *4B, *4C, *4D, *5, *6, *7, *8, *9, *10, *12, *16, *NULL, *DEL
CYP2B6 | cytochrome P-450, family 2, subfamily B, polypeptide 6 | | CYP2B6 | *5 (C1459T=ARG487CYS); *6 (G516T=GLN172HIS); *2 (C64T=ARG22CYS); *3 (C777A=SER259ARG); *4 (A785G=LYS262ARG)
CYP2D6 | cytochrome P-450, family 2, subfamily D, polypeptide 6 | | CYP2D6 | *3, *4A, *5
CYP2E1 | cytochrome P-450, family 2, subfamily E, polypeptide 1 | | CYP2E1 | *1C, *1D, *DRA1, *RSA1
DAPK1 | death-associated protein kinase 1 | DAPK | DAPK1, DAPK
DAT | dopamine transporter | DAT1 | DAT, DAT1 | VNTR
DDC | dopa decarboxylase (aromatic l-amino acid decarboxylase) | AADC | DDC, AADC | haplotype
DLC1 | deleted in liver cancer 1 | | DLC1
DRD1 | dopamine receptor D1 | | DRD1 | *DDE1
DRD2 | dopamine receptor D2 | | DRD2 | *TAQ1A (*A), *TAQ1B, -141C *INS/*DEL, *FOK1, *INTRON 2, *MBO1
DRD4 | dopamine receptor D4 | | DRD4 | VNTR
DRD5 | dopamine receptor D5 | | DRD5 | haplotype
DβH | dopamine beta hydroxylase | | DβH | G1368A, C1021T, *A allele (G444A)
E-CADHERIN | cadherin 1, type 1, E-cadherin (epithelial) | | E-CADHERIN, calcium- dependent adhesion protein, epithelial
EGFR | epidermal growth factor receptor (erythroblastic leukemia viral (v-erb-b) onco homolog, avian) | | EGFR
ELA2 | elastase, neutrophil expressed | ELANE | ELA2
EN2 | engrailed homeobox 2 | EN-2 | EN2
ENOS | endothelial nitric oxide synthase | NOS3 | ENOS, NOS3 | *A allele (a quadruple repeat of a 27 base-pair sequence in INTRON 4), GLU298ASP (*ASP298)
EPHX1 | gene of epoxide hydrolase 1, microsomal (xenobiotic) | MEH | EPHX1, MEH microsomal epoxide hydrolase | EXON 3 SNP, EXON 4 SNP, EXONs 3-4 SNP haplotypes, (T → C) TYR113HIS (*H), (A → G) HIS139ARG
ERCC1 | excision repair cross- complementing rodent repair deficiency, complementation group 1 (includes overlapping antisense sequence) | | ERCC1
ESR1 | estrogen receptor 1 | | estrogen receptor α | *XBAL (c.454-351A → G), *PVULL (c.454-397T → C)
FAS | Fas (TNF receptor superfamily, member 6) | | FAS
FHIT | fragile histidine triad | | FHIT, FRA3B
FMS | colony stimulating factor 1 receptor | CSF1R, C-FMS, CD115, FIM2, CSFR | CSF1R, C-FMS, CD115, FIM2, CSFR
GABARAP | GABA receptor-associated protein | | GABARAP
GABA _B2_ | γ-aminobutyric acid type B receptor 2 | | GABA_B2_ | haplotype
GC | group-specific component (vitamin D binding protein) | | GC | *1S (416GLU, 420THR), *1F (416ASP, 420THR), *1S/*1F, *2 (416ASP, 420LYS), haplotype
GPX | glutathione peroxidase | | GPX
GSTA1 | glutathione-S-transferase 1α | | GSTA1
GSTM1 | glutathione-S-transferase μ1 | | GSTM1 | *NULL, *DEL
GSTP1 | glutathione-S-transferase π1 | | GSTP1 | ILE105VAL, *ILE/*ILE, *ILE/*VAL, ALA114VAL, *ALA/*ALA, *ALA/*VAL
GSTT1 | glutathione-S-transferase θ1 | | GSTT1 | *NULL, *DEL
H-CADHERIN | cadherin 13, H-cadherin (heart) | CDH13 | H-CADHERIN, CDH13
HER-2/NEU | v-erb-b2 erythroblastic leukemia viral oncogene homolog 2, neuro/glioblastoma derived oncogene homolog (avian) | ERBB2 | HER-2/NEU, erb B2 c-erb B2/ neu protein, HER-2 (human epidermal growth factor receptor 2)
HPRT | hypoxanthine phosphoribosyltransferase | | HPRT
IL-1β | interleukin-1β | | IL-1β | C-31T (TATA Box), *-31C, *-31T
JUN | jun oncogene | | JUN
KRAS | v-Ki-ras2 Kirsten rat sarcoma viral oncogene homolog | | KRAS
LAMA3 | laminin, α3 | | LAMA3
LAMB3 | laminin, β3 | | LAMB3
LAMC2 | laminin, γ2 | | LAMC2
LIG1 | ligase I, DNA, ATP-dependent | | LIG1 | ALA170ALA (A → C), ASP802ASP (C → T), ALA814ALA (C → G)
LIG4 | ligase IV, DNA, ATP-dependent | | LIG4 | ALA3ALA (C8T, cDNA), THR9ILE (C27T, cDNA)
LKB1/STK11 | serine/threonine kinase 11 | | LKB1, STK11
LMYC | v-myc myelocytomatosis viral onco gene homolog 1, lung carcinoma derived | L-MYC, MYCL1 | L-MYC, LMYC, MYCL1
MAOA | monoamine oxidase A | | MAOA | silent C1460T (EXON 14), VNTR
MAOB | monoamine oxidase B | | MAOB | A644G (*A,*G)
MBD4 | methyl-CpG binding domain protein 4 | | MBD4 | SER342PRO (T → C), GLU346LYS (G → A)
MGMT | O^6^-methylguanine-DNA methyltransferase | | MGMT | LEU84PHE, ILE143VAL
MMP-1 | matrix metallopeptidase 1 (interstitial collagenase) | | MMP-1
MMP-12 | matrix metallopeptidase 12 (macrophage elastase) | | MMP-12
MPO | myeloperoxidase | | MPO
MSX1 | msh homeobox 1 | | MSX1 | haplotype (intronic CA repeat), *X1.3/*X1.3, *X2.4/*X2.4, *2 (rare allele)
MUC5AC | mucin 5AC, oligomeric mucus/gel-forming | | MUC5AC
MUTYH | mutY homolog (E. coli) | | MUTYH, mutY DNA glycosylase, A/G-specific adenine DNA glycosylase | GLN335HIS (G → C)
MYO18B | myosin XVIIIB | | MYO18B
NAT1 | N-acetyltransferase 1 | | NAT1, arylamine N-acetyltransferase 1 | 1088 *A/*A (T1088A), 1095 *A/*A (C1095A)
NAT2 | N-acetyltransferase 2 | | NAT2, arylamine N-acetyltransferase 2 | ILE114THR (T → C), LYS161LYS (C → T), LYS268ARG (A → G), ARG197GLN (G → A), TYR94TYR (C → T), GLY286GLU (G → A), *4/*4 (wild type)
NBS1 | Nijmegen breakage syndrome 1 | NBN | NBS1, NBN, nibrin | GLN185GLU (C → G)
N-MYC | v-myc myelocytomatosis viral related oncogene, neuroblastoma derived (avian) | NMYC, MYCN | N-MYC, NMYC, MYCN, N-myc proto-oncogene protein
NORE1A | RAS association (RALGDS/AF- 6) domain family member 5 | RASFF5 | NORE1A, RASFF5
NRXN1 | neurexin 1 | | NRXN1
NRXN3 | neurexin 3 | | NRXN3
NTRK2 | neurotrophic tyrosine kinase, receptor, type 2 | | NTRK2
OGG1 | 8-oxoguanine DNA glycosylase | | OGG1 | SER326CYS (C → G), 326*CYS/*CYS, 326*SER/*SER
OPRM1 | opioid receptor, μ1 | | OPRM1 | ASN40ASP (A118G), *ASP40, *ASN40
P14 ^ARF^ | cyclin-dependent kinase inhibitor 2A (CDKN2A) | P14 | P14, P14ARF (the alternate reading frame products of CDKN2A gene)
P16 | cyclin-dependent kinase inhibitor 2A (CDKN2A) | P16INK4A | P16, P16INK4A (the major product of CDKN2A gene)
P21 | cyclin-dependent kinase inhibitor 1A | P21, CDNK1A, CIP1, WAF1, SDI1 | P21, CDNK1A, CIP1, WAF1, SDI1 | SER31ARG
P53 | tumor suppressor | | P53 | ARG72PRO (G → C), 72*ARG/*PRO, 72*PRO/*PRO, *MSPI (INTRON 6), 16 bp insertion (INTRON 3)
P73 | tumor protein gene 73 | TP73 | P73, TP73 | *GC/*GC, *AT/*AT, *GC/*AT (G4A, C14T in EXON 2)
PARKIN | Parkinson disease (autosomal recessive, juvenile) 2, parkin | PARK2 | PARKIN (ligase)
PAX5 α | paired box gene 5 | BSAP (B-cell specific activator) α | PAX5 α (one of the products of PAX5 gene), BSAP (B-cell specific activator protein) α
PAX5 β | paired box gene 5 | BSAP (B-cell specific activator) β | PAX β (one of the products of PAX5 gene), BSAP (B-cell specific activator protein) β
PCMVCAT | a plasmid construct containing the reporter gene CAT (chloramphenicol acetyltransferase) driven by CMV (cytomegalovirus) promoter | | PCMVCAT, chloramphenicol acetyltransferase as a reporter
PLAP | placental alkaline phosphatase | ALPP | PLAP, ALPP alkaline phosphatase, placental (Regan isozyme) | *1/*1, *2/*2
POLD1 | polymerase (DNA directed), delta 1, catalytic subunit 125kDa | | POLD1 | ARG19HIS (G → A), HIS119ARG (A → G), SER173ASN (A → G)
PTEN | phosphatase and tensin homolog | | PTEN, deleted on chromosome 10 | this gene may be deleted on chromosome 10 (10q23) with the development of cancers
RAD23B | RAD23 homolog B (S. cerevisiae) | | RAD23B, UV excision repair protein RAD23 homolog B, XP-C repair complementing protein | ALA249VAL (C → T)
RAD4 | RAD4 gene of S. cerevisiae | | RAD4, S. cerevisiae DNA damage recognition and repair protein
RAD50 | RAD50 gene homolog (S. cerevisiae) | | RAD50 (human) | ARG1111ILE (G3374T, cDNA)
RAD51 | RAD51 homolog (S. cerevisiae) | | RAD51
RAD52 | RAD52 homolog (S. cerevisiae) | | RAD52
RAD54L | RAD54 homolog (S. cerevisiae) | S. cerevisiae RAD50 gene homolog | RAD54L | ARG374SER (G1222C, cDNA)
RASSF1A | Ras association (RalGDS/AF-6) domain family member 1 (A isoform) | | RASSF1A
RASSF2 | Ras association (RalGDS/AF-6) domain family member 2 | | RASSF2
RASSF4 | Ras association (RalGDS/AF-6) domain family member 4 | | RASSF4, tumor suppressor protein
RB | retinoblastoma 1 tumor suppressor | RB1 | RB, RB1
SERPINA1 | serpin peptidase inhibitor, clade A (α-1 antiproteinase, antitrypsin), member 1 | | SERPINA1, AAT protein | *M, *S, *Z, *NULL
SERPINA3 | serpin peptidase inhibitor, clade A (α-1 antiproteinase, antitrypsin), member 3 | | SERPINA3, ACT protein | PRO229ALA, LEU55PRO, MET389VAL, ALA- 15THR (signal peptide), 1258DELAA
SFTPB | surfactant protein B | | SFTPB; surfactant, pulmonary-associated protein B | A-18C (promoter), A1013C, C1580T, A9306G, INTRON 4 variants, THR131ILE
STK11 | serine/threonine kinase 11 | | STK11
TDG | thymine-DNA glycosylase | | TDG
TGFα | transforming growth factor α | | TGFα
TGFβ1 | transforming growth factor β1 | | TGFβ1 | SNP RS1800469 (C-509T, promoter), SNP RS2241712 (G-10807A, promoter), SNP RS6957 (3’UTR), SNP RS224178 (3’UTR), SNP RS1982073 (T29C, LEU10PRO, EXON 1)
TGFβ3 | transforming growth factor β3 | | TGFβ3
TH | tyrosine hydroxylase | | TH | VNTR
TIMP-3 | tissue inhibitor of metalloproteinase 3 | | TIMP-3
TNFα | tumor necrosis factor (TNF superfamily, member 2) | TNF | TNFα, TNF | TNF2 ( a promoter SNP, G-308A), SNPs G-376A and G-238A (promoter), G489A (INTRON), SNP RS3091257 (3’UTR), SNP RS769178 (3’UTR)
TP | thymidine phosphorylase | | TP
TPH | tryptophan hydroxylase | TPH1 | TPH, TPH1 | C218A, A779C
TP53 | tumor protein | | TP53
TRAIL-R1 | TNF-related apoptosis inducing ligand receptor 1 | TNFRSF10A | TRAIL-R1, TNFRSF10A, death receptor 4
UGT1A | UDP glucuronosyltransferase 1 family, polypeptide A1 | | UGT1A
XPC | xeroderma pigmentosum, complementation group C | XPCC, XP3 | XPC, XPCC, XP3 | ALA499VAL (C → T), LYS939GLN (A → C), *PAT (poly AT ins/del polymorphism)
XPD | xeroderma pigmentosum, complementation group D | ERCC2 | XPD, ERCC2 | ASP312ASN (G → A, 312 *G/*A), LYS751GLN (A → C, 751 *A/*C)
XPF | xeroderma pigmentosum, complementation group F | ERCC4 | XPF, ERCC4 | SER662PRO (T → C), ARG415GLN (G1244A, EXON 8 SNP RS1800067), SER835SER (T2505C, EXON 11 SNP RS1799801)
XPG | xeroderma pigmentosum, complementation group G | ERCC5 | XPG, ERCC5 | HIS1104ASP (G3507C, SNP RS17655), HIS46HIS (T335C, SNP RS1047768), CYS529SER (SNP RS2227869)
XPV | polymerase (DNA directed) eta | POLH | XPV POLH, human DNA polymerase η
XRCC1 | x-ray repair complementing defective repair in Chinese hamster cells 1 | | XRCC1 | ARG194TRP (C → T), ARG280HIS (G → A), ARG399GLN (G → A)
XRCC2 | x-ray repair complementing defective repair in Chinese hamster cells 2 | | XRCC2
XRCC3 | x-ray repair complementing defective repair in Chinese hamster cells 3 | | XRCC3 | THR241MET (T → C)
XRCC4 | x-ray repair complementing defective repair in Chinese hamster cells 4 | | XRCC4 | ALA247SER (G → T)
XRCC5 | x-ray repair complementing defective repair in Chinese hamster cells 5 (double-strand- break rejoining) | KU80 | XRCC5, KU80
XRCC6 | x-ray repair complementing defective repair in Chinese hamster cells 6 | KU70 | XRCC6, KU70