# Acknowledgments

This report was prepared by the U.S. Department of Health and Human Services under the general direction of the Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health.

Vice Admiral Regina Benjamin, M.D., M.B.A., Surgeon General, U.S. Public Health Service, Office of the Assistant Secretary for Health, Office of the Surgeon General, Office of the Secretary, U.S. Department of Health and Human Services, Washington, D.C.

Rear Admiral Boris Lushniak, M.D., M.P.H., Deputy Surgeon General, U.S. Public Health Service, Office of the Assistant Secretary for Health, Office of the Surgeon General, Office of the Secretary, U.S. Department of Health and Human Services, Washington, D.C.

Rear Admiral Christopher Halliday, D.D.S., M.P.H., Chief of Staff, U.S. Public Health Service, Office of the Assistant Secretary for Health, Office of the Surgeon General, Office of the Secretary, U.S. Department of Health and Human Services, Washington, D.C.

Mary Beth Bigley, Dr. P.H., M.S.N., A.N.P., Acting Director of the Office of Science and Communication, Office of the Surgeon General, Office of the Assistant Secretary for Health, Office of the Secretary, U.S. Department of Health and Human Services, Washington, D.C.

Rear Admiral (Retired) Steven K. Galson, M.D., M.P.H., former Acting Surgeon General, U.S. Public Health Service, Office of the Surgeon General, Office of the Assistant Secretary for Health, Office of the Secretary, U.S. Department of Health and Human Services, Washington, D.C.

Rear Admiral (Retired) Kenneth P. Moritsugu, M.D., M.P.H., former Acting Surgeon General, U.S. Public Health Service, Office of the Surgeon General, Office of Public Health and Science, Office of the Secretary, U.S. Department of Health and Human Services, Washington, D.C.

Rear Admiral (Retired) Carol A. Romano, Ph.D., R.N., F.A.A.N., former Acting Deputy Surgeon General, U.S. Public Health Service, Office of the Surgeon General, Office of Public Health and Science, Office of the Secretary, U.S. Department of Health and Human Services, Washington, D.C.

Rear Admiral (Retired) David Rutstein, M.D., M.P.H., former Acting Deputy Surgeon General, U.S. Public Health Service, Office of the Assistant Secretary for Health, Office of the Surgeon General, Office of the Secretary, U.S. Department of Health and Human Services, Washington, D.C.

Rear Admiral (Retired) Robert C. Williams, P.E., D.E.E., former Acting Deputy Surgeon General, U.S. Public Health Service, Office of the Surgeon General, Office of the Assistant Secretary for Health, Office of the Secretary, U.S. Department of Health and Human Services, Washington, D.C.

Thomas R. Frieden, M.D., M.P.H., Director, Centers for Disease Control and Prevention, Atlanta, Georgia.

Ursula Bauer, Ph.D., Director, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

Barbara Bowman, Ph.D., Associate Director for Science, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

Samuel F. Posner, Ph.D., Associate Director for Science (Acting), National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

Tim A. McAfee, M.D., M.P.H., Director, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

Terry F. Pechacek, Ph.D., Associate Director for Science, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

## The editors of the report were

David Sidransky, M.D., Senior Scientific Editor, Professor, Otolaryngology-Head & Neck Surgery, Oncology, Pathology, Urology, Cellular and Molecular Medicine, and Director, Head and Neck Cancer Research, The Johns Hopkins University School of Medicine, Johns Hopkins Medical Institutions, Baltimore, Maryland.

Leslie A. Norman, Managing Editor, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

Anne McCarthy, Technical Editor, Northrop Grumman supporting National Center for Health Marketing, Division of Creative Services, Centers for Disease Control and Prevention, Atlanta, Georgia.

Peter L. Taylor, M.B.A., Technical Editor, Senior Editor, Palladian Partners, Silver Spring, Maryland.

## Contributing editors were

David L. Ashley, Ph.D., Chief, Emergency Response and Air Toxicants Branch, Division of Laboratory Sciences, National Center for Environmental Health, Centers for Disease Control and Prevention, Atlanta, Georgia.

Neal L. Benowitz, M.D., Professor of Medicine and Bio-pharmaceutical Sciences and Chief, Division of Clinical Pharmacology and Experimental Therapeutics, University of California, San Francisco, California.

Dorothy Hatsukami, Ph.D., Forster Family Professor in Cancer Prevention, Professor of Psychiatry, University of Minnesota Tobacco Use Research Center, University of Minnesota, Minneapolis, Minnesota.

Stephen S. Hecht, Ph.D., Wallin Professor of Cancer Prevention, Masonic Cancer Center, University of Minnesota, Minneapolis, Minnesota.

Jack E. Henningfield, Ph.D., Vice President Research and Health Policy, Pinney Associates, Bethesda, Maryland; and Professor, Adjunct, Department of Psychiatry and Behavioral Sciences, The Johns Hopkins University School of Medicine, Baltimore, Maryland.

Patricia Richter, Ph.D., DABT, Toxicologist, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

Jonathan M. Samet, M.D., M.S., Professor and Chairman, Department of Epidemiology, Bloomberg School of Public Health, The Johns Hopkins University, Baltimore, Maryland (1994–2008); and Director, USC Institute for Global Health, and Chairman, Department of Preventive Medicine, Keck School of Medicine, University of Southern California, Los Angeles, California (2008–present).

Gayle C. Windham, Ph.D., M.S.P.H., Research Scientist Supervisor, Chief, Environmental Surveillance Unit, Division of Environmental and Occupational Disease Control, California Department of Public Health, Richmond, California.

## Contributing authors were

David L. Ashley, Ph.D., Chief, Emergency Response and Air Toxicants Branch, Division of Laboratory Sciences, National Center for Environmental Health, Centers for Disease Control and Prevention, Atlanta, Georgia.

Timothy B. Baker, Ph.D., Professor of Medicine, University of Wisconsin School of Medicine and Public Health, Madison, Wisconsin.

Steve A. Belinsky, Ph.D., Director, Lung Cancer Program, Senior Scientist, Lovelace Respiratory Research Institute, Albuquerque, New Mexico.

Neal L. Benowitz M.D., Professor of Medicine and Bio-pharmaceutical Sciences and Chief, Division of Clinical Pharmacology and Experimental Therapeutics, University of California, San Francisco, California.

Tomoku Betsuyaku, M.D., Ph.D., Associate Professor, First Department of Medicine, Hokkaido University School of Medicine, Sapporo, Japan.

Ann M. Bode, Ph.D., Research Professor and Associate Director, The Hormel Institute, University of Minnesota, Austin, Minnesota.

Anne Burke, M.D., Assistant Professor of Medicine, Gastroenterology Division, University of Pennsylvania School of Medicine, Philadelphia, Pennsylvania.

David M. Burns, M.D., Professor Emeritus, Department of Family and Preventive Medicine, School of Medicine, University of California, San Diego, California.

Rebecca Buus, Ph.D., Health Scientist, Maternal and Infant Health Branch, Division of Reproductive Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

Laurie Chassin, Ph.D., Regents Professor of Psychology, Psychology Department, Arizona State University, Tempe, Arizona.

David Christiani, M.D., M.P.H., Professor, Departments of Environmental Health and Epidemiology, Harvard School of Public Health, Harvard University, Boston, Massachusetts.

Pamela I. Clark, M.S.P.H., Ph.D., Research Professor, School of Public Health, University of Maryland, College Park, Maryland.

John P. Cooke, M.D., Ph.D., Professor of Medicine, Stanford University, Stanford, California.

Adolfo Correa, M.D., Ph.D., M.P.H., Medical Officer, Division of Birth Defects and Developmental Disabilities, National Center on Birth Defects and Developmental Disabilities, Centers for Disease Control and Prevention, Atlanta, Georgia.

Johannes Czernin, M.D., Professor, Molecular and Medical Pharmacology, and Chief, Ahmanson Biological Imaging Division, David Geffen School of Medicine, University of California, Los Angeles, California.

Gerald N. DeLorenze, Ph.D., Research Scientist, Division of Research, Kaiser Permanente Northern California, Oakland, California.

David M. DeMarini, Ph.D., Genetic Toxicologist, Integrated Systems Toxicology Division, U.S. Environmental Protection Agency, Research Triangle Park, North Carolina.

Delia Dempsey, M.D., M.S., Assistant Professor, Pediatrics, Medicine and Clinical Pharmacology, Division of Clinical Pharmacology, University of California, San Francisco, San Francisco, California.

Phillip A. Dennis, M.D., Ph.D., Senior Investigator, Medical Oncology Branch, Center for Cancer Research, National Cancer Institute, National Institutes of Health, Bethesda, Maryland.

Yan Shirley Ding, Ph.D., Senior Service Fellow, Emergency Response and Air Toxicants Branch, Division of Laboratory Sciences, National Center for Environmental Health, Centers for Disease Control and Prevention, Atlanta, Georgia.

Mirjana V. Djordjevic, Ph.D., Program Director, Tobacco Control Research Branch, Behavioral Research Program, Division of Cancer Control and Population Sciences, National Cancer Institute, National Institutes of Health, Bethesda, Maryland.

Zigang Dong, M.D., M.S., Dr. P.H., Professor, The Hormel Institute, University of Minnesota, Austin, Minnesota.

Björn Eliasson, M.D., Ph.D., Associate Professor, Department of Internal Medicine, Sahlgrenska University Hospital, Göteborg, Sweden.

Lucinda England, M.D., M.S.P.H., Medical Epidemiologist, Maternal and Infant Health Branch, Division of Reproductive Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

Reginald Fant, Ph.D., Senior Scientist and Director, Pinney Associates, Bethesda, Maryland.

Garret A. FitzGerald, M.D., Chair, Department of Pharmacology, and Director, Institute for Translational Medicine and Therapeutics, University of Pennsylvania School of Medicine, Philadelphia, Pennsylvania.

Mari S. Golub, Ph.D., Staff Toxicologist, Office of Environmental Health Hazard Assessment, California Environmental Protection Agency, Sacramento, California.

Dorothy Hatsukami, Ph.D., Forster Family Professor in Cancer Prevention, Professor of Psychiatry, University of Minnesota Tobacco Use Research Center, University of Minnesota, Minneapolis, Minnesota.

Stephen S. Hecht, Ph.D., Wallin Professor of Cancer Prevention, Masonic Cancer Center, University of Minnesota, Minneapolis, Minnesota.

Marc K. Hellerstein, M.D., Ph.D., Professor (DH Calloway Chair in Human Nutrition), Department of Nutritional Sciences, University of California, Berkeley, California; and Professor of Endocrinology, Metabolism and Nutrition, Department of Medicine, University of California, San Francisco, California.

Jack E. Henningfield, Ph.D., Vice President Research and Health Policy, Pinney Associates, Bethesda, Maryland; and Professor, Adjunct, Department of Psychiatry and Behavioral Sciences, The Johns Hopkins University School of Medicine, Baltimore, Maryland.

Brian Hitsman, Ph.D., Assistant Professor, Department of Preventive Medicine, Northwestern University, Chicago, Illinois.

James C. Hogg, M.D., Ph.D., Emeritus Professor of Pathology and Lab Medicine, iCAPTURE Centre for Cardiovascular and Pulmonary Research, University of British Columbia and St. Paul’s Hospital, Vancouver, British Columbia, Canada.

Anne M. Joseph, M.D., M.P.H., Wexler Professor of Medicine, and Director, Applied Clinical Research Program, University of Minnesota Medical School, Minneapolis, Minnesota.

Caryn Lerman, Ph.D., Mary W. Calkins Professor, Department of Psychiatry and Annenberg Public Policy Center; and Director, Tobacco Use Research Center, Scientific Director, Abramson Cancer Center, University of Pennsylvania, Philadelphia, Pennsylvania.

William MacNee, Professor, ELEGI Colt Research Labs, MRC Centre for Inflammation Research, The Queen’s Medical Research Institute, University of Edinburgh, Edinburgh, Scotland, United Kingdom.

Athina Markou, Ph.D., Professor, Department of Psychiatry, School of Medicine, University of California, San Diego, La Jolla, California.

Robert Merritt, M.A., Branch Chief, Epidemiology and Surveillance Branch, Division of Heart Disease and Stroke Prevention, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

Dennis L. Molfese, Ph.D., Distinguished University Scholar and Professor, Birth Defects Center, University of Louisville, Louisville, Kentucky.

Masaaki Moriya, Ph.D., Research Professor, Laboratory of Chemical Biology, Department of Pharmacological Sciences, University at Stony Brook, The State University of New York, Stony Brook, New York.

Marcus Munafò, M.A., M.Sc., Ph.D., Reader in Biological Psychology, Department of Experimental Psychology, University of Bristol, Bristol, United Kingdom.

Sharon E. Murphy, Ph.D., Professor, Biochemistry, Molecular Biology and BioPhysics, Masonic Cancer Center, University of Minnesota, Minneapolis, Minnesota.

Raymond Niaura, Ph.D., Professor, Department of Psychiatry and Human Behavior, The Warren Alpert Medical School of Brown University; and Director, Trans-disciplinary Research, Butler Hospital, Providence, Rhode Island.

James Pankow, Ph.D., Professor, Department of Chemistry, and Department of Civil and Environmental Engineering, Portland State University, Portland, Oregon.

Steve Pappas, Ph.D., Research Chemist, Emergency Response and Air Toxicants Branch, Division of Laboratory Sciences, National Center for Environmental Health, Centers for Disease Control and Prevention, Atlanta, Georgia.

Terry F. Pechacek, Ph.D., Associate Director for Science, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

Kenneth A. Perkins, Ph.D., Professor of Psychiatry, Western Psychiatric Institute and Clinic, University of Pittsburgh School of Medicine, Pittsburgh, Pennsylvania.

Lisa A. Peterson, Ph.D., Professor, Masonic Cancer Center and the Division of Environmental Health Sciences, University of Minnesota, Minneapolis, Minnesota.

Gerd P. Pfeifer, Ph.D., Professor and Chair, Division of Biology, Beckman Research Institute, City of Hope National Medical Center, Duarte, California.

Halit Pinar, M.D., Director, Division of Perinatal and Pediatric Pathology, Women and Infants Hospital of Rhode Island; and Professor, Department of Pathology and Laboratory Medicine, Brown University Alpert School of Medicine, Providence, Rhode Island.

Gregory Polzin, Ph.D., Research Chemist, Emergency Response and Air Toxicants Branch, Division of Laboratory Sciences, National Center for Environmental Health, Centers for Disease Control and Prevention, Atlanta, Georgia.

Patricia Richter, Ph.D., DABT, Toxicologist, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

Nancy Rigotti, M.D., Professor of Medicine, Harvard Medical School; and Director, Tobacco Research and Treatment Center, Massachusetts General Hospital, Boston, Massachusetts.

Wendie A. Robbins, Ph.D., Associate Professor, UCLA Schools of Nursing and Public Health, University of California, Los Angeles, California.

Andrew G. Salmon, M.A., D.Phil., Senior Toxicologist, Office of Environmental Health Hazard Assessment, California Department of Health Services, Oakland, California.

Jonathan M. Samet, M.D., M.S., Professor and Chairman, Department of Epidemiology, Bloomberg School of Public Health, The Johns Hopkins University, Baltimore, Maryland (1994–2008); and Director, USC Institute for Global Health, and Chairman, Department of Preventive Medicine, Keck School of Medicine, University of Southern California, Los Angeles, California (2008–present).

Robert M. Senior, M.D., Professor of Pulmonary Medicine, Cell Biology & Physiology, Division of Pulmonary and Critical Care, Washington University School of Medicine, St. Louis, Missouri.

Edwin K. Silverman, M.D., Ph.D., Associate Professor of Medicine, Harvard Medical School, Harvard University; and Associate Physician, Brigham and Women’s Hospital, Boston, Massachusetts.

Margaret R. Spitz, M.D., M.P.H., Professor and Chair, Department of Epidemiology, The University of Texas, M. D. Anderson Cancer Center, Houston, Texas.

Stephen B. Stanfill, M.S., Chemist, Emergency Response and Air Toxicants Branch, National Center for Environmental Health, Centers for Disease Control and Prevention, Atlanta, Georgia.

Prudence Talbot, Ph.D., Professor of Cell Biology, Department of Cell Biology and Neuroscience, University of California, Riverside, California.

Anne Thorndike, M.D., M.P.H., Instructor in Medicine, General Medicine Unit, Massachusetts General Hospital, Boston, Massachusetts.

Clifford H. Watson, Ph.D., Lead Research Chemist, Emergency Response and Air Toxicants Branch, National Center for Environmental Health, Centers for Disease Control and Prevention, Atlanta, Georgia.

Gayle C. Windham, Ph.D., M.S.P.H., Research Scientist Supervisor, Chief, Environmental Surveillance Unit, Division of Environmental and Occupational Disease Control, California Department of Public Health, Richmond, California.

Weija (William) Wu, Ph.D., Senior Service Fellow, Emergency Response and Air Toxicants Branch, Division of Laboratory Sciences, National Center for Environmental Health, Centers for Disease Control and Prevention, Atlanta, Georgia.

Mitchell Zeller, J.D., Vice President for Policy and Strategic Communications, Pinney Associates, Bethesda, Maryland.

## Reviewers were

Erik M. Augustson, Ph.D., M.P.H., Behavioral Scientist/Psychologist, Tobacco Control Research Branch, Behavioral Research Program, Division of Cancer Control and Population Sciences, National Cancer Institute, National Institutes of Health, Bethesda, Maryland.

Cathy L. Backinger, Ph.D., M.P.H., Chief, Tobacco Control Research Branch, Behavioral Research Program, Division of Cancer Control and Population Sciences, National Cancer Institute, National Institutes of Health, Bethesda, Maryland.

Neal L. Benowitz M.D., Professor of Medicine and Bio-pharmaceutical Sciences and Chief, Division of Clinical Pharmacology and Experimental Therapeutics, University of California, San Francisco, California.

Mary Beth Bigley, Dr. P.H., M.S.N., A.N.P., Acting Director of the Office of Science and Communication, Office of the Surgeon General, Office of Public Health and Science, Office of the Secretary, U.S. Department of Health and Human Services, Washington, D.C.

Michele Bloch, M.D., Ph.D., Medical Officer, Tobacco Control Research Branch, Behavioral Research Program, Division of Cancer Control and Population Sciences, National Cancer Institute, National Institutes of Health, Bethesda, Maryland.

Naomi Breslau, Ph.D., Professor, Department of Epidemiology, Michigan State University, East Lansing, Michigan.

Klaus D. Brunnemann, M.S., Research Associate, New York Medical College, Valhalla, New York.

David M. Burns, M.D., Professor Emeritus, Department of Family and Preventive Medicine, School of Medicine, University of California, San Diego, California.

Pamela I. Clark, M.S.P.H., Ph.D., Research Professor, School of Public Health, University of Maryland, College Park, Maryland.

Gregory N. Connolly, D.M.D., M.P.H., Professor, Department of Society, Human Development, and Health, Harvard School of Public Health, Harvard University, Boston, Massachusetts.

William A. Corrigall, Ph.D., Professor of Psychiatry, University of Minnesota; and Senior Scientist, Minneapolis Medical Research Foundation, Minneapolis, Minnesota.

James D. Crapo, M.D., Professor of Medicine, National Jewish Health, Denver, Colorado.

Michael Criqui, M.D., M.P.H., Professor and Chief, Division of Preventive Medicine, Department of Family and Preventive Medicine; and Professor, Department of Medicine, School of Medicine, University of California, San Diego, La Jolla, California.

K. Michael Cummings, Ph.D., M.P.H., Senior Research Scientist, Chair, Department of Health Behavior, Division of Cancer Prevention and Population Sciences, Roswell Park Cancer Institute, Buffalo, New York.

Mirjana V. Djordjevic, Ph.D., Program Director, Tobacco Control Research Branch, Behavioral Research Program, Division of Cancer Control and Population Sciences, National Cancer Institute, National Institutes of Health, Bethesda, Maryland.

Erik Dybing, M.D., Ph.D., Division Director and Professor (retired), Division of Environmental Health, Norwegian Institute of Public Health, Oslo, Norway.

Michael Eriksen, Sc.D., Professor, and Director, Institute of Public Health, Georgia State University, Atlanta, Georgia.

Jefferson Fowles, Ph.D., Toxicologist, LyondellBasell Industries, Rotterdam, The Netherlands.

Adi F. Gazdar, M.D., Professor, Department of Pathology, University of Texas Southwestern Medical Center, Dallas, Texas.

Gary A. Giovino, Ph.D., M.S., Professor and Chair, Department of Health Behavior, School of Public Health and Health Professions, University at Buffalo, The State University of New York, Buffalo, New York.

Stanton Glantz, Ph.D., Professor of Medicine, Division of Cardiology, University of California, San Francisco, California.

Michael R. Guerin, Ph.D., Associate Division Director (retired), Oak Ridge National Laboratory, Knoxville, Tennessee.

Dorothy Hatsukami, Ph.D., Forster Family Professor in Cancer Prevention, Professor of Psychiatry, University of Minnesota Tobacco Use Research Center, University of Minnesota, Minneapolis, Minnesota.

Jack E. Henningfield, Ph.D., Vice President Research and Health Policy, Pinney Associates, Bethesda, Maryland; and Professor, Adjunct, Department of Psychiatry and Behavioral Sciences, The Johns Hopkins University School of Medicine, Baltimore, Maryland.

Allison Chausmer Hoffman, Ph.D., Program Director, National Institute on Drug Abuse, National Institutes of Health, Bethesda, Maryland.

John R. Hoidal, M.D., Professor and Chairman of Medicine, School of Medicine, University of Utah Health Sciences Center, Salt Lake City, Utah.

John E. Hokanson, Ph.D., Associate Professor and Chair, Department of Epidemiology, Colorado School of Public Health, University of Colorado, Denver, Aurora, Colorado.

John Hughes, M.D., Professor, Department of Psychiatry, University of Vermont, Burlington, Vermont.

Richard D. Hurt, M.D., Professor of Medicine, Mayo Clinic College of Medicine, Rochester, Minnesota.

Jared B. Jobe, Ph.D., FABMR, Program Director, Clinical Applications and Prevention Branch, Division of Prevention and Population Sciences, National Heart, Lung, and Blood Institute, National Institutes of Health, Bethesda, Maryland.

Rachel Kaufmann, Ph.D., M.P.H., Deputy Associate Director for Science, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

Karl T. Kelsey, M.D., M.O.H., Professor, Community Health and Pathology and Laboratory Medicine, Director, Center for Environmental Health and Technology, Brown University, Providence, Rhode Island.

Juliette Kendrick, M.D., Medical Officer, Division of Reproductive Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

Martin Kharrazi, Ph.D., Chief, Program Research and Demonstration Section, Genetic Disease Screening Program, California Department of Public Health, Richmond, California.

Taline V. Khroyan, Ph.D., Behavioral Pharmacologist, SRI International, Center for Health Sciences, Menlo Park, California.

Walther N.M. Klerx, Food and Consumer Product Safety Authority, Eindhoven, The Netherlands.

Philip Lazarus, Ph.D., Professor of Pharmacology, College of Medicine, Pennsylvania State University, Milton S. Hershey Medical Center, Hershey, Pennsylvania.

Scott Leischow, Ph.D., Associate Director for Behavioral and Social Sciences Research, Arizona Cancer Center, The University of Arizona, Tucson, Arizona.

Christina N. Lessov-Schlaggar, Ph.D., Research Assistant Professor, Department of Psychiatry, Washington University School of Medicine, St. Louis, Missouri.

Catherine Lorraine, Director, Policy Development and Coordination Staff, Food and Drug Administration, Silver Spring, Maryland.

Cathy Melvin, Ph.D., M.P.H., Director, Child Health Services Program, Cecil G. Sheps Center for Health Services Research, University of North Carolina, Chapel Hill, North Carolina.

John D. Minna, M.D., Director, Hamon Center for Therapeutic Oncology Research, University of Texas Southwestern Medical Center, Dallas, Texas.

Joshua E. Muscat, Ph.D., Professor, Department of Public Health Sciences, College of Medicine, Pennsylvania State University, Milton S. Hershey Medical Center, Hershey, Pennsylvania.

Mark Parascandola, Ph.D., M.P.H., Epidemiologist, Tobacco Control Research Branch, Behavioral Research Program, Division of Cancer Control and Population Sciences, National Cancer Institute, National Institutes of Health, Bethesda, Maryland.

Wallace Pickworth, Ph.D., Health Research Leader, Battelle Centers for Public Health Research and Evaluation, Baltimore, Maryland.

John M. Pinney, President, Pinney Associates, Bethesda, Maryland.

Britt C. Reid, D.D.S., Ph.D., Chief, Modifiable Risk Factors Branch, Epidemiology and Genetics Research Program, Division of Cancer Control and Population Sciences, National Cancer Institute, National Institutes of Health, Bethesda, Maryland.

John E. Repine, M.D., Director, Webb-Waring Center, Waring Professor of Medicine and Pediatrics, School of Medicine, University of Colorado, Denver, Colorado.

William Rickert, Ph.D., Chief Executive Officer, Labstat International ULC, Kitchener, Ontario, Canada.

David J. Riley, M.D., Professor, Department of Medicine, University of Medicine and Dentistry of New Jersey, Robert Wood Johnson Medical School, Piscataway, New Jersey.

Scott Rogers, M.P.H., Public Health Advisor, Epidemiology and Genetics Research Program, Division of Cancer Control and Population Sciences, National Cancer Institute, National Institutes of Health, Bethesda, Maryland.

Dale P. Sandler, Ph.D., Chief, Epidemiology Branch, National Institute of Environmental Health Sciences, National Institutes of Health, Research Triangle Park, North Carolina.

David A. Scott, Ph.D., Associate Professor, Oral Health and Systemic Disease Research Group, University of Louisville, Louisville, Kentucky.

Harold E. Seifried, Ph.D., DABT, Chemist, Toxicologist, Industrial Hygienist (retired), Program Director, Nutritional Sciences Research Group, Division of Cancer Prevention, National Cancer Institute, National Institutes of Health, Bethesda, Maryland.

Peter G. Shields, M.D., Professor of Medicine and Oncology, Deputy Director, Lombardi Comprehensive Cancer Center, Georgetown University Medical Center, Washington, D.C.

Saul Shiffman, Ph.D., Research Professor, Psychology and Psychiatry, University of Pittsburgh; and Senior Scientific Advisor, Pinney Associates, Pittsburgh, Pennsylvania.

Donald R. Shopland, Sr., U.S. Public Health Service (retired), Ringgold, Georgia.

Stephen Sidney, M.D., M.P.H., Associate Director for Clinical Research, Division of Research, Kaiser Permanente, Oakland, California.

Gary D. Stoner, Ph.D., Professor Emeritus, Department of Internal Medicine, The Ohio State University, Columbus, Ohio.

Gary E. Swan, Ph.D., Director, Center for Health Sciences, SRI International Fellow, SRI International, Center for Health Sciences, Menlo Park, California.

Michael J. Thun, M.D., M.S., Vice President Emeritus, Epidemiology and Surveillance Research, American Cancer Society, Atlanta, Georgia.

Robert B. Wallace, M.D., M.Sc., Irene Ensminger Stecher Professor of Epidemiology and Internal Medicine, Department of Epidemiology, University of Iowa College of Public Health, Iowa City, Iowa.

Deborah M. Winn, Ph.D., Deputy Director, Epidemiology and Genetics Research Program, Division of Cancer Control and Population Sciences, National Cancer Institute, National Institutes of Health, Bethesda, Maryland.

## Other contributors were

Charlotte Gerczak, M.L.A., Communications Associate, Department of Epidemiology, Bloomberg School of Public Health, The Johns Hopkins University, Baltimore, Maryland.

Roberta B. Gray, Administrative Supervisor to Dr. Jonathan M. Samet, Department of Epidemiology, Bloomberg School of Public Health, The Johns Hopkins University, Baltimore, Maryland.

Marta Gwinn, M.D., M.P.H., Medical Officer, Office of Public Health Genomics, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

Nancy Leonard, Administrative Coordinator to Dr. Jonathan M. Samet, Department of Epidemiology, Bloomberg School of Public Health, The Johns Hopkins University, Baltimore, Maryland.

Deborah Williams, Desktop Publishing Specialist to Dr. Jonathan M. Samet, Department of Epidemiology, Bloomberg School of Public Health, The Johns Hopkins University, Baltimore, Maryland.