# List of Abbreviations

1-HOP: 1-hydroxypyrene
4-ABP: 4-aminobiphenyl
4-HNE: 4-hydroxy-2-nonenal
8-oxo-dG: 7-hydroxy-8-oxo-2′-deoxyguanosine
8-OH-dG: 8-hydroxy-2′-deoxyguanosine
8-OH-DPAT: 8-hydroxy-2-dipropylaminotetralin
AAT: α1-antitrypsin
ACE: angiotensin-converting enzyme
ACh: acetylcholine
ACTH: adrenocorticotropic hormone
ADMA: asymmetric dimethylarginine
AGT: O^6^-alkylguanine–DNA alkyltransferase
AH: aryl hydrocarbon
AHH: aryl hydrocarbon hydroxylase
AKT: protein kinase B
AOR: adjusted odds ratio
AP: apurinic/apyrimidinic
AP-1: activator protein-1
APA: American Psychiatric Association
APO: apolipoprotein
APO A-I: apolipoprotein A-I
APO B: apolipoprotein B
APO E: apolipoprotein E
ATP: adenosine triphosphate
B[a]P: benzo[a]pyrene
B[b]F: benzo[b]fluoranthene
B[k]F: benzo[k]fluoranthene
BAL: bronchoalveolar lavage
BER: base excision repair
BH: BCL-2 homology
BMI: body mass index
BPDE: benzo[a]pyrene-7,8-diol-9,10-epoxide
BSID: Bayley Scales of Infant Development
Ca^2+^: calcium ion
Cal/EPA: California Environmental Protection Agency
CAM: chorioallantoic membrane
CaMKII: Ca^2+^ calmodulin-dependent protein kinase II
CAN: Canadian Intense
CAT: chloramphenicol acetyltransferase
CB_1_: cannabinoid subtype 1
CDC: Centers for Disease Control and Prevention
CDK: cyclin-dependent kinase
CETP: cholesterol ester transfer protein
CHD: coronary heart disease
CI: confidence interval
CNS: central nervous system
CO: carbon monoxide
CO_2_: carbon dioxide
COPD: chronic obstructive pulmonary disease
CPS-I: Cancer Prevention Study I
CPS-II: Cancer Prevention Study II
CREB: cyclic adenosine monophosphate–response element binding protein
CRP: C-reactive protein
CS: conditioned stimulus
CSE: cigarette smoke extract
CT: computed tomography
CUZNSOD: copper zinc superoxide dismutase
CVD: cardiovascular disease
DEB: diepoxybutane
DHBMA: dihydroxybutyl mercapturic acid
DHβE: [^3^H]dihydro-beta-erythroidine
dL: deciliter
DMBA: 7,12-dimethybenz[a]anthracene
DRC: DNA repair capacity
DRZ: diagonal radioactive zone
DSB: double-strand break
DSBR: double-strand break repair
DSM-III-R: Diagnostic and Statistical Manual of Mental Disorders, 3rd ed. (rev)
DSM-IV: Diagnostic and Statistical Manual of Mental Disorders, 4th ed.
EB: 3,4-epoxybutene
ECSOD: extracellular superoxide dismutase
EF: etiologic fraction
ELF: epithelial lining fluid
ENOS: endothelial nitric oxide synthase
EPA: U.S. Environmental Protection Agency
EPC: endothelial progenitor cell
EPO: eosinophil-specific peroxidase
ERK: extracellular signal-regulated kinase
F-344: Fischer-344
FDA: U.S. Food and Drug Administration
Fe^2+^: ferrous ion
Fe^3+^: ferric ion
FEV_1_: forced expiratory volume in one second
FFA: free fatty acid
FR: fecundability ratio
FSH: follicle-stimulating hormone
FTC: U.S. Federal Trade Commission
FTND: Fagerström Test for Nicotine Dependence
FTQ: Fagerström Tolerance Questionnaire
FVC: forced vital capacity
g: gram
GABA: γ-aminobutyric acid
GC: gas chromatography
GCL: glutamate cysteine ligase
GGR: global genomic nucleotide excision repair
GLu-P-1: 2-amino-6-methyldipyrido[1,2-a:3′,2′-d] imidazole
GOLD: Global Initiative for Chronic Obstructive Lung Disease
GPX: glutathione peroxidase
GRX: glutathione reductase
GSH: glutathione
GSSG: oxidized glutathione
GST: glutathione-S-transferase
GTP: guanosine triphosphate
H/R: hypoxia/reperfusion
H_2_O: water
H_2_O_2_: hydrogen peroxide
H_2_S: hydrogen sulfide
HAT: histone acetyltransferase
Hb: hemoglobin
HbA_1c_: hemoglobin A_1c_
HBEC: human bronchial epithelial cell
HCA: heterocyclic amine
hCG: human chorionic gonadotropin
HCN: hydrogen cyanide
HCR: host cell reactivation
HDAC: histone deacetylase
HDL: high-density lipoprotein
HDLc: high-density lipoprotein cholesterol
Hg: mercury
HIV: human immunodeficiency virus
HONC: Hooked on Nicotine Checklist
HOX: hypohalous acids
HPG: hypothalamic-pituitary-gonadal
HPLC: high-performance liquid chromatography
HR23B: homologous recombinational repair group 23B
IARC: International Agency for Research on Cancer
IBF: intervillous blood flow
ICAM: intercellular adhesion molecule
ICD-10: International Statistical Classification of Diseases and Related Health Problems, Tenth Revision
Ig: immunoglobulin
IgM: immunoglobulin M
IL: interleukin
INOS: inducible nitric oxide synthase
IOM: Institute of Medicine
ISO: International Organization for Standardization
IUGR: intrauterine growth restriction
IVF: in vitro fertilization
kcal: kilocalorie
kg: kilogram
L: liter
LBW: low birth weight
LC: liquid chromotography
LDL: low-density lipoprotein
LDLc: low-density lipoprotein cholesterol
LH: luteinizing hormone
LMPCR: ligation-mediated polymerase chain reaction
LOD: logarithm of the odds
LPL: lipoprotein lipase
LUC: luciferase
m^3^: cubic meter
MAO: monoamine oxidase
MAPK: mitogen-activated protein kinase
MDM2: murine double minute 2
MDPH: Massachusetts Department of Public Health
MEK: mitogen-activated protein kinase kinase
mg: milligram
mGluR2/3: metabotropic glutamate receptor subtype 2/3
mGluR5: metabotropic glutamate receptor subtype 5
MHBMA: monohydroxybutenyl mercapturic acid
MI: myocardial infarction
mL: milliliter
mm: millimeter
MMP: matrix metalloproteinase
MMR: mismatch repair
MMS: methyl methanesulfonate
MNSOD: manganese superoxide dismutase
MPEP: 2-methyl-6-(phenylethynyl)pyridine
MPO: myeloperoxidase
mRNA: messenger RNA
MRP: multidrug-resistance protein
MS: mass spectrometry
MSCA: McCarthy Scales of Children’s Abilities
MT1: membrane-type 1
MTT: 3-(4,5-dimethylthiazol-2-yl)-2,5-diphenyltet-razolium bromide
μg: microgram
μm: micrometer
μmol: micromole
N_2_: nitrogen
NAB: N′-nitrosoanabasine
nAChR: nicotinic acetylcholine receptor
NADPH: reduced nicotinamide adenine dinucleotide phosphate
NAT: N-acetyltransferase
NATB: N′-nitrosoanatabine
NCI: National Cancer Institute
NDMA: N-nitrosodimethylamine
NER: nucleotide excision repair
NF-κB: nuclear factor-kappa B
ng: nanogram
NHLBI: National Heart, Lung, and Blood Institute
NIH: National Institutes of Health
NK: natural killer
nmol: nanomole
NMTCA: N-nitroso-2-methylthiazolidine 4-carboxylic acid
NNAL: 4-(methylnitrosamino)-1-(3-pyridyl)-1-butanol
NNK: 4-(methylnitrosamino)-1-(3-pyridyl)-1-butanone
NNN: N′-nitrosonornicotine
NO: nitric oxide
NO_2_: nitrogen dioxide
NOS: nitric oxide synthase
NPRO: N-nitrosoproline
NRC: National Research Council
NRT: nicotine replacement therapy
NSCLC: non-small-cell lung cancer
NST: nonstress test
NTCA: N-nitrosothiazolidine 4-carboxylic acid
O_2_: oxygen
O_2_•^−^: superoxide anion
OH: hydroxyl radical
ONOO^−^: peroxynitrite
ONOOH: peroxynitrous acid
OR: odds ratio
p: short arm of chromosome
PAD: peripheral arterial disease
PAF: platelet-activating factor
PAH: polycyclic aromatic hydrocarbon
PAI-1: plasminogen activator inhibitor-1
PARP: poly (adenosine diphosphate–ribose) polymerase
PAT: poly AT insertion/deletion polymorphism
PCASRM: Practice Committee of the American Society for Reproductive Medicine
PCNA: proliferating cell nuclear antigen
p-CREB: phosphorylated CREB
PdG: 1,N^2^-propanodeoxyguanosine
PDK1: 3-phosphoinositide–dependent protein kinase-1
PET: positron emission tomography
pg: picogram
pH_eff_: effective pH
PhIP: 2-amino-1-methyl-6-phenylimidazo[4,5-b] pyridine
PHS: U.S. Public Health Service
PI: protease inhibitor
PI-3K: phosphatidylinositol-3 kinase
PIP3: phosphatidylinositol 3,4,5-triphosphate
PKA: protein kinase A
PKB: protein kinase B (also known as AKT)
PKC: protein kinase C
PK_cs_: protein kinase catalytic subunit
PlGF: placental growth factor
PMN: polymorphonuclear neutrophil
pmol: picomole
p-MPPI: 4-(2′-methoxy-phenyl)-1-[2′-(n-2″-pyridinyl)- p-iodobenzamido]ethyl-piperazine
POB: pyridyloxobutyl
pol: polymerase
ppm: parts per million
PPROM: preterm premature rupture of membranes
PREP: potential reduced-exposure product
PRX: peroxiredoxin
q: long arm of chromosome
Q•^−^: semiquinone radical
RCT: reverse cholesterol transport
REC: homologous recombination
RI: resistance index
RNS: reactive nitrogen species
ROS: reactive oxygen species
RR: relative risk
S/D: systolic/diastolic
SAB: spontaneous abortion
SARS: severe acute respiratory syndrome
SCC: squamous cell carcinoma
SCE: sister chromatid exchange
SCENIHR: Scientific Commission on Emerging and Newly Identified Health Risks
SCLC: small-cell lung cancer
SD: standard deviation
SES: socioeconomic status
sFlt-1: soluble vascular endothelial growth factor receptor Flt-1
SGA: small for gestational age
sICAM: soluble intercellular adhesion molecule
SIDS: sudden infant death syndrome
SNO: S-nitrosothiol
SNP: single nucleotide polymorphism
SOD: superoxide dismutase
S-PMA: S-phenylmercapturic acid
STR: short tandem repeat
sVCAM: soluble vascular cell adhesion molecule
TBARS: thiobarbituric acid reactive substances
TCR: transcription-coupled repair
TFIIH: transcription initiation factor IIH
TGFβ: transforming growth factor-beta
TGRL: triglyceride-rich lipoprotein
Th1: helper T-cell subset 1
Th2: helper T-cell subset 2
TIMP: tissue inhibitor of metalloproteinase
T_max_: time to reach maximum blood concentrations of nicotine
TNFα: tumor necrosis factor-alpha
tPA: tissue plasminogen activator
TPM: total particulate matter
trans, anti-PheT: r-1,t-2,3,c-4-tetrahydroxy-1,2,3,4-tetrahydro- phenanthrene
Trp-P-1: 3-amino-1,4-dimethyl-5H-pyrido[4,3-b]indole
Trp-P-2: 3-amino-1-methyl-5H-pyrido[4,3-b]indole
TRX: thioredoxin
TSNA: tobacco-specific nitrosamine
tt-MA: trans,trans-muconic acid
TxB_2_: thromboxane B_2_
TxM: thromboxane metabolite
UCSF: University of California at San Francisco
UGT: uridine-5′-diphosphate-glucuronosyltransferase
US: unconditioned stimulus
USDHEW: U.S. Department of Health, Education, and Welfare
USDHHS: U.S. Department of Health and Human Services
USPSTF: U.S. Preventive Services Task Force
UV: ultraviolet
VCAM: vascular cell adhesion molecule
VEGF: vascular endothelial growth factor
VEGFR: vascular endothelial growth factor receptor
VLDL: very-low-density lipoprotein
V_max_: maximum velocity
VOC: volatile organic compound
VTA: ventral tegmental area
WHO: World Health Organization
XP (A–G): xeroderma pigmentosum (groups A–G)
γGT: γ-glutamyltranspeptidase