# Resources and Related Links

This section provides the names of resources and links in government and the private sector related to bone health. Links to non-Federal organizations do not constitute an endorsement of any organization by the Federal Government, and none should be inferred.

## Federal Government

Agency for Healthcare Research and Quality (AHRQ)

Osteoporosis publications and electronic information

http://www.ahrq.gov/news/pubsix.htm

Centers for Disease Control and Prevention (CDC)

Growing Stronger: Strength Training for Older Adults

http://www.cdc.gov/nccdphp/dnpa/physical/growing_stronger

PATCH—CDC’s Planned Approach to Community Health

http://www.cdc.gov/nccdphp/patch/index.htm

Physical Activity and Health: A Report of the Surgeon General

http://www.cdc.gov/nccdphp/sgr/sgr.htm

Powerful Bones, Powerful Girls Web Site

http://www.cdc.gov/powerfulbones/

http:/www.cdc.gov/powerfulbones/parents

Powerful Girls Calendar

http://www.cdc.gov/powerfulbones/games_fun/calendar_2004.pdf

Promoting Better Health for Young People Through Physical Activity and Sports

http://www.cdc.gov/nccdphp/dash/presphysactrpt/index.htm

VERB_™_. It’s what you do. Youth Media Campaign

http://www.cdc.gov/youthcampaign/

Wisewoman: Well-Integrated Screening and Evaluation for Women Across the Nation

http://www.cdc.gov/wisewoman

National Heart, Lung, and Blood Institute (NHLBI)

DASH (Dietary Approaches to Stop Hypertension) Eating Plan

http://www.nhlbi.nih.gov/health/public/heart/hbp/dash/

Hearts N’ Parks

http://www.nhlbi.nih.gov/health/prof/heart/obesity/hrt_n_pk/index.htm

National Cholesterol Education Program

http://www.nhlbi.nih.gov/about/ncep/

National Institute on Aging (NIA)

Exercise: A Guide from the National Institute on Aging

http://www.nia.nih.gov/exercisebook/index.htm

Exercise: A Video from the National Institute on Aging

http://www.niapublications.org/exercisevideo/index.asp

National Institute of Arthritis and Musculoskeletal and Skin Diseases (NIAMS)

Information Package—Ordering Information

http://www.niams.nih.gov/hi/index.htm#ip

Osteoporosis Prevention, Diagnosis, and Therapy

http://odp.od.nih.gov/consensus/cons/111/111_intro.htm

Osteoporosis: Progress and Promise

http://www.niams.nih.gov/hi/topics/osteoporosis/opbkgr.htm

National Institute of Child Health and Human Development (NICHD)

Milk Matters Educational Campaign

http://156.40.88.3/milk/milk.cfm

National Institute of Diabetes and Digestive and Kidney Diseases (NIDDK)

Sisters Together: Move More, Eat Better

http://www.niddk.nih.gov/health/nutrit/sisters/sisters.htm

National Institutes of Health (NIH)

Clinical Trials

http://www.ClinicalTrials.gov

NIH Osteoporosis and Related Bone Disease~National Resource Center

http://www.osteo.org/default.asp

President’s Council on Physical Fitness and Sports

The President’s Challenge

http://www.fitness.gov

http://www.presidentschallenge.org

U.S. Administration on Aging

Aging Internet Information Notes: Osteoporosis

http://www.aoa.gov/prof/notes/docs/osteoporosis.doc

U. S. Department of Agriculture (USDA)

Dietary Guidelines for Americans

http://www.usda.gov/cnpp/

School Meals

http://www.fns.usda.gov/cnd

USDA Food and Nutrition Service

http://www.fns.usda.gov

United States National Agricultural Library

http://www.nal.usda.gov

U. S. Department of Education (USDOE)

National Institute on Disability and Rehabilitation Research (NIDRR)

http://www.ed.gov/about/offices/list/osers/nidrr/index.html?src=mr

U.S. Department of Health and Human Services (HHS)

Dietary Guidelines for Americans

http://www.health.gov/dietaryguidelines

Healthier US Initiative

http://www.healthierus.gov

Healthfinder^®^ Gateway to Reliable Consumer Health Information on the Internet

http://www.healthfinder.gov

Healthy People in Healthy Communities: A Community Planning Guide Using Healthy People 2010

http://www.healthypeople.gov/publications/HealthyCommunities2001

Healthy People 2010 Toolkit

http://www.healthypeople.gov/state/toolkit

National Women’s Health Information Center

http://www.4woman.gov

STEPS to a Healthier US Initiative

http://www.healthierus.gov/steps/index.html

U.S. Food and Drug Administration (FDA)

Guidance on How to Understand and Use the Nutrition Facts Panel on Food Labels

http://www.cfsan.fda.gov/~dms/foodlab.html

U.S. Food and Drug Administration—FDA Consumer Magazine (10/02)

http://www.fda.gov/fdac/features/2002/502_men.html

## State Government

Association of State and Territorial Chronic Disease Program Directors

Osteoporosis Council

http://www.chronicdisease.org/Osteo_Council/osteo_about.htm

Osteoporosis Council: Contact information for state osteoporosis directors/coordinators

http://www.chronicdisease.org/Osteo_Council/osteo_membership.htm

Osteoporosis State Program Practices That Work

http://www.chronicdisease.org/whc/Practices_that_Work.pdf

Osteoporosis 2000: A Resource Guide for State Programs

http://www.chronicdisease.org/Osteo_Council/publications/Resource_Guide.pdf

State Osteoporosis Web Sites

Alabama Department of Public Health

http://www.adph.org/NUTRITION/default.asp?DeptId=115&TemplateId=2022&TemplateNbr=0

Arizona Osteoporosis Coalition

http://www.azoc.org

http://www.fitbones.org

California Department of Health Services, Arthritis and Osteoporosis Unit

http://www.dhs.ca.gov/osteoporosis

Colorado Department of Public Health and Environment: Osteoporosis Web Site

http://www.cdphe.state.co.us/pp/Osteoporosis/osteohom.html

Florida Osteoporosis Prevention and Education Program

http://www.doh.state.fl.us/family/osteo/default.html

Georgia Osteoporosis Initiative

http://www.gabones.com

Indiana Osteoporosis Prevention Initiative

http://www.in.gov/isdh/programs/osteo

Kentucky Office of Women’s Physical and Mental Health: Osteoporosis

http://chs.ky.gov/womenshealth/resourcecenter/Resources/osteoporosis.htm

Maryland Department of Health and Mental Hygiene

http://www.strongerbones.org

Michigan Department of Community Health

http://www.michigan.gov/mdch/0,1607,7-132-2940_2955_2978-,00.html

Mississippi State Department of Health

http://www.msdh.state.ms.us/msdhsite/index.cfm/13,0,225,html

Missouri Department of Health and Senior Services

http://www.dhss.state.mo.us/maop

New Jersey Department of Health and Senior Services

http://www.state.nj.us/health/senior/osteo

New York State Department of Health

http://www.health.state.ny.us/nysdoh/osteo/index.htm

Ohio Department of Health

http://www.odh.state.oh.us/odhprograms/osteo/osteo1.htm

Rhode Island Department of Health

http://www.health.ri.gov/disease/osteoporosis/index.htm

Tennessee Department of Health

http://www2.state.tn.us/health/healthpromotion/osteoporosis.html

Texas Department of Health: Osteoporosis Awareness and Education Program

http://www.tdh.state.tx.us/osteo

Virginia Department of Health

http://www.vahealth.org/nutrition/bones.htm

West Virginia Department of Health and Human Resources

http://www.wvdhhr.org/bph/oehp/hp/osteo/default.htm

## Non-Government

American Academy of Orthopaedic Surgeons (AAOS)

http://www.aaos.org

American Academy of Pediatrics (AAP)

Policy Statement on Calcium Requirements of Infants, Children, and Adolescents

http://aappolicy.aappublications.org/policy_statement/index.dtl#C

American Council on Exercise

http://www.acefitness.org

American College of Sports Medicine

http://www.acsm.org

American Dietetic Association (ADA)

http://www.eatright.org

American Society for Bone and Mineral Research (ASBMR)

http://www.asbmr.org

ASBMR Bone Curriculum Web Site

http://depts.washington.edu/bonebio/ASBMRed/ASBMRed.html

Bone Builders

http://www.bonebuilders.org/

BoneKEy-Osteovision ^®^

http://www.bonekey-ibms.org

Foundation for Osteoporosis Research and Education (FORE)

http://www.fore.org/

Growing Stronger: Strength Training for Older Adults

http://nutrition.tufts.edu/research/growingstronger

International Bone and Mineral Society (IBMS)

http://www.ibmsonline.org/

International Osteoporosis Foundation (IOF)

http://www.osteofound.org/

International Society for Clinical Densitometry (ISCD)

http://www.iscd.org/osteoblast/index.cfm

National Dairy Council (NDC)

http://www.nationaldairycouncil.org

National Osteoporosis Foundation (NOF)

http://www.nof.org

National Strength and Conditioning Association

http://www.nsca-lift.org

Osteoporosis and Bone Physiology, University of Washington

http://courses.washington.edu/bonephys

Osteoporosis Education, University of Washington

http://www.osteoed.org/faq/index.html#male

http://www.osteoed.org

Osteogenesis Imperfecta Foundation (OIF)

http://www.oif.org

The Paget Foundation (TPF)

http://www.paget.org

Shape-Up America!

http://www.shapeup.org

U.S. Bone and Joint Decade

http://www.usbjd.org