# Appendices

Appendix A Congressional Language Calling for Surgeon General’s Report

Appendix B How Do We Know What We Know: The Evidence Behind the Evidence

Appendix C Resources and Related Links