# References

1 Flegal KM, Carroll MD, Ogden CL, Curtin LR. Prevalence and trends in obesity among US adults, 1999–2008. JAMA. Jan 20. 2010;303(3):235-41. Epub 2010 Jan 13. [pmid: 20071471].
2 Ogden CL, Carroll MD, Curtin LR, Lamb MM, Flegal KM. Prevalence of high body mass index in US children and adolescents, 2007–2008. JAMA. Jan 20. 2010;303(3):242-9. Epub 2010 Jan 13. [pmid: 20071470].
3 Center for Disease Control. U.S. Obesity Trends. Trends by State 1985–2008. Available at: http://www.cdc.gov/obesity/data/trends.html. Accessed: January 19, 2010.
4 US Department of Health and Human Services. The Surgeon General’s Call to action to prevent and decrease overweight and obesity. (Rockville, MD). U.S. Department of Health and Human Services, Public Health Service, Office of the Surgeon General. 2001. Available from: U.S. GPO, Washington.
5 Flegal KM, Graubard BI, Williamson DF, Gail MH. Excess deaths associated with underweight, overweight, and obesity. JAMA. Apr 20. 2005;293(15):1861-7. [pmid: 15840860].
6 Clinical Guidelines on the Identification, Evaluation, and Treatment of Overweight and Obesity in Adults--The Evidence Report. National Institutes of Health. Obes Res. Sep. 1998;6(Suppl 2):51S-209S. [pmid: 9813653].
7 Nathan BM, Moran A. Metabolic complications of obesity in childhood and adolescence: more than just diabetes. Curr Opin Endocrinol Diabetes Obes. Feb. 2008;15(1):21-9. [pmid: 18185059].
8 Freedman DS, Kettel L, Serdula MK, Dietz WH, Srinivasan SR, Berenson GS. The Relation of Childhood BMI to Adult Adiposity: The Bogalusa Heart Study. Pediactrics. 2005;115:22-27.
9 Flegal KM, Carroll MD, Ogden CL, Johnson CL. Prevalence and trends in obesity among US adults, 1999–2000. JAMA. Oct 9. 2002;288(14):1723-7. [pmid: 12365955].
10 Ogden CL, Flegal KM, Carroll MD, Johnson CL. Prevalence and trends in overweight among US children and adolescents, 1999–2000. JAMA. Oct 9. 2002;288(14):1728-32. [pmid: 12365956].
11 Nielsen SJ, Popkin BM. Patterns and trends in food portion sizes, 1977–1998. JAMA. Jan 22. 2003;289(4):450-3. [pmid: 12533124].
12 Nielsen SJ, Siega-Riz AM, Popkin BM. Trends in energy intake in U.S. between 1977 and 1996: similar shifts seen across age groups. Obes Res. May. 2002;10(5):370-8. [pmid: 12006636].
13 Nielsen SJ, Popkin BM. Changes in beverage intake between 1977 and 2001. Am J Prev Med. Oct. 2004;27(3):205-10. [pmid: 15450632].
14 Sindelar R. Recess: Is It Needed in the 21st Century?. Early Childhood and Parenting (ECAP) Collaborative. University of Illinois. Urbana-Champaign. July. 2004. Available at http://ceep.crc.uiuc.edu/poptopics/recess.html.
15 CDC. Prevalence of overweight, obesity, and extreme obesity among adults: United States, Trends 1976--80 through 2005--2006. Hyattsville, MD. US Department of Health and Human Services, National Center for Health Statistics, CDC. 2008.
16 Rennie KL, Jebb SA. Prevalence of obesity in Great Britain. Obes Rev. Feb. 2005;6(1):11-2. [pmid: 15655034].
17 Stamatakis E, Primatesta P, Chinn S, Rona R, Falascheti E. Overweight and obesity trends from 1974 to 2003 in English children: what is the role of socioeconomic factors?. Arch Dis Child. Oct. 2005;90(10):999-1004. [pmid: 15956046].
18 Luo J, Hu FB. Time trends of obesity in pre-school children in China from 1989 to 1997. Int J Obes Relat Metab Disord. Apr. 2002;26(4):553-8. [pmid: 12075583].
19 Differences in Prevalence of Obesity Among Black, White, and Hispanic Adults --- United States, 2006—2008. MMWR. July 17. 2009;58(27):740-744. [pmid: 19609247].
20 Holt R, Peveler R. Obesity, Serious Mental Illness and Antipsychotic Drugs. Diabetes, Obesity and Metabolism. 2009;11(7):665-679.
21 National Association of State Mental Health Program Directors. Obesity and Prevention Strategies for Individuals with Serious Mental Illness, Technical Report. 2008.
22 Hoffmann V, Ahl J, Meyers A, Schuh L, Shults K, Collins D, Jensen L. Wellness Intervention for Patients with Serious and Persistent Mental Illness. Journal of Clinical Psychiatry. 2005;66(12):1576-1579. [pmid: 16401160].
23 McIntyre R, McElroy S, Konarski J, Soczynska J, Bottas Al, Castel S, Wilkins K, Kennedy S. Substance Use Disorders and Overweight/Obesity in Bipolar Disorder: Preliminary Evidence for Competing Addictions. Journal of Clinical Psychiatry. 2007;68:1352-1357. [pmid: 17915973].
24 National Association of State Mental Health Program Directors. Obesity and Prevention Strategies for Individuals with Serious Mental Illness, Technical Report. 2008.
25 Simon G, Von Korff M, Saunders K, Miglioretti D, Crane P, Van Belle G, Kessler R. Association Between Obesity and Psychiatric Disorders in the U.S Adult Population. Archives of General Psychiatry. 2006;63(7):824-830. [pmid: 16818872].
26 Varley C, McClellan J. Implications of Marked Weight Gain Associated with Atypical Antipsychotic Medications in Children and Adolescents. Journal of the American Medical Association. 2009;302(16):1811-1812. [pmid: 19861677].
27 Prentice AM, Jebb SA. Beyond body mass index. Obes Rev. Aug. 2001;2(3):141-7. [pmid: 12120099].
28 Freedman DS, Wang J, Thornton JC, Mei Z, Sopher AB, Pierson RN Jr, et al. Classification of body fatness by body mass index-for-age categories among children. Arch Pediatr Adolesc Med. Sep. 2009;163(9):805-11. [pmid: 19736333].
29 U.S. Department of Health and Human Services and U.S. Department of Agriculture. Dietary Guidelines for Americans 2005. 6th ed. Washington, DC. U.S. Government Printing Office. 200.
30 Clinical Guidelines on the Identification, Evaluation, and Treatment of Overweight and Obesity in Adults: The Evidence Report. http://www.nhlbi.nih.gov/guidelines/obesity/ob_gdlns.htm.
31 Romero-Corral A, Montori VM, Somers VK, Korinek J, Thomas RJ, Allison TG, Mookadam F, Lopez-Jimenez F. Association of bodyweight with total mortality and with cardiovascular events in coronary artery disease: a systematic review of cohort studies. The Lancet. 2006;368(9536):666-678.
32 Kuczmarski RJ, Ogden CL, Guo SS, Grummer-Strawn LM, Flegal KM, Mei Z, et al. CDC. Growth Charts for the United States: methods and development. Vital Health Stat. 2002. May. 2000;11(246):1-190.
33 Krebs NF, Himes JH, Jacobson D, Nicklas TA, Guilday P, Styne D. Assessment of child and adolescent overweight and obesity. Pediatrics. Dec. 2007;120(Suppl 4):S193-S228. [pmid: 18055652].
34 RC, Wright JA, Pepe MS, Seidel KD, Dietz WH. Predicting obesity in young adulthood from childhood and parental obesity. N Engl J Med. 1997;37(13):869-873.
35 Serdula MK, Ivery D, Coates RJ, Freedman DS, Williamson DF, Byers T. Do obese children become obese adults? A review of the literature. Prev Med. 1993;22:167-177. [pmid: 8483856].
36 Dietz W. Health consequences of obesity in youth: Childhood predictors of adult disease. Pediatrics. 1998;101:518-525. [pmid: 12224658].
37 Esposito L, Fisher JO, Mennella JA, Hoelscher DM, Huang TT. Developmental perspectives on nutrition and obesity from gestation to adolescence. Prev Chronic Dis. 2009;6(3). http://www.cdc.gov/pcd/issues/2009/jul/09_0014.htm. Accessed [01/26/2009].
38 Berenson GS, Srinivasan SR, Bao W, Newman WP 3rd, Tracy RE, Wattigney WA. Association between multiple cardiovascular risk factors and atherosclerosis in children and young adults. The Bogalusa Heart Study. N Engl J Med. Jun 4. 1998;338(23):1650-6. [pmid: 9614255].
39 Center for Disease Control. Diabetes Data & Trends. Number (in Millions) of Civilian/Noninstitutionalized Persons with Diagnosed Diabetes, United States, 1980–2006. Available at http://www.cdc.gov/diabetes/statistics/prev/national/figpersons.htm. Accessed January 19, 2010.
40 Centers for Disease Control and Prevention. National diabetes fact sheet: general information and national estimates on diabetes in the United States, 2007. Atlanta, GA. U.S. Department of Health and Human Services, Centers for Disease Control and Prevention. 2008.
41 Visscher TL, Seidell JC. The public health impact of obesity. Annu Rev Public Health. 2001;22:355-75. [pmid: 11274526].
42 Liese AD, D'Agostino RB Jr, Hamman RF, Kilgo PD, Lawrence JM, Liu LL, et al. The burden of diabetes mellitus among US youth: prevalence estimates from the SEARCH for Diabetes in Youth Study. Pediatrics. Oct. 2006;118(4):1510-8. [pmid: 17015542].
43 Bell RA, Mayer-Davis EJ, Beyer JW, D'Agostino RB Jr, Lawrence JM, Linder B, et al. Diabetes in non-Hispanic white youth: prevalence, incidence, and clinical characteristics: the SEARCH for Diabetes in Youth Study. Diabetes Care. Mar. 2009;32(Suppl 2):S102-S111. [pmid: 19246575].
44 Bell RA, Mayer-Davis EJ, Beyer JW, D'Agostino RB Jr, Lawrence JM, Linder B, et al. Diabetes in non-Hispanic white youth: prevalence, incidence, and clinical characteristics: the SEARCH for Diabetes in Youth Study. Diabetes Care. Mar. 2009;32(Suppl 2):S102-S111. [pmid: 19246575].
45 Petitti DB, Klingensmith GJ, Bell RA, Andrews JS, Dabelea D, Imperatore G, et al. Glycemic control in youth with diabetes: the SEARCH for diabetes in Youth Study. J Pediatr. Nov. 2009;155(5):668-72. [pmid: 19643434].
46 Arenz S, Ruckerl R, Koletzko B, et al. Breast-feeding and childhood obesity—a systematic review. [Review]. Int J Obes Relat Metab Disord: Journal of the International Association for the Study of Obesity. 2004;28:1247-1256.
47 Division of Nutrition and Physical Activity. Research to Practices Series No 3: Does Drinking Beverages with Added Sugars Increase the Risk of Overweight?. Atlanta. Centers for Disease Control and Prevention. 2006.
48 Coon KA, Tucker KL. Television and children's consumption patterns. A review of the literature. Minerva Pediatr. 2002;54:423-436. [pmid: 12244280].
49 Björntorp P. Do stress reactions cause abdominal obesity and comorbidities?. Obes Rev. 2001;2(2):73-86. [pmid: 12119665].
50 Braveman P. A health disparities perspective on obesity research. Prev Chronic Dis. 2009;6(3).
51 U.S. Department of Health and Human Services. U.S. Department of Agriculture. Dietary Guidelines for Americans, 2005. 6th edition. Washington, D.C. U.S. Government Printing Office. January. 2005.
52 Dennison BA. Television Viewing and Television in Bedrooms Associated with Overweight Risk Among Low-Income Preschool Children. Pediatrics. 2002;109(9):1028-1035. [pmid: 12042539].
53 2008 Physical Activity Guidelines for Americans. Available at http://www.health.gov/paguidelines/guidlines/default.aspx. Accessed December 31, 2009.
54 Rideout V, Vanderwater E, Wartella E. Kaiser Family Foundation; Generation M2: Media in the Lives of 8- to 18-Year-Olds. January 20. 2010.
55 Kaiser Family Foundation. Zero to six: electronic media in the lives of infants, toddlers and preschoolers. Menlo Park (CA). The Henry J. Kaiser Family Foundation. 2003.
56 Forum on Child and Family Statistics. America’s Children: Key National Indicators of Well-Being 2009. Available at http://www.childstats.gov/americaschildren/famsoc3.asp. Accessed December 29, 2009.
57 Centers for Disease Control and Prevention. Guidelines for school and community programs to promote lifelong physical activity among young people. MMWR. 1997;46:1-36.
58 Centers for Disease Control and Prevention. Guidelines for school health programs to promote lifelong healthy eating. MMWR. 1996;45:1-41.
59 Gortmaker SL, Peterson K, Wiecha J, Sobol AM, Dixit S, Fox MK, Laird N. Reducing obesity via a school-based interdisciplinary intervention among youth: Planet Health. Arch Pediatr Adolesc Med. 1999;53(4):409-418. [pmid: 10201726].
60 Robinson TN. Reducing children’s television viewing to prevent obesity: a randomized controlled trial. JAMA. 1999;282(16):1561-1567. [pmid: 10546696].
61 Coleman KJ, Tiller CL, Sanchez J, Heath EM, Sy O, Milliken G, Dzewaltowski DA. Prevention of the epidemic increase in child risk of overweight in low-income schools: The El Paso Coordinated Approach to Child Health. Arch Pediatr Adolesc Med. 2005;159(3):217-224. [pmid: 15753263].
62 Economos CD, Hyatt RR, Goldberg JP, Must A, Naumova EN, Collins JJ, Nelson ME. A community intervention reduces BMI z-score in children: Shape Up Somerville first year results. Obesity. 2007;5(5):1325-1336. [pmid: 17495210].
63 Foster GD, Sherman S, Borradaile KE, Grundy KM, Vander Veur SS, Nachmani J, Karpyn A, Kumanyika S, Shultz J. A policy-based school intervention to prevent overweight and obesity. Pediatrics. 2008;121(4):e794-e802. [pmid: 18381508].
64 Gutin B, Yin Z, Johnson M, Barbeau P. Preliminary findings of the effect of a 3-year after-school physical activity intervention on fitness and body fat: The Medical College of Georgia Fitkid Project. Int J Pediatr Obes. 2008;3(Suppl 1):3-9. [pmid: 18278626].
65 National Association for Sport and Physical Education. Understanding the difference: is it physical education or physical activity?. Reston (VA). National Association for Sport and Physical Education. 2005. Available at http://www.aahperd.org/naspe/publications/teachingTools/PAvsPE.cfm. Accessed on December 31, 2009.
66 National Association for Sport and Physical Education. Comprehensive school physical activity programs. Reston (VA). National Association for Sport and Physical Education. 2008. Available at http://www.aahperd.org/naspe/standards/upload/Comprehensive-School-Physical-Activity-Programs-2008.pdf. Accessed on December 31, 2009.
67 Lee SM, Burgeson CR, Fulton JE, Spain CC. Physical education and physical activity: results from the School Health Policies and Programs Study 2006. J Sch Health. 2007;77(8):435-463. [pmid: 17908102].
68 Centers for Disease Control and Prevention. Youth Risk Behavior Surveillance — United States, 2007. Surveillance Summaries, 2008. MMWR. 2008;57:1-131.
69 Anderson LM, Quinn TA, Glanz K, Ramirez G, Kahwati LC, Johnson DB, Buchanan LR, Archer WR, Chattopadhyay S, Kalra GP, Katz DL. Task Force on Community Preventive Services. The effectiveness of worksite nutrition and physical activity interventions for controlling employee overweight and obesity: a systematic review. Am J Prev Med. Oct. 2009;37(4):340-57. Review. [pmid: 19765507].
70 Finkelstein EA, Trogdon JG, Cohen JW, Dietz W. Annual medical spending attributable to obesity: payer-and service-specific estimates. Health Affairs (Millwood). Sep-Oct. 2009;28(5):w822-31. Epub 2009 Jul 27.
71 Thorpe KE, Florence CS, Howard DH, Joski P. The impact of obesity on rising medical ppending. Health Affairs (Millwood). 2004;W4:480-486.
72 Aldana SG. Financial Impact of Health Promotion Programs: A comprehensive review of the literature. Am J Health Promot. 2001;15(5):296-320. [pmid: 11502012].
73 Chapman LS. Meta-evaluation of worksite health promotion economic return studies: 2005 Update. Am J Health Promot. 2005;19(6):1-11.
74 Goetzel RZ, Ozminkowski RJ. The health and cost benefits of work site health-promotion programs. Annu Rev Public Health. 2008;29:303-323. [pmid: 18173386].
75 Pelletier KR. A review and analysis of the clinical and cost-effectiveness studies of comprehensive health promotion and disease management programs at the worksite: 2000–2004 update (VI). J Occup Environ Med. 2005;47(10):1051-1058. [pmid: 16217246].
76 Center for Disease Control CDC’s LEAN Works!. A workplace obesity prevention program. Available at http://www.cdc.gov/LEANWorks/. Accessed on December 31, 2009.
77 Phillips RL Jr, Bazemore AW, Dodoo MS, Shipman SA, Green LA. Family physicians in the child health care workforce: opportunities for collaboration in improving the health of children. Pediatrics. 2006;188(3):1200-6. [pmid: 16951016].
78 Whitlock EP, O’Connor EA, Williams SB, Beil TL, Lutz KW. Effectiveness of weight management interventions in children: A targeted systematic review for the USPSTF. Pediatrics. 2010. [doi: 10.1542/peds.2009-1955].
79 Khan L, Sobush K, Keener D, Goodman K, Lowry A, Kakietek J, Zaro S. Recommended community strategies and measurements to prevent obesity in the United States. MMWR. 2009;58:RR-7.