# Closing Statement and Charge from the Surgeon General

To stop the obesity epidemic in this country, we must remember that Americans will be more likely to change their behavior if they have a meaningful reward—something more than just reaching a certain weight or BMI measurement. The real reward has to be something that people can feel and enjoy and celebrate. That reward is invigorating, energizing, joyous health. It is a level of health that allows people to embrace each day and live their lives to the fullest—without disease, disability, or lost productivity.

Good nutrition, regular physical activity, and stress management significantly contribute to achieving optimal health. By practicing these healthy lifestyle behaviors, excess weight is prevented, weight loss is sustained, and strength and endurance are achieved. This is the reward we need to communicate to the American public. We must help our communities make the important and life-saving connection between being healthy, fit and living well.

We are indeed at a crossroads. The “old normal” was to stress the importance of attaining recommended numbers for weight and BMI. Although these numbers are important measures of disease and disability, the total picture is much bigger. It involves the creation of a “new normal”—an emphasis on achieving an optimal level of health and well-being. People want to live long and live well, and they are making their voices heard across this nation. Today’s obesity epidemic calls for committed, compassionate citizens to mobilize and demand the health and well-being they so richly deserve. I have heard this call to arms, and I am honored to do everything in my power to help Americans live long and live well.