# Acknowledgements

The Surgeon General’s Vision for a Healthy and Fit Nation was developed by the Office of the Surgeon General. Critical scientific oversight and writing support was provided by the Centers for Disease Control and Prevention (CDC) Division of Nutrition, Physical Activity, and Obesity. Data and analysis was provided by the (CDC) National Center for Health Statistics. Substantial scientific input was also provided by the National Institute of Diabetes and Digestive and Kidney Diseases. Technical and editorial support was also provided by numerous U.S. Department of Health and Human Services subject matter experts.