# Results

## Study Identification and Characteristics

As delineated in the PRISMA diagram (Figure 1), there were 1274 citations identified upon our literature search with 1198 citations remaining after duplicates were removed. After title and abstract and full text review, 271 citations remained that met inclusion and exclusion criteria. One-hundred seven of these citations were duplicate reports, had overlapping populations with other studies in the search, or were summary studies without unique data not already encompassed in the search. As such, 146 unique studies were included in this technology assessment, as were 18 supplemental studies.

In each section we report the number of studies and their univariate analyses that evaluated for rejection, graft survival, and patient survival. Information on the studies germane to multivariate analyses is reported in those subsections.

Key characteristics of each unique study may be found in Appendix C. Of the 146 unique studies included in this report, 119 (82 percent) were retrospective observational studies, 15 (10 percent) for prospective observational studies and 12 (8 percent) for clinical controlled trials. Over half of the studies included in this technology assessment were conducted before 1984, and fewer than ten percent of the studies were conducted after 1992. Hundred and twelve of 146 (77 percent) of the studies did not account for confounders by using statistical methods such as propensity score adjustment or randomization. Seventy-three percent of the studies did not report demographics for the population of interest for this technology assessment. Over one-third of the included studies were conducted in the United States, and fewer than one percent of the studies were multicenter studies. For the assessments of the strength of the body of evidence for each key question, see Appendix D.

## Evaluation of Good Quality Studies

Of the 146 unique studies included in the evaluation of the impact of transfusion, only five studies were rated as good quality studies, all of which were clinical controlled trials.14–18 Amongst the five good quality studies, three (60 percent) evaluated the impact of donor specific transfusion on renal allograft outcomes (i.e. rejection, graft and patient survival), while the remaining two (40 percent) evaluated protocol transfusion (therapeutic transfusion given when necessary). (Table 5–Table 7) All studies provided outcomes on graft rejection, graft and patient survival.

Nine analyses reported results on rejection frequency, defined as the percent of patients treated for rejection, patients with at least one rejection episode or rejection rate per patient. Of the five analyses reporting on the statistical significance of their results, two found significant reductions in rejection episodes in patients receiving transfusion (one for DST and the other for random transfusion), one found the use of DST significantly increased total number of rejection episodes, and the remaining two found no significant differences in transfused patients as compared to the control group. (Table 5)

Of all these good quality studies, only one study provided a definition of graft survival.16 Two of the five studies reported the statistical significance of the results. While one of them found that transfusion significantly improved 1-year and maximum duration of graft survival, 17 the other study found that donor-specific transfusions did not have a significant impact on 1-year graft survival (which was the maximum duration as well), although there was a trend towards improvement with the use of donor-specific transfusions.18 The remaining three studies that did not report statistical significance of the results found that transfusions (regardless transfusion types) had a beneficial to neutral direction of effect on 1-year and maximum duration graft survival.14–16(Table 6).

Two of the five studies15,17 reported three analyses in which transfusions did not have any significant effect on 1-year patient survival while one of the studies17 found no significant impact on maximum duration patient survival as well. The other three studies found donor-specific transfusions to have a neutral effect on 1–year and maximum duration of patient survival, but the significance of the results was not reported. (Table 7)

Table 5 Results of good quality studies on rejection

Study, Year | Intervention | Graft Rejection Definition | Graft Rejection (%) | P-value
Marti HP et al, 2006 | DST (n=55) Control (n=55) | Patients treated for acute renal allograft rejection during the first year after living renal allograft transplantation | 6 14 | NR
Hiesse C et al, 2001a^*^ Hiesse C et al, 2001b^*^ | DR-matched transfusion (n=31) No Transfusion (n=36) DR-mismatched transfusion (n=39) No Transfusion (n=36) | Patients treated for biopsy-confirmed acute rejection episodes during the six-month post-transplant period Patients treated for biopsy-confirmed acute rejection episodes during the six-month post-transplant period | 19 33 33 33 | NR NR
Alexander JW et al, 1999^§^ | DST (n=115) Control (n=97) DST (n=115) Control (n=97) | Patients with biopsy-confirmed rejection episodes Patients reporting at least one rejection | 70 56 52 45 | NR 0.32
Opelz G et al, 1997 § | Transfusion (n=205) No transfusion (n=218) Transfusion (n=205) No transfusion (n=218) | Patients not treated for rejection during the first year Patients with ≥ 1 rejection episodes during the first year | 46 45 16 25 | 0.86 0.03
Sharma RK et al, 1997^§^ | DST (n=15) Non-DST (n=15) DST (n=15) Non-DST (n=15) | Patient with biopsy-confirmed rejection episodes Patient with biopsy-confirmed rejection episodes | 4^†^ 16^†^ 1.1^‡^ 0.26^‡^ | < 0.01 < 0.01

* A transfusion was considered HLA-DR matched if a minimum of one HLA-DRB1 allele was present in the transfusion donor as well as recipient

† denotes total number of rejection episodes not percentage of patient with rejection episode

‡ denotes rejection rate per patient not percentage of patient with rejection episodes

§ Rejection outcomes included in the above table provided some of the rejection endpoints that were evaluated in the study

DR=HLA-DR, DST=donor-specific transfusion, n=number of patients in the study group, NR=not reported, NS=not significant

Table 6 Results of good quality studies on graft survival

Study, Year | Intervention | Graft Survival Definition | 1-year graft survival (%) | P-value | Max Duration | Max duration graftsurvival (%) | P-value
Marti HP et al, 2006 | DST (n=55) Control (n=55) | NR | 98 89 | NR | 6 years | 98 82 | NR
Hiesse C et al, 2001a^*^ Hiesse C et al, 2001b^*^ | DR-matched transfusion (n=31) No Transfusion (n=36) DR-mismatched transfusion (n=39) No Transfusion (n=36) | NR NR | 90 92 92 92 | NR NR | 5 years 5 years | 79 80 84 80 | NR NR
Alexander JW, 1999 | DST (n=115) Control (n=97) | Death-censored graft survival | 95 95 | NR | 2 years | 90 90 | NR
Opelz G et al, 1997^*^ | Transfusion (n=205) No Transfusion (n=218) | NR | 90 82 | 0.02 | 5 years | 79 70 | 0.03
Sharma RK et al, 1997 | DST (n=15) Non-DST (n=15) | NR | 86 75 | > 0.05 | 1 year | 86 75 | > 0.05

* Results of multivariate analyses were listed in Table 12

DR=HLA-DR, DST=donor-specific transfusion, n=number of patients in the study group, NR=not reported, NS=not significant

Table 7 Results of good quality studies on patient survival

Study, Year | Intervention | Patient Survival Definition | 1-year patient survival (%) | P-value | Max Duration | Max duration patient survival (%) | P-value
Marti et al, 2006 | DST (n=55) Control (n=55) | NR | 100 100 | NR | 6 years | 100 93 | NR
Hiesse C et al, 2001a Hiesse C et al, 2001b | DR-matched transfusion (n=31) No Transfusion (n=36) DR-mismatched transfusion (n=39) No Transfusion (n=36) | NR NR | 100 100 97 100 | NS NS | 5 years 5 years | 86 92 97 92 | NR NR
Alexander JW, 1999 | DST (n=115) Control (n=97) | NR | 98 100 | NR | 2 years | 97 98 | NR
Opelz G et al, 1997 | Transfusion (n=205) No transfusion (n=218) | NR | 98 96 | 0.37 | 5 years | 91 90 | 0.54
Sharma RK et al, 1997 | DST (n=15) Non-DST (n=15) | NR | 92 86 | NR | 1 year | 92 86 | NR

DR=HLA-DR, DST=donor-specific transfusion, n=number of patients in the study group, NR=not reported, NS=not significant

Figure 1 PRISMA Diagram

## Key Question 1a Do red blood cell transfusions prior to renal transplant impact allograft rejection/survival and what is the magnitude of that effect relative to other factors (e.g., pregnancy, prior transplantation?)

### Univariate Analysis Results

One-hundred six unique studies were included in the evaluation of the impact of pretransplant transfusion on renal allograft outcomes.14–81,81–119

Nine of the 106 studies were clinical controlled trials, 12 were prospective observational studies, and 85 were retrospective observational studies, of which 5 (4.8 percent), 10 (9.4 percent), and 91 (85.8 percent) were rated as good, fair, and poor quality, respectively. Of the 401 analyses reported from the studies, 74 percent were from retrospective studies, with the remaining split between controlled trials (13 percent) and prospective studies (13 percent). Forty-seven (12 percent), 278 (69 percent), 76 (19 percent) analyses included results for graft rejection, graft survival and patient survival, respectively (Table 8).

### Rejection14–21,23,30,35,37,38,42,44,47,50,65,68–71,73,76,89,92,94,95,97,98,102–104,108,113,118

Forty-seven analyses reported results on rejection outcomes, of which 25 analyses reported on the statistical significance of their results. Of the 25 analyses, 22 (88.0 percent) found either a significant reduction in rejection resulting from transfusion or no significant effect. To be considered in this evaluation, studies had to provide a p-value, 95 percent confidence interval, or explicitly say whether or not statistical significance was achieved. Thus, we concluded that transfusions had a significant beneficial to no significant effect on rejection outcomes and graded the strength of the body of evidence as low.

When evaluating the overall direction of transfusion effects on rejection outcomes, 36 of the 47 analyses (76.6 percent) found either a decreased risk or no change in rejection resulting from transfusion. Thus, we concluded that transfusions had a beneficial to neutral effect on rejection outcomes and graded the strength of the body of evidence as insufficient because in addition to the standard limitations within this body of evidence, it was difficult to gauge the magnitude of the effect from the available data (Table 9). To be classified as either decreasing or increasing the risk of rejection with transfusion, data had to be available within the study showing a direction of change or the text needed to note that the risk was either decreased or increased. Statistical significance was not evaluated in this directionality evaluation.

### Graft Survival14–20,22–45,47–68,70,72–86,88,90–120

Fifty-five and sixty-five analyses performed statistical evaluations to determine if transfusions had a significant effect on 1-year and maximum duration graft survival, respectively. All available analyses reported either a significant increase or no significant effect on 1-year and maximum duration graft survival. None of the analyses found transfusion to have a significant negative impact on 1-year and maximum duration of graft survival. Thus, we concluded that transfusion had a significant beneficial to no significant effect on 1-year and maximum duration graft survival, and we graded the strength of the body of evidence for such effects to be low.

One-hundred thirty-two and one-hundred forty-six analyses performed evaluations of the magnitude of 1-year and maximum duration graft survival, respectively. One-hundred twenty-eight (96.9 percent) and one-hundred thirty-eight (94.5 percent) analyses reported either a >10 percent increase or a small change within 10 percent in either direction in survival on 1-year and maximum duration graft survival. Thus, we concluded that transfusion had a beneficial to neutral effect on 1-year and maximum duration graft survival, and we graded the strength of the body of evidence for such effects to be low (Table 10).

### Patient Survival14–18,23,29,33,37,38,50,53,59,62,65,71,77,86,88,89,93,95,99,104,106,108,111–113,118,120,121

Sixteen and eighteen analyses performed statistical evaluations to determine if transfusions had a significant effect on 1-year and maximum duration patient survival, respectively. All available analyses reported either a significant increase or no significant effect on 1-year and maximum duration patient survival. None of the analyses found transfusion to have a significant negative impact on 1-year and maximum duration of patient survival. Thus, we concluded that transfusion has a significant beneficial to neutral effect on 1-year and maximum duration patient survival, and we graded the strength of the body of evidence for such effects to be low.

Thirty-five and forty-one analyses performed evaluations of the magnitude of 1-year and maximum duration patient survival, respectively. Thirty-three (94.3 percent) and thirty-seven (90.2 percent) analyses reported either a >10 percent increase or a small change within 10 percent in either direction in survival on 1-year and maximum duration patient survival. Thus, we concluded that transfusion has a beneficial to neutral effect on 1-year and maximum duration patient survival, and we graded the strength of the body of evidence for such effects to be low (Table 10).

### Multivariate Analysis Results

Three analyses 122,123 evaluated prior transplantation as a covariate in multivariate analysis assessing for rejection. In two (66.7 percent) analyses, prior transplantations were independent predictors of increasing chances of rejection. The final analysis found that prior transplantation was not an independent predictor of rejection in either direction. Two analyses113,123 evaluated prior transfusion as a covariate in multivariate analysis assessing for rejection. In both (100.0 percent) analyses, transfusions were independent predictors of decreasing rejection. One (100 percent) analysis122 evaluated prior pregnancy as a covariate in multivariate analysis assessing for rejection. Prior pregnancy was an independent predictor of decreasing rejection (Table 11).

Twelve analyses84,87,123–128 evaluated prior transplantation as a covariate in multivariate analysis assessing for graft survival. In six (50.0 percent) analyses, prior transplantations were independent predictor of worsening graft survival. The other analyses found that prior transplantations were not independent predictors of graft survival in either direction. Ten analyses15,17,71,87,117,123,125,127 evaluated prior transfusion as a covariate in multivariate analysis assessing for graft survival. In five (50.0 percent) analyses,124,126 transfusions were independent predictors of benefiting graft survival. The other analyses found that prior transfusions were not independent predictors of graft survival in either direction. Four analyses evaluated prior pregnancy as a covariate in multivariate analysis assessing for graft survival. In one (25.0 percent) analyses, pregnancy was an independent predictor of worsening graft survival. In this analysis, the covariate that was an independent predictor was three or more pregnancies. The other analyses found that prior pregnancies were not independent predictors of graft survival in either direction (Table 12).

Seven analyses123,124,127,128 evaluated prior transplantation as a covariate in multivariate analysis assessing for patient survival. In one (14.3 percent) analysis, prior transplantation was an independent predictor of worsening patient survival. The other analyses found that prior transplantations were not independent predictors of patient survival in either direction. One analysis127 evaluated prior transfusion as a covariate in multivariate analysis assessing for patient survival. This analysis found that prior transplantation was not an independent predictor of patient survival in either direction. No analyses evaluated prior pregnancy as a covariate in multivariate analysis assessing for patient survival (Table 13).

In summary, prior transplant may induce increases in rejection and worsening graft survival or no significant changes may occur in these outcomes but benefits are unlikely to result from these outcomes. Transfusions may be related to decreasing rejection and benefiting graft survival or no significant changes may occur but it is unlikely that these outcomes would worsen as a result of transfusion. Prior pregnancy had very scant data and could not be well assessed.

Table 8 Insight into body of literature: Transfusion versus no transfusion (KQ 1a)

| Rejection | Graft Survival | Patient Survival | Validity of Studies
KQ 1a. Transfusion versus No transfusion | CCT 9 Analyses | CCT 1-year – 12 Analyses Max time – 13 Analyses | CCT 1-year – 8 Analyses Max time – 8 Analyses | Good 5 studies
KQ 1a. Transfusion versus No transfusion | POBS 1 Analysis | POBS 1-year – 24 Analyses Max time – 27 Analyses | POBS 1-year – 1 Analysis Max time – 3 Analyses | Fair 10 studies
KQ 1a. Transfusion versus No transfusion | ROBS 37 Analyses | ROBS 1-year – 96 Analyses Max time – 106 Analyses | ROBS 1-year – 26 Analyses Max time – 30 Analyses | Poor 91 studies

CCT=clinical controlled trial, KQ=key question, Max=maximum followup time, POBS=prospective observational studies, ROBS=retrospective observational studies

Table 9 Impact of transfusions (any type) on rejection (KQ 1a)

Impact of Transfusions on: | Significant Reduction in Rejection | No Significant Effect on Rejection | Significant Increases in Rejection | Decreased Risk of Rejection^*^ | No Change in Rejection^†^ | Increased Risk of Rejection^*^
Rejection at Any Time Point | 9/25 (36.0%) | 13/25 (52.0%) | 3/25 (12.0%) | 28/47 (59.6%) | 8/47 (17.0%) | 11/47 (23.4%)

* Data either showing a decrease/increase of any magnitude or notation in text stating a decrease/increase

† Data either showing no difference, or notation in text stating no change

Table 10 Impact of transfusions (any type) on graft and patient survival (KQ1a)

Impact of transfusions on: | Significant Increases in Survival | No Significant Effect | Significant Decreases in Survival | >10% Increase in Survival | 10% to −10% Change in Survival | >10% Decrease in Survival
1-Year Graft Survival | 29/55 (52.7%) | 26/55 (47.3%) | 0/55 (0.0%) | 65/132 (49.2%) | 63/132 (47.7%) | 4/132 (3.1%)
Max Duration Graft Survival | 30/65 (46.2%) | 35/65 (53.8%) | 0/65 (0.0%) | 76/146 (52.0%) | 62/146 (42.5%) | 8/146 (5.5%)
1-Year Patient Survival | 0/16 (0.0%) | 16/16 (100%) | 0/16 (0.0%) | 1/35 (2.9%) | 32/35 (91.4%) | 2/35 (5.7%)
Max Duration Patient Survival | 1/18 (5.6%) | 17/18 (94.4%) | 0/18 (0.0%) | 8/41 (19.5%) | 29/41 (70.7%) | 4/41 (9.8%)

Table 11 Multivariate results: the impact of transfusions on rejection (KQ 1a)

Study, Year Total N | Analysis Type | Covariate | Outcome Evaluated | Multivariate Results | Significant Effect
Impact of previous transplant
Reed A, 1991 N=127 | Poisson^*^ | Prior transplant | Rejection episodes | NR, P=0.40 | NA
Sanfilippo F, 1986 N=3811 | Cox^†^ | Prior failed graft (1) | Irreversible graft rejection | RR 1.409, P=0.0002 | Transplant worsens rejection
Sanfilippo F, 1986 N=3811 | Cox^†^ | Prior failed grafts (≥2) | Irreversible graft rejection | RR 1.884, P=0.0006 | Transplant worsens rejection
Impact of pretransplant transfusions
Waanders MM, 2008 N=118 | Cox^†^ | Pretransplant protocol blood transfusion | Severe acute rejection | HR 0.385 (0.186–0.796), P=0.010 | Transfusion benefits rejection
Sanfilippo F, 1986 N=3811 | Cox^†^ | No pretransplant transfusion | Irreversible graft rejection | RR 1.377, P=0.0003 | Transfusion benefits rejection
Impact of pregnancy
Reed A, 1991 N=127 | Poisson^*^ | Pregnancy | Rejection episodes | NR, P=0.017 | Pregnancy benefits rejection

* Poisson multivariate analysis

† Cox proportional hazards regression analysis

HR=hazard ratio; N=number of patients in analysis; NR=not reported; NS=not significant; RR=relative risk

Table 12 Multivariate results: the impact of transfusions on graft survival (KQ1a)

Study, Year Total N | Analysis Type | Covariate | Outcome Evaluated | Multivariate Results | Significant Effect
Impact of previous transplant
Tang H, 2008 N=2882 | Cox^*^ | Previous transplant | Graft failure | HR 2.29 (1.73–3.02), P<0.001 | Transplant worsens graft survival
Peters TG, 1995 Study period: 1982–1991 N=17,937 | Cox^*^ | Retransplant | Graft survival | RR 1.35, P<0.0001 | Transplant worsens graft survival
Poli F, 1995 N=416 | Cox^*^ | Graft number (first transplant, re-transplant) | Graft survival | RR 1.4 (0.5–4.0), P=0.3 | NA
Sautner T, 1994 N=146 | Stepwise logistic regression | History of prior transplants (1) | Graft loss | RR 1.4, P=0.005 | Transplant worsens graft survival
Sautner T, 1994 N=146 | Stepwise logistic regression | History of prior transplants (≥2) | Graft loss | RR 0.21×10^5^ P=0.005 | Transplant worsens graft survival
Madrenas J, 1988 N=287 | Cox^*^ | Second transplant | Graft survival | RR 1.179, P=NS | NA
Madrenas J, 1988 N=287 | Cox^*^ | ≥3 transplants | Graft survival | RR 1.606, P=NS | NA
CMTSG, 1986 CyA^†^ N=142 | Cox^*^ | Prior transplant | Graft loss | RR 0.60, P=NS | NA
CMTSG, 1986 Control^‡^ N=149 | Cox^*^ | Prior transplant | Graft loss | RR 1.33, P=NS | NA
Sanfilippo F, 1986 N=3811 | Cox^*^ | Prior failed graft (1) | Graft failure | RR 1.217, P=0.011 | Transplant worsens graft survival
Sanfilippo F, 1986 N=3811 | Cox^*^ | Prior failed grafts (≥2) | Graft failure | RR 1.506, P=0.009 | Transplant worsens graft survival
Rao KV, 1983 N=300 | Cox^*^ | Previous transplants | Graft survival | NR, P=0.3380 | NA
Impact of pretransplant transfusions
Lietz K, 2003 N=502 | Cox^*^ | Blood transfusions | Graft survival | RR 1.316 (0.671–2.582), P=0.4243 | NA
Hiesse C, 2001 N=144 | Cox^*^ | No transfusion (vs. matched or mismatched transfusion) | Graft survival | HR 1.1 (0.51–2.48), P=0.76 | NA
Hiesse C, 2001 N=144 | Cox^*^ | Transfusion with 1-DR matched blood | Graft survival | HR 0.59 (0.22–1.55), P=0.28 | NA
Opelz G, 1997 N=423 | Cox^*^ | Pretransplant transfusions – 1 year f/u | Graft survival | RR 2.5, P=0.003 | Transfusion benefits graft survival
Opelz G, 1997 N=423 | Cox^*^ | Pretransplant transfusions – 5 year f/u | Graft survival | RR 1.9, P=0.006 | Transfusion benefits graft survival
Peters TG, 1995 Study period: 1982–1991 N=17,937 | Cox^*^ | Pre-transplant transfusions | Graft survival | RR 0.79, P<0.0001 | Transfusion benefits graft survival
Xiao X, 1992 N=201 | Cox^*^ | Pretransplant transfusion | Graft survival | RR 0.9998, P=0.128 | NA
Madrenas J, 1988 N=287 | Cox^*^ | Pretransplant blood transfusions | Graft survival | RR 0.5447, P=0.018 | Transfusion benefits graft survival
Sanfilippo F, 1986 N=3811 | Cox^*^ | No pretransplant transfusion | Graft failure | RR 1.321, P=0.0002 | Transfusion benefits graft survival
Rao KV, 1983 N=300 | Cox^*^ | Blood transfusions | Graft survival | NR, P=0.2765 | NA
Impact of pregnancy
Tang H, 2008 Females only N=2349 | Cox^*^ | Pregnancy (1) | Graft failure | HR 1.11 (0.79–1.56), P=0.554 | NA
Tang H, 2008 Females only N=2349 | Cox^*^ | Pregnancies (2) | Graft failure | HR 1.28 (0.91–1.81), P=0.147 | NA
Tang H, 2008 Females only N=2349 | Cox^*^ | Pregnancies (≥3) | Graft failure | HR 1.54 (1.11–2.16), P<0.05 | Pregnancy worsens graft survival
Sautner T, 1994 N=146 | Stepwise logistic regression | Pregnancies | Graft survival | NR, P=NS | NA

* Cox proportional hazards regression analysis

† Patients received immunosuppression with cyclosporine

‡ Patients received control immunosuppression with azathioprine

CyA=cyclosporine; CMTSG=Canadian Multicenter Transplant Study Group; f/u=followup; HR=hazard ratio; N=number of patients in analysis; NR=not reported; NS=not significant; RR=relative risk

Table 13 Multivariate results: the impact of transfusions on patient survival (KQ1a)

Study, Year Total N | Analysis Type | Covariate | Outcome Evaluated | Multivariate Results | Significant Effect
Impact of previous transplant
Tang H, 2008 N=2882 | Cox^*^ | Previous transplant | Patient death | HR 3.59 (2.69–4.80), P<0.001 | Transplant worsens patient survival
Madrenas J, 1988 N=287 | Cox^*^ | Second transplant | Patient survival | RR 1.261, P=NS | NA
Madrenas J, 1988 N=287 | Cox^*^ | ≥3 transplants | Patient survival | RR 3.968, P=NS | NA
CMTSG, 1986 CyA N=142 | Cox^*^ | Prior transplant | Patient death | RR 0.49, P=NS | NA
CMTSG, 1986 Control N=149 | Cox^*^ | Prior transplant | Patient death | RR 1.10, P=NS | NA
Sanfilippo F, 1986 N=3811 | Cox^*^ | Prior failed graft (1) | Patient death | RR 0.998, P=NS | NA
Sanfilippo F, 1986 N=3811 | Cox^*^ | Prior failed grafts (≥2) | Patient death | RR 1.712, P=0.08 | NA
Impact of pretransplant transfusions
Madrenas J, 1988 N=287 | Cox^*^ | Pretransplant blood transfusions | Patient survival | RR 0.7447, P=NS | NA

* Cox proportional hazards regression analysis

CMTSG=Canadian Multicenter Transplant Study Group; HR=hazard ratio; N=number of patients in analysis; NA=not applicable; NR=not reported; NS=not significant; RR=relative risk

### Evaluation of Different Types of Transfusions on Renal Allograft Outcomes

While our base-case analyses combined different types of transfusions to assess the overall impact of transfusion on renal transplant outcomes, in these subgroup evaluations, we separated the analyses of donor-specific transfusions versus no transfusion from other types of transfusions versus no transfusion.

#### Non-DST Therapeutic/Protocol Transfusions 15,17,19,20,24–29,31–37,39–45,48,49,51–58,60–63,65,66,69,71–76,78–88,90,91,95,96,98,100–103,105–107,109–111,113–117,119,120,129

Of the 106 unique studies included in Key Question 1a, 267 analyses reported the impact of therapeutic or protocol transfusion on renal allograft outcomes. Of the 267 analyses, 20 (7.5 percent),15,17,19,20,35,37,42,44,65,69,71,73,76,95,98,102,103,113 204 (76.4 percent), 15,17,19,20,24–29,31–37,39–45,48,49,51–58,60–63,65,66,72–86,88,90,91,95,96,98,100–103,105–107,109–111,113–117,119,120,130 and 43 (16.1 percent) analyses15,17,29,33,37,53,62,65,71,77,86,88,95,103,106,111,113,120 included results for rejection, graft survival and patient survival respectively (Table 14)

Fourteen of the twenty analyses provided statistical significance of the results on graft rejection, of which 12 (86 percent) found therapeutic or protocol transfusions to have significant beneficial to no significant effect on rejection outcomes. The strength of body of evidence of this outcome was graded as low. For the overall direction of therapeutic or protocol transfusion effects on rejection outcomes, eighty-five percent of the analyses found such transfusions to have beneficial to neutral effect, and we graded the strength of evidence as insufficient because the magnitude of the effect from the available data was difficult to gauge (Table 15).

All the analyses that reported significance of results on both graft and patient survival found that therapeutic or protocol transfusions either significantly improved or had no significant effect on survival outcomes at 1-year and maximum duration. The vast majority (83 to 96 percent) of analyses found the magnitude of the transfusion effects on graft and patient survival at 1-year and maximum duration to be beneficial or neutral (Table 16). The strength of the body of evidence in all cases was low.

The results of this subgroup analysis were not markedly different from those of our base-case analyses, thus the overall conclusion for Key Question 1a remains the same.

Table 14 Insight into body of literature: therapeutic/protocol transfusions versus no transfusion (excluding DST analyses) (KQ 1a)

| Rejection | Graft Survival | Patient survival | Validity of Studies
KQ 1a. Transfusion versus No transfusion | CCT 4 Analyses | CCT 1-year –8 Analyses Max time –8 Analyses | CCT 1-year –3 Analyses Max time –3 Analyses | Good 2 studies
KQ 1a. Transfusion versus No transfusion | POBS 0 Analysis | POBS 1-year –16 Analyses Max time –19 Analyses | POBS 1-year –0 Analysis Max time –2 Analyses | Fair 5 studies
KQ 1a. Transfusion versus No transfusion | ROBS 16 Analyses | ROBS 1-year –75 Analyses Max time –78 Analyses | ROBS 1-year –17 Analyses Max time –18 Analyses | Poor 73 studies

Abbreviations: CCT=clinical controlled trial, KQ=key question, Max=maximum followup time, POBS=prospective observational studies, ROBS=retrospective observational studies

Table 15 Impact of therapeutic/protocol transfusions (excluding DST analyses) on rejection (KQ 1a)

Impact of transfusions on: | Significant Reduction in Rejection | No Significant Effect on Rejection | Significant Increases in Rejection | Decreased Risk of Rejection^*^ | No Change in Rejection † | Increased Risk of Rejection^*^
Rejection at Any Time Point | 6/14 (42.9%) | 6/14 (42.9%) | 2/14 (14.2%) | 13/20 (65.0%) | 4/20 (20.0%) | 3/20 (15.0%)

* Data either showing a decrease/increase of any magnitude or notation in text stating a decrease/increase

† Data either showing no difference, or notation in text stating no change

Table 16 Impact of therapeutic/protocol transfusion (excluding DST analyses) on graft and patient survival (KQ1a)

Impact of transfusions on: | Significant Increases in Survival | No Significant Effect | Significant Decreases in Survival | >10% Increase in Survival | 10% to – 10% Change in Survival | >10% Decrease in Survival
1-Year Graft Survival | 22/43 (51.2%) | 21/43 (48.8%) | 0/43 (0.0%) | 54/99 (54.5%) | 41/99 (41.4%) | 4/99 (4.1%)
Max Duration Graft Survival | 21/47 (44.7%) | 26/47 (55.3%) | 0/47 (0.0%) | 58/105 (55.2%) | 41/105 (39.0%) | 6/105 (5.7%)
1-Year Patient Survival | 0/12 (0.0%) | 12/12 (100%) | 0/12 (0.0%) | 1/20 (5.0%) | 17/20 (85.0%) | 2/20 (10.0%)
Max Duration Patient Survival | 1/12 (8.3%) | 11/12 (91.7%) | 0/12 (0.0%) | 4/23 (17.4%) | 15/23 (65.2%) | 4/23 (17.4%)

#### Donor-Specific Transfusion14,16,18,19,21–23,30,32,38,47,50,51,59,64,65,67,68,70,89,92–97,99,104,108,112,118

Thirty-one of the 106 unique studies included in Key Question 1a evaluated the impact of donor specific transfusions on renal allograft outcomes. A total of 134 analyses were reported in the DST studies, of which 27, 74, and 33 analyses were included for rejection outcomes, graft and patient survival, respectively. (Table 17)

A little over 90 percent of the analyses that reported the significance of results on rejection outcomes found that DST either significantly reduced or had no significant effect on rejection. Although DST was shown to have more beneficial effects (56 percent) on rejection outcomes when assessing the direction of its effect, 30 percent of the total rejection analyses also found DST to have detrimental effects on graft rejection. As such, 70 percent of the analyses found either a beneficial or neutral effect on graft rejection. The strength of the body of evidence for the significance of results on rejection was low, while the strength of evidence for the magnitude of DST effects was graded as insufficient. (Table 18)

All analyses that reported significance results of graft survival found that DST either significantly improved or had no significant effect on 1-year and maximum duration of graft survival, while all analyses found DST to have no significant effect on 1-year and maximum duration of patient survival. For the magnitude of DST effects, the use of DST was found to have a beneficial or neutral effect on graft and patient survival in 95–100% of analyses at 1-year and maximum duration of followup. The strength of evidence in all cases was low. (Table 19)

Table 17 Insight into body of literature: DST versus no transfusion (KQ 1a)

| Rejection | Graft Survival | Patient survival | Validity of Studies
KQ 1a. Transfusion versus No transfusion | CCT 5 Analyses | CCT 1-year –4 Analyses Max time –5 Analyses | CCT 1-year –5 Analyses Max time –5 Analyses | Good 3 studies
KQ 1a. Transfusion versus No transfusion | POBS 1 Analysis | POBS 1-year –8 Analyses Max time –8 Analyses | POBS 1-year –1 Analysis Max time –1 Analyses | Fair 8 studies
KQ 1a. Transfusion versus No transfusion | ROBS 21 Analyses | ROBS 1-year –21 Analyses Max time –28 Analyses | ROBS 1-year –9 Analyses Max time –12 Analyses | Poor 19 studies

Abbreviations: CCT=clinical controlled trial, KQ=key question, Max=maximum followup time, POBS=prospective observational studies, ROBS=retrospective observational studies

Table 18 Impact of DST on rejection (KQ 1a)

Impact of transfusions on: | Significant Reduction in Rejection | No Significant Effect on Rejection | Significant Increases in Rejection | Decreased Risk of Rejection^*^ | No Change in Rejection † | Increased Risk of Rejection^*^
Rejection at Any Time Point | 3/11 (27.3%) | 7/11 (63.6%) | 1/11 (9.1%) | 15/27 (55.6%) | 4/27 (14.8%) | 8/27 (29.6%)

* Data either showing a decrease/increase of any magnitude or notation in text stating a decrease/increase

† Data either showing no difference, or notation in text stating no change

Table 19 Impact of DST on graft and patient survival (KQ1a)

Impact of transfusions on: | Significant Increases in Survival | No Significant Effect | Significant Decreases in Survival | >10% Increase in Survival | 10% to −10% Change in Survival | >10% Decrease in Survival
1-Year Graft Survival | 7/12 (58.3%) | 5/12 (41.7%) | 0/12 (0.0%) | 11/33 (33.3%) | 22/33 (66.7%) | 0/33 (0.0%)
Max Duration Graft Survival | 9/18 (50.0%) | 9/18 (50.0%) | 0/18 (0.0%) | 18/41 (43.9%) | 21/41 (51.2%) | 2/41 (4.9%)
1-Year Patient Survival | 0/4 (0.0%) | 4/4 (100%) | 0/4 (0.0%) | 0/15 (0.0%) | 15/15 (100.0%) | 0/15 (0.0%)
Max Duration Patient Survival | 0/6 (0.0%) | 6/6 (100.0%) | 0/6 (0.0%) | 4/18 (22.2%) | 14/18 (77.8%) | 0/18 (0.0%)

## Key Question 1bi Is any such impact of red blood cell transfusions on renal transplant outcomes altered by planned DST versus therapeutic transfusions?

### Univariate Analysis Results

Eleven unique studies were included in the evaluation of the impact of planned DST versus non-DST on renal transplant outcomes.32,51,65,96,122,131–136 One of the 11 studies was a prospective observational study, and 10 were retrospective observational studies, of which 2 (18.2 percent) were rated as fair quality and 9 (81.8 percent) were rated as poor quality. Of the 48 analyses reported from the studies, 25 percent were from the prospective study, and 75 percent were from retrospective studies. Seven (14.5 percent), 33 (68.8 percent), and 8 (16.7 percent) included results for graft rejection, graft survival and patient survival, respectively (Table 20).

### Rejection 65,122,131–133,136

Seven analyses reported results on rejection outcomes of which three (42.8 percent) analyses reported on the statistical significance of the results. These three analyses found either a significant reduction in rejection or no significant effect associated with DST.65,122,136 To be considered in this evaluation, studies had to provide a p-value, 95 percent confidence interval, or explicitly state whether or not statistical significance was achieved. Thus, we concluded that planned DST had a significant beneficial to neutral effect on rejection outcomes and graded the strength of the body of evidence as low. When assessing the overall direction of change for DST versus non-DST on rejection outcomes, six of seven analyses (85.8 percent) found either a decreased risk or no change in rejection resulting from planned DST. We concluded that DST versus non-DST had a beneficial to neutral impact on rejection outcomes. We graded the strength of evidence as insufficient as it was challenging to gauge the magnitude of the effect from the available data. (Table 21) To be classified as either decreasing or increasing the risk of rejection with transfusion, data had to be available within the study showing a direction of change or the text needed to note that the risk was either decreased or increased. Statistical significance was not evaluated in this directionality evaluation.

### Graft Survival65,131,132,135,136

Four and five analyses completed statistical evaluations to determine if DST had a significant effect on 1-year and maximum duration graft survival, respectively (Table 22). All presented analyses determined that DST had either a significant increase or no significant effect on 1-year and maximum duration graft survival. None of the analyses found DST to have a negative significant impact on 1-year and maximum duration graft survival. Therefore, we concluded that DST versus non-DST had a beneficial to neutral significant effect on 1-year and maximum duration graft survival. The strength of evidence was graded as low.

Sixteen and seventeen analyses evaluated the magnitude of 1-year and maximum duration graft survival, respectively. All analyses reported either a >10 percent increase or a small change within 10 percent in either direction in survival with regard to 1-year and maximum duration graft survival. We concluded that DST had a beneficial to neutral effect on 1-year and maximum duration graft survival, and that the strength of evidence for these effects to be low.

### Patient Survival65,133,135

Two analyses and two analyses performed statistical evaluations to establish if DST had a significant effect on 1-year and maximum duration patient survival, respectively (Table 22). All analyses demonstrated that DST had no significant effect on 1-year and maximum duration patient survival. None of the analysis found DST to have a significant increase or decrease in 1-year and maximum patient survival. We concluded that DST versus non-DST had no significant effect on 1-year and maximum duration patient survival. We graded the strength of evidence for these effects to be insufficient.

Four analyses and four analyses examined the extent of DST on 1-year and maximum duration patient survival, respectively. All analyses reported a small change within 10 percent in either direction on 1-year and maximum duration patient survival. We concluded that DST versus non-DST had a neutral effect on 1-year and maximum duration patient survival, and we assessed the strength of the body of evidence for these effects to be low.

### Multivariate Analysis Results

One analysis122 evaluated DST as a covariate in multivariate analysis assessing for rejection episodes (Table 23). DST was found to be an independent predictor of decreasing rejection in this analysis.

Four analyses64,96 evaluated the effects of DST for graft survival in multivariate analyses. One of the four analyses (25.0 percent) found that DST was an independent predictor in benefiting graft survival. The other analyses did not find that DST was an independent predictor. However, in three of the four analyses, including the one in which it was found to be an independent predictor, DST was compared to no transfusion, not to a non-DST transfusion. No analysis examined DST as a covariate in multivariate analysis evaluating patient survival (Table 24).

In summary, DST may or may not impact rejection, may or may not benefit graft survival and the impact on patient survival is unknown.

Table 20 Insight into body of literature: Donor-specific transfusion (KQ 1bi)

| Rejection | Graft Survival | Patient survival | Validity of Studies
KQ 1bi. DST | CCT None | CCT None | CCT None | Good None
KQ 1bi. DST | POBS None | POBS 1-year – 6 Analyses Max time – 6 Analyses | POBS None | Fair 2 studies
KQ 1bi. DST | ROBS 7 Analyses | ROBS 1-year – 10 Analyses Max time – 11 Analyses | ROBS 1-year – 4 Analyses Max time – 4 Analyses | Poor 9 studies

CCT=clinical controlled trial, DST=donor specific transfusion, KQ=key question, Max=maximum followup time, POBS=prospective observational studies, ROBS=retrospective observational studies

Table 21 Impact of donor specific transfusion on rejection (KQ1bi)

KQ 1bi | Significant Decreases in Rejection | No Significant Effect on Rejection | Significant Increases in Rejection | Decreased Risk of Rejection^*^ | No Change in Rejection^†^ | Increased Risk of Rejection^*^
Graft Rejection Any Time Point | 2/3 (66.7%) | 1/3 (33.3%) | 0/3 (0.0%) | 3/7 (42.9%) | 3/7 (42.9%) | 1/7 (14.2%)

* Data either showing a decrease/increase o00f any magnitude or notation in text stating a decrease/increase

† Data either showing no difference, or notation in text stating no change

Table 22 Impact of DST on graft and patient survival (KQ 1bi)

KQ 1bi | Significant Increases in Survival | No Significant Effect | Significant Decreases in Survival | >10% Increase in Survival | 10% to − 10% Change in Survival | >10% Decrease in Survival
1-Year Graft Survival | 2/4 (50.0%) | 2/4 (50.0%) | 0/4 (0.0%) | 3/16 (18.8%) | 13/16 (81.2%) | 0/16 (0.0%)
Max Duration Graft Survival | 2/5 (40.0%) | 3/5 (60.0%) | 0/5 (0.0%) | 6/17 (35.3%) | 11/17 (64.7%) | 0/17 (0.0%)
1-Year Patient Survival | 0/2 (0%) | 2/2 (100%) | 0/2 (0%) | 0/4 (0%) | 4/4 (100%) | 0/4 (0%)
Max Duration Patient Survival | 0/2 (0%) | 2/2 (100%) | 0/2 (0%) | 0/4 (0%) | 4/4 (100%) | 0/4 (0%)

Table 23 Multivariate results: Impact of DST on rejection (KQ1bi)

Study, Year Total N | Analysis Type | Covariate | Outcome Evaluated | Multivariate Results | Significant Effect
Reed A, 1991 N=127 | Poisson multivariate analysis | DST | Rejection episodes | NR, P=0.0001 | DST benefits rejection

DST=donor specific transfusion; N=number of patients in analysis; NR=not reported

Table 24 Multivariate results: Impact of DST on graft survival (KQ bi)

Study, Year Total N | Analysis Type | Covariate | Outcome Evaluated | Multivariate Results | Significant Effect
Jin DC, 1996 N=680 | Cox^*^ | DST | Graft survival | RR 0.808, P=0.2729 | NA
Sanfilippo F, 1990 N=2138 | Cox^*^ | DST vs. no transfusion | Graft survival | RR 0.77, P=NS | NA
Sanfilippo F, 1990 1-haplotype match N=1246 | Cox^*^ | DST vs. no transfusion | Graft survival | RR 0.56, P<0.06 | DST benefits graft survival
Sanfilippo F, 1990 2-haplotype match N=750 | Cox^*^ | DST vs. no transfusion | Graft survival | RR 1.03, P=NS | NA

* Cox proportional hazards regression analysis

DST=donor specific transfusion; N=number of patients in analysis; NS=not significant; RR=relative risk

## Key Question 1bii Is any such impact of red blood cell transfusions on renal transplant outcomes altered by the number of transfusions, the number of units of blood, and/or the number of donors?

### Univariate Analysis Results

We answered this key question by categorizing the number of transfusions and the number of units of blood into four groups: zero, 1 to ≤5, 5 to 10 (or ≥ 5), and ≥ 10 transfusions or units of blood. Pairwise comparisons of different transfusion intensities (i.e. transfusion intensities versus no transfusion and higher intensity versus lower intensity) were conducted to evaluate whether transfusion effects on survival outcomes would be altered by the number of transfusions or units of blood transfused.

Thirty-seven unique studies were included in the evaluation of the impact of different number of transfusions on renal allograft outcomes.3, 20, 24, 34, 37, 41, 43, 45, 52, 57, 64, 72, 73, 98, 101, 102, 106, 109, 115, 116, 119, 126, 128, 137–150 Three of the 37 studies were clinical controlled trials, two were prospective observational studies, and 32 were retrospective observational studies, of which none was rated as good quality, 7 rated fair, and 30 rated poor. Of the 314 analyses reported by the studies, the majority of analyses (88.4 percent) were from retrospective studies, while only 6.8 percent and 4.8 percent of the analyses were from controlled trials and prospective studies respectively. Nineteen (6.1 percent), 265 (84.3 percent), and 30 (9.6 percent) analyses included results for graft rejection, graft survival and patient survival, respectively (Table 25).

### Rejection

#### Number of transfusions37, 73, 102, 138

Eighteen analyses reported results on rejection outcomes, of which 5 of the 18 analyses reported on the statistical significance of their results. Of the five analyses, all found either a significant reduction in rejection resulting from using any higher versus any lower number of transfusions or no significant effect. To be considered in this evaluation, studies had to provide a p-value, 95 percent confidence interval, or explicitly say whether or not statistical significance was achieved. Thus, we concluded that the use of larger number of transfusions had a beneficial to no significant effect on rejection outcomes and graded the strength of the body of evidence as low (Table 26).

When evaluating the overall direction of transfusion effects on rejection outcomes, 16 of the 18 analyses (88.9 percent) found either a decreased risk or no change in rejection resulting from using any higher versus any lower number of transfusions. Thus, we concluded that any higher number of transfusions had a beneficial to neutral effect on rejection outcomes and graded the strength of the body of evidence as insufficient because in addition to the standard limitations within this body of evidence, it was difficult to gauge the magnitude of the effect from the available data (Table 26). To be classified as either decreasing or increasing the risk of rejection with transfusion, data had to be available within the study showing a direction of change or the text needed to note that the risk was either decreased or increased. Statistical significance was not evaluated in this directionality evaluation.

#### Units of Transfusions20

One analysis reported results on rejection outcomes of which it found no significant effect on rejection outcomes. The direction of transfusion effects resulting from using any higher number versus any lower number of units of blood did not change rejection outcomes. Thus, we concluded that the use of any number of units of blood had a neutral effect on rejection outcomes and graded the strength of the body of evidence as insufficient. In addition to the standard limitations within this body of evidence, it was difficult to gauge the magnitude of the effect from the available data (Table 26). To be classified as either decreasing or increasing the risk of rejection with transfusion, data had to be available within the study showing a direction of change or the text needed to note that the risk was either decreased or increased. Statistical significance was not evaluated in this directionality evaluation.

#### Number of donors

No analysis reported results on rejection outcomes. Thus, there was insufficient data to grade the strength of evidence on the effect of number of donors on graft rejection.

### Graft Survival

#### Number of transfusions3, 34, 37, 41, 57, 73, 98, 101, 102, 106, 109, 115, 116, 126, 128, 137, 138, 140–146, 150

##### Any number of transfusions versus no transfusion

Twelve and nine analyses performed statistical evaluations to determine if different number of transfusions had a significant effect on 1-year and maximum duration graft survival versus no transfusions, respectively. The comparisons were made between different intensity of transfusions versus no transfusions (1–5, 5–10, and ≥10 transfusions versus no transfusions). Receiving 1 to 5 or ten or more transfusions had only significantly beneficial or no significant effects of 1-year and maximal duration graft survival versus no transfusions. While two analyses found that 5–10 transfusions had a significant beneficial effect on 1-year and maximal duration graft survival versus no transfusions, two analyses (one for 1-year and the other for maximum duration), both reported in the same study by Chavers et al, found receiving more than five transfusions to have significant detrimental effect on 1-year and maximum duration graft survival versus no transfusion.138 Another analysis found >5 transfusion versus no transfusion to have a significant negative effect on maximum duration graft survival.126 In a final analysis of 1-year graft survival, >5–10 transfusions versus no transfusion was found to have no significant effect on graft survival. Thus, we concluded that having 1–5 and ten or more transfusions has a beneficial to no significant effect on 1-year and maximum duration graft survival versus no transfusions, the impact of 5–10 transfusions is mixed, and we graded the strength of the body of evidence for such effects to be low (Table 27).

Fifty-one and fifty-three analyses performed evaluations of the magnitude of 1-year and maximum duration graft survival for different numbers of transfusions (1–5, 5–10, and ≥10 transfusions) versus no transfusions, respectively. Forty-nine (96.1 percent) and forty-nine (92.5 percent) analyses reported either a >10 percent increase or a small change within 10 percent in either direction in survival on 1-year and maximum duration graft survival, respectively. Thus, we concluded that different number of transfusion has a beneficial to neutral effect on 1-year and maximum duration graft survival, and we graded the strength of the body of evidence for such effects to be low.

##### Higher number versus lower number of transfusions

Eleven and ten analyses performed statistical evaluations to determine if higher versus lower number of blood transfusions had a significant effect on 1-year and maximum duration graft survival, respectively. For 1-year survival, nine of the eleven (82 percent) analyses in the three different pairwise groups (>5 versus 1–5, >10 versus 1–5, >10 versus 5–10) reported either a significant increase or no significant effect on 1-year graft survival. Two of the 11 analyses (18 percent) found > 5 transfusions versus 1–5 transfusions to have a significant negative impact on 1-year graft survival. For maximum duration, only the evaluation of >5 versus 1–5 transfusions had evaluable analyses, of which 7 out of 11 (64 percent) analyses found a significant beneficial or no significant effect. The remaining four analyses (36 percent) found >5 transfusions to have a significant negative impact on maximum duration of graft survival. Thus, we concluded that different number of transfusions has a beneficial to no significant effect on 1-year and maximum duration graft survival, and we graded the strength of the body of evidence for such effects to be low to insufficient (Table 28).

Forty-three and forty-seven analyses performed evaluations of the magnitude of 1-year and maximum duration graft survival for higher versus lower number of blood transfusions, respectively. For 1-year survival, all available analyses in the three different pairwise groups (>5 versus 1–5, >10 versus 1–5, >10 versus 5–10) reported either a >10 percent increase or a small change within 10 percent in either direction on 1-year and maximum duration graft survival. For maximum duration, in 42 of 47 analyses (89.4 percent), a beneficial or neutral effect was seen with higher versus lower number of transfusions. Thus, we concluded that different number of transfusion has a beneficial to neutral effect on 1-year and maximum duration graft survival, and we graded the strength of the body of evidence for such effects to be low.

#### Units of transfusions20, 24, 43, 45, 52, 64, 72, 119, 139, 148, 149

##### Any units of transfusions versus no transfusion

Eleven and sixteen analyses performed statistical evaluations to determine if different number of units transfused had a significant effect on 1-year and maximum duration graft survival versus no transfusions, respectively. The comparisons were made between different intensity of units transfused versus no units (1–5 versus 0, 5–10 versus 0, and ≥10 versus 0 transfusions). All available analyses in three different pairwise groups reported either a significant beneficial or no significant effect on 1-year and maximum duration graft survival. None of the analyses found the number of units transfused to have a significant negative impact on 1-year and maximum duration of graft survival. Thus, we concluded that different number of units transfused has a beneficial to no significant effect on 1-year and maximum duration graft survival, and we graded the strength of the body of evidence for such effects to be low (Table 29).

Twenty-one and twenty-two analyses performed evaluations of the magnitude of 1-year and maximum duration graft survival for different numbers of transfusions (1–5, 5–10, and ≥10 transfusions) versus no transfusions, respectively. In all analyses for 1-year (100.0 percent) and all analyses except one (95.5 percent) for maximum duration graft survival, a large benefit or small change was noted (Table 29). Thus, we concluded that different number of units of blood transfused has a beneficial to neutral effect on 1-year and maximum duration graft survival, and we graded the strength of the body of evidence for such effects to be low.

##### Higher number versus lower number of transfused units

Six and twelve analyses performed statistical evaluations to determine if higher versus lower number of transfused units had a significant effect on 1-year and maximum duration graft survival, respectively. For 1-year survival and maximum duration survival, all available analyses in the three different pairwise groups (≥5 versus 1–5, ≥10 versus 1–5, ≥10 versus 5–10) reported either a significant increase or no significant effect. None of the analyses found transfusion to have a significant negative impact on 1-year and maximum duration of graft survival (Table 30). Thus, we concluded that a higher number of units of transfused blood had a beneficial to neutral effect on 1-year and maximum duration graft survival, and we graded the strength of the body of evidence for such effects to be low.

Twelve and sixteen analyses performed evaluations of the magnitude of 1-year and maximum duration graft survival for higher versus lower number of blood transfusions, respectively. For 1-year survival, all available analyses in the three different pairwise groups (≥5 versus 1–5, >10 versus 1–5, >10 versus 5–10) reported either an increase or no effect on 1-year and maximum duration graft survival with a higher versus lower number of units infused. For maximum duration, in 15 of 16 analyses (93.8 percent), a beneficial or neutral effect was seen with higher versus lower number of transfusions (Table 30). Thus, we concluded that a higher number of units of transfused blood had a beneficial to neutral effect on 1-year and maximum duration graft survival, and we graded the strength of the body of evidence for such effects to be low.

#### Number of donors

No analysis reported results on 1-year and maximum duration graft survival. Therefore, there was insufficient data to grade the strength of evidence on the effect of number of donors on graft survival.

### Patient Survival

#### Number of transfusions37, 73, 142

A total of 16 analyses, split evenly between those reporting 1-year (n=8) and those reporting maximum duration (n=8) patient survival, reported statistical results on the impact of different number of transfusions versus no transfusion. Regardless of the number of transfusions (1–5, 5–10, or ≥10 versus no transfusions), all analyses found no significant effect. As such, the conclusion was that there is a neutral effect on 1-year and maximum duration patient survival regardless of the number of transfusions versus receiving no transfusion. We graded the strength of evidence to be low (Table 31).

Similarly, all of the 14 analyses, split evenly between those reporting 1-year and those reporting maximum duration patient survival, reported statistical evaluations of the impact of higher transfusion intensities versus lower transfusion intensities. In every comparison of higher versus lower transfusion intensity, no significant effect on 1-year and maximum duration patient survival occurred. Thus, we concluded that number of transfusions did not have any significant impact on 1-year and maximum duration patient survival, and we graded the strength of the body of evidence for such effects to be low (Table 32).

Eight and seven analyses performed evaluations of the magnitude of different transfusion intensities (1–5, 5–10, or ≥10) compared to no transfusion on 1-year and maximum duration patient survival, respectively. All analyses found either a >10 percent increase or a small change within 10 percent in either direction in 1-year and maximum duration patient survival. We concluded that there was a large beneficial to neutral effect of different number of transfusions versus no transfusion on patient survival and we graded the strength of the body of evidence as low (Table 31).

Seven and five analyses evaluated the magnitude of higher transfusion intensities to lower transfusion intensities (≥5 vs. 1–5, >10 vs. 1–5, >10 vs. 5–10) on 1-year and maximum duration patient survival, respectively. All of the analyses reported a small change within 10 percent in either direction in survival on 1-year and maximum duration patient survival. We concluded that the number of transfusion has small impact on patient survival, and we graded the strength of the body of evidence for such effects to be low (Table 32).

#### Units of transfusions

No analysis reported results on 1-year and maximum duration patient survival. Thus, there was insufficient data to grade the strength of evidence on the effect of number of units of transfusions on patient survival.

#### Number of donors

No analysis reported results on 1-year and maximum duration patient survival. Therefore, there was insufficient data to grade the strength of evidence on the effect of number of donors on patient survival.

### Multivariate Analysis Results

Seven analyses138, 151 evaluated the number of transfusions or the number of units transfused as a covariate in multivariate analysis assessing rejection. In five of these analyses, transfusion was a covariate but the remaining people in the dataset could include patients who received no transfusions (Table 33). In three of five (60.0 percent) of these analyses, the use of transfusions was an independent predictor of lesser rejection. Two other analyses specifically compared a higher intensity (>5 transfusions) to lower intensity of transfusions (1–5 transfusions) and lower intensity could not include no transfusions. One of the two analyses (50.0 percent) found that greater than five transfusions was an independent predictor of increasing the risk of rejection. Both of these latter analyses were from the same study and higher number of transfusions was significant for living donors (RR 1.29, p=0.003) but not for cadaver donors (1.02, P=0762).

Eighteen analyses84, 124, 126, 128, 138, 152–155 assessed the number of transfusions or the number of units transfused as a covariate in multivariate analysis evaluating graft survival. In six of the analyses (33.3 percent), transfusions of different intensities were independent predictors of worsening graft survival (Table 34). One analysis (6 percent) found that one or more transfusions were an independent predictor of benefiting graft survival. Eleven analyses (61.1 percent) did not find transfusions ranging from one to greater than 10 to be independent predictors of graft survival in either direction. When we evaluated only studies which explicitly compared a higher number of transfusions versus a lower number that could not include zero (no transfusions), 2 analyses were available and were both from the same study. In this study, the use of >5 transfusions was an independent predictor of worsening graft survival in both living and cadaver donors.

Seven analyses124, 128, 154, 156 evaluated the number of transfusions or the number of units transfused as a covariate in multivariate analysis assessing for patient survival (Table 35). Three of the analyses were from the same study.138 In this study, the covariate “1–5 transfusions versus no transfusions” was not an independent predictor of patient survival. In this study, 1 analysis (14 percent) found that 6 to 10 transfusions versus no transfusion and another analysis (14 percent) found that >10 transfusions versus no transfusion were both independent predictors of worsening patient survival. One analysis (14 percent) from another trial found that transfusions greater than 40 units was a significant predictor of worsening patient survival. Four analyses (57 percent) determined that the number of transfusions or number of units transfused was not an independent predictor of patient survival in either direction but three of four of the analyses were limited to five or fewer transfusions.

In summary, transfusions were not an independent predictor of rejection, graft survival, or patient survival in either direction in a large number of analyses. Greater than five transfusions may have worsening graft and patient survival compared to one to five transfusions but the data are scant and may differ based on whether the graft is from a living or cadaver donor.

Table 25 Insight into body of literature: Number/Units of transfusions and number of donors (KQ1bii)

| Rejection | Graft Survival | Patients Survival | Validity of Studies
KQ 1bii. Number/Units of Transfusion, Number of Donors | CCT 1 Analysis | CCT 1-year –9 Analyses Max time –11 Analyses | CCT None | Good 0 study
KQ 1bii. Number/Units of Transfusion, Number of Donors | POBS None | POBS 1-year –6 Analyses Max time – 9 Analyses | POBS None | Fair 7 studies
KQ 1bii. Number/Units of Transfusion, Number of Donors | ROBS 18 Analyses | ROBS 1-year –112 Analyses Max time –118 Analyses | ROBS 1-year –15 Analyses Max time –15 Analyses | Poor 30 studies

CCT=clinical controlled trial, KQ=key question, Max=maximum followup time, POBS=prospective observational studies, ROBS=retrospective observational studies,

Table 26 Impact of any number/unit of transfusions, or number of donors on rejection (KQ1bii)

KQ 1bii Graft Rejection Any Time Point | Significant Decreases in Rejection | No Significant Effect on Rejection | Significant Increases in Rejection | Decreased Risk of Rejection * | No Change in Rejection † | Increased Risk of Rejection *
Number of transfusions^‡^ | 2/5 (40.0%) | 3/5 (60.0%) | 0/5 (0.0%) | 6/18 (33.3%) | 10/18 (55.6%) | 2/18 (11.1%)
Number of units of transfusion^‡^ | 0/1 (0.0%) | 1/1 (100.0%) | 0/1 (0.0%) | 0/1 (0.0%) | 1/1 (100.0%) | 0/1 (0.0%)
Number of donors | No data | No data | No data | No data | No data | No data

* Data either showing a decrease/increase of any magnitude or notation in text stating a decrease/increase

† Data either showing no difference, or notation in text stating no change

‡ Any number/units of transfusions versus any other number/units of transfusions

Table 27 Impact of number of transfusions on graft survival: intensity of transfusion versus no transfusion (KQ1bii)

Number of transfusions | Significant Increases in Survival | No Significant Effect | Significant Decreases in Survival | >10% Increase in Survival | 10% to −10% Change in Survival | >10% Decrease in Survival
1–5 versus 0
1-Year graft survival | 1/5 (20.0%) | 4/5 (80.0%) | 0/5 (0.0%) | 10/19 (52.6%) | 9/19 (47.4%) | 0/19 (0.0%)
Max duration graft survival | 2/4 (50.0%) | 2/4 (50.0%) | 0/4 (0.0%) | 9/20 (45.0%) | 10/20 (50.0 %) | 1/20 (5.0%)
5–10/>5 versus 0
1-Year graft survival | 2/4 (50.0%) | 1/4 (25.0%) | 1/4 (25.0%) | 11/20 (55.0%) | 7/20 (35.0%) | 2/20 (10.0%)
Max duration graft survival | 2/4 (50.0%) | 0/4 (0.0%) | 2/4 (50.0%) | 10/21 (47.6%) | 8/21 (38.1%) | 3/21 (14.3%)
≥10 versus 0
1-Year graft survival | 1/3 (33.3%) | 2/3 (66.7%) | 0/3 (0.0%) | 9/12 (75.0%) | 3/12 (25.0%) | 0/12 (0.0%)
Max duration graft survival | 1/1 (100.0%) | 0/1 (0.0%) | 0/1 (0.0%) | 9/12 (75.0%) | 3/12 (25.0%) | 0/12 (0.0%)

Table 28 Impact of number of transfusions on graft survival: higher versus lower number of transfusions (KQ1bii)

Number of transfusions | Significant Increases in Survival | No Significant Effect | Significant Decreases in Survival | >10% Increase in Survival | 10% to −10% Change in Survival | >10% Decrease in Survival
5–10/>5 versus 1–5
1-Year graft survival | 4/7 (57.1%) | 1/7 (14.3%) | 2/7 (28.6%) | 9/21 (42.9%) | 12/21 (57.1%) | 0/21 (0.0%)
Max duration graft survival | 6/11 (54.5%) | 1/11 (9.1%) | 4/11 (36.4%) | 11/28 (39.3%) | 11/28 (39.3%) | 6/28 (21.4%)
≥10 versus 1–5
1-Year graft survival | 0/2 (0.0%) | 2/2 (100.0%) | 0/2 (0.0%) | 4/10 (40.0%) | 6/10 (60.0%) | 0/10 (0.0%)
Max duration graft survival | No data | No data | No data | 3/9 (33.3%) | 6/9 (66.7%) | 0/9 (0.0%)
≥10 versus 5–10
1-Year graft survival | 0/2 (0.0%) | 2/2 (100.0%) | 0/2 (0.0%) | 2/12 (16.7%) | 10/12 (83.3%) | 0/12 (0.0%)
Max duration graft survival | No data | No data | No data | 1/11 (9.1%) | 10/11 (90.9%) | 0/11 (0.0%)

Table 29 Impact of units of blood on graft survival: increasing number of units versus no transfusion (KQ1bii)

KQ 1bii Units of blood | Significant Increases in Survival | No Significant Effect | Significant Decreases in Survival | >10% Increase in Survival | 10% to −10% Change in Survival | >10% Decrease in Survival
1–5 versus 0
1-Year graft survival | 1/5 (20.0%) | 4/5 (80.0%) | 0/5 (0.0%) | 4/10 (40.0%) | 6/10 (60.0%) | 0/10 (0.0%)
Max duration graft survival | 2/7 (28.6%) | 5/7 (71.4%) | 0/7 (0.0%) | 5/10 (50.0%) | 4/10 (40.0%) | 1/10 (10.0%)
5–10/>5 versus 0
1-Year graft survival | 1/4 (25.0%) | 3/4 (75.0%) | 0/4 (0.0%) | 3/8 (37.5%) | 5/8 (62.5%) | 0/8 (0.0%)
Max duration graft survival | 2/5 (40.0%) | 3/5 (60.0%) | 0/5 (0.0%) | 5/9 (55.6%) | 3/9 (33.3%) | 1/9 (11.1%)
≥10 versus 0
1-Year graft survival | 1/2 (50.0%) | 1/2 (50.0%) | 0/2 (0.0%) | 3/3 (100.0%) | 0/3 (0.0%) | 0/3 (0.0%)
Max duration graft survival | 2/4 (50.0%) | 2/4 (50.0%) | 0/4 (0.0%) | 2/3 (66.7%) | 1/3 (33.3%) | 0/3 (0.0%)

Table 30 Impact of units of blood on graft survival: greater number of units versus lower numbers of units (KQ1bii)

KQ 1bii Units of blood | Significant Increases in Survival | No Significant Effect | Significant Decreases in Survival | >10% Increase in Survival | 10% to −10% Change in Survival | >10% Decrease in Survival
5–10/>5 versus 1–5
1-Year graft survival | 0/4 (0.0%) | 4/4 (100.0%) | 0/4 (0.0%) | 1/8 (12.5%) | 7/8 (87.5%) | 0/8 (0.0%)
Max duration graft survival | 0/7 (0.0%) | 7/7 (100.0%) | 0/7 (0.0%) | 1/11 (9.1%) | 9/11 (81.8%) | 1/11 (9.1%)
≥10 versus 1–5
1-Year graft survival | 0/1 (0.0%) | 1/1 (100.0%) | 0/1 (0.0%) | 1/3 (33.3%) | 2/3 (66.7%) | 0/3 (0.0%)
Max duration graft survival | 0/3 (0.0%) | 3/3 (100.0%) | 0/3 (0.0%) | 1/3 (33.3%) | 2/3 (66.7%) | 0/3 (0.0%)
≥10 versus 5–10
1-Year graft survival | 0/1 (0.0%) | 1/1 (100.0%) | 0/1 (0.0%) | 0/1 (0.0%) | 1/1 (100.0%) | 0/1 (0.0%)
Max duration graft survival | 0/2 (0.0%) | 2/2 (100.0%) | 0/2 (0.0%) | 1/2 (50.0%) | 1/2 (50.0%) | 0/2 (0.0%)

Table 31 Impact of number of transfusions on patient survival: intensity of transfusion versus no transfusion (KQ1bii)

Number of transfusions | Significant Increases in Survival | No Significant Effect | Significant Decreases in Survival | >10% Increase in Survival | 10% to −10% Change in Survival | >10% Decrease in Survival
1–5 versus 0
1-Year patient survival | 0/3 (0.0%) | 3/3 (100.0%) | 0/3 (0.0%) | 0/3 (0.0%) | 3/3 (100.0%) | 0/3 (0.0%)
Max duration patient survival | 0/3 (0.0%) | 3/3 (100.0%) | 0/3 (0.0%) | 0/3 (0.0%) | 3/3 (100.0%) | 0/3 (0.0%)
5–10/>5 versus 0
1-Year patient survival | 0/3 (0.0%) | 3/3 (100.0%) | 0/3 (0.0%) | 1/3 (33.3%) | 2/3 (66.7%) | 0/3 (0.0%)
Max duration patient survival | 0/3 (0.0%) | 3/3 (100.0%) | 0/3 (0.0%) | 1/3 (33.3%) | 2/3 (66.7%) | 0/3 (0.0%)
≥10 versus 0
1-Year patient survival | 0/2 (0.0%) | 2/2 (100.0%) | 0/2 (0.0%) | 1/2 (50.0%) | 1/2 (50.0%) | 0/2 (0.0%)
Max duration patient survival | 0/2 (0.0%) | 2/2 (100.0%) | 0/2 (0.0%) | 0/1 (0.0%) | 1/1 (100.0%) | 0/1 (0.0%)

Table 32 Impact of number of transfusions on patient survival: higher versus lower number of transfusions (KQ1bii)

Number of transfusions | Significant Increases in Survival | No Significant Effect | Significant Decreases in Survival | >10% Increase in Survival | 10% to −10% Change in Survival | >10% Decrease in Survival
5–10/>5 versus 1–5
1-Year patient survival | 0/3 (0.0%) | 3/3 (100.0%) | 0/3 (0.0%) | 0/3 (0.0%) | 3/3 (100.0%) | 0/3 (0.0%)
Max duration patient survival | 0/3 (0.0%) | 3/3 (100.0%) | 0/3 (0.0%) | 0/3 (0.0%) | 3/3 (100.0%) | 0/3 (0.0%)
≥10 versus 1–5
1-Year patient survival | 0/2 (0.0%) | 2/2 (100.0%) | 0/2 (0.0%) | 0/2 (0.0%) | 2/2 (100.0%) | 0/2 (0.0%)
Max duration patient survival | 0/2 (0.0%) | 2/2 (100.0%) | 0/2 (0.0%) | 0/1 (0.0%) | 1/1 (100.0%) | 0/1 (0.0%)
≥10 versus 5–10
1-Year patient survival | 0/2 (0.0%) | 2/2 (100.0%) | 0/2 (0.0%) | 0/2 (0.0%) | 2/2 (100.0%) | 0/2 (0.0%)
Max duration patient survival | 0/2 (0.0%) | 2/2 (100.0%) | 0/2 (0.0%) | 0/1 (0.0%) | 1/1 (100.0%) | 0/1 (0.0%)

Table 33 Multivariate results: Impact of number/units of transfusion on rejection (KQ1bii)

Study, Year Total N | Analysis Type | Covariate | Outcome Evaluated | Multivariate Results | Significant Effect
Higgins RM, 2004 N=265 | Multiple logistic regression | 3 or more transfused blood units before transplant | Acute rejection | OR 0.49 (0.29–0.83), P=0.008 | Transfusion benefits rejection
Chavers BM, 1997 LD^*^ N=2007 | NR | 1–5 transfusions vs. 0 | First acute rejection episode | RR 0.86, P=0.036 | Transfusion benefits rejection
Chavers BM, 1997 CAD^†^ N=2008 | NR | 1–5 transfusions vs. 0 | First acute rejection episode | RR 0.86, P=0.046 | Transfusion benefits rejection
Chavers BM, 1997 LD^*^ N=2007 | NR | >5 transfusions vs. 0 | First acute rejection episode | RR 1.11, P=0.284 | NA
Chavers BM, 1997 CAD^†^ N=2008 | NR | >5 transfusions vs. 0 | First acute rejection episode | RR 0.88, P=0.123 | NA
Chavers BM, 1997 LD^*^ N=2007 | NR | >5 transfusions vs. 1–5 | First acute rejection episode | RR 1.29, P=0.003 | >5 transfusions worsens rejection
Chavers BM, 1997 CAD^†^ N=2008 | NR | >5 transfusions vs. 1–5 | First acute rejection episode | RR 1.02, P=0.762 | NA

* A separate analysis involving patients receiving living-donor renal transplants

† A separate analysis involving patients receiving cadaver renal transplants

CAD=cadaver transplants; LD=living donor; N=number of patients in analysis; NR=not reported; NS=not significant; OR=odds ratio; RR=relative risk

Table 34 Multivariate results: Impact of number/units of transfusion on graft survival (KQ1bii)

Study, Year Total N | Analysis Type | Covariate | Outcome Evaluated | Multivariate Results | Significant Effect
Tang H, 2008 N=2882 | Cox^*^ | 1–5 pre-transplant transfusions vs. 0 | Graft survival | HR 1.21 (0.95–1.54), P=0.124 | NA
Tang H, 2008 N=2882 | Cox^*^ | 6–10 pre-transplant transfusions vs. 0 | Graft survival | HR 1.10 (0.72–1.69), P=0.652 | NA
Tang H, 2008 N=2882 | Cox^*^ | >10 pre-transplant transfusions vs. 0 | Graft survival | HR 1.10 (0.73–1.69), P=0.625 | NA
Park YH, 2004 N=77 | Cox^*^ | Preoperative multiple transfusion history | Graft loss | RR 4.2, P=NR | NA
Bunnapradist S, 2003 N=7079 | Cox^*^ | 1–5 pretransplant blood transfusions | Graft failure | HR 1.27 (1.07–1.49), P=0.005 | Transfusion worsens graft survival
Agarwal SK, 2002 N=144 | NR | Number of blood transfusions | Graft survival | NR, P=NS | NA
Montagnino G, 2000 N=143 | Cox^*^ | Blood transfusions (0 vs. ≥ 1) | Graft survival | RR 1.99 (1.021–3.889), P=0.043 | Transfusion benefits graft survival
Chavers BM, 1997 LD^†^ N=2007 | NR | 1–5 transfusions vs. 0 | Graft failure | RR 1.04, P=0.770 | NA
Chavers BM, 1997 CAD^‡^ N=2008 | NR | 1–5 transfusions vs. 0 | Graft failure | RR 0.85, P=0.200 | NA
Chavers BM, 1997 LD^†^ N=2007 | NR | >5 transfusions vs. 0 | Graft failure | RR 1.64, P=0.002 | Transfusion worsens graft survival
Chavers BM, 1997 CAD^‡^ N=2008 | NR | >5 transfusions vs. 0 | Graft failure | RR 1.15, P=0.288 | NA
Chavers BM, 1997 LD^†^ N=2007 | NR | >5 transfusions vs. 1–5 | Graft failure | RR 1.58, P=0.001 | >5 transfusions worsen graft survival
Chavers BM, 1997 CAD^‡^ N=2008 | NR | >5 transfusions vs. 1–5 | Graft failure | RR 1.35, P=0.002 | >5 transfusions worsen graft survival
Poli F, 1995 N=416 | Cox^*^ | Pre-transplant transfusion (0 vs. >0) | Graft survival | RR 1.2 (0.7–2.1), P=0.4 | NA
Sautner T, 1994 N=146 | Stepwise logistic regression | Number of pretransplant transfusions (5–10) | Graft loss | RR 1.7, P=0.02 | Transfusion worsens graft survival
Sautner T, 1994 N=146 | Stepwise logistic regression | Number of pretransplant transfusions (>10) | Graft loss | RR 6-fold increase, P=0.02 | Transfusion worsens graft survival
CMTSG, 1986 CyA^§^ N=142 | Cox^*^ | Transfusion< 4 units N=67 (47%) | Graft loss | RR 0.99, P=NS | NA
CMTSG, 1986 Control^‖^ N=149 | Cox^*^ | Transfusion< 4 units N=75 (50%) | Graft loss | RR 1.35, P=NS | NA

* Cox proportional hazards regression analysis

† A separate analysis involving patients receiving living-donor renal transplants

‡ A separate analysis involving patients receiving cadaver renal transplants

§ Patients received immunosuppression with cyclosporine

‖ Patients received control immunosuppression with azathioprine

CAD=cadaver transplants; CMTSG=Canadian Multicenter Transplant Study Group; CyA=cyclosporine; HR=hazard ratio; LD=living donor; N=number of patients in analysis; NR=not reported; NS=not significant; RR=relative risk

Table 35 Multivariate results: Impact of number/units of transfusion on patient survival (KQ1bii)

Study, Year Total N | Analysis Type | Covariate | Outcome Evaluated | Multivariate Results | Significant Effect
Tang H, 2008 N=2882 | Cox^*^ | 1–5 pre-transplant transfusions vs. 0 | Patient death | HR 1.29 (0.97–1.72), P=0.083 | NA
Tang H, 2008 N=2882 | Cox^*^ | 6–10 pre-transplant transfusions vs. 0 | Patient death | HR 1.64 (1.04–2.58), P<0.05 | Transfusion worsens patient survival
Tang H, 2008 N=2882 | Cox^*^ | >10 pre-transplant transfusions vs. 0 | Patient death | HR 1.98 (1.28–3.05), P<0.005 | Transfusion worsens patient survival
Herget-Rosenthal S, 2003 N=40 | Stepwise logistic regression | Multiple transfusions greater than 40 units | Patient death | RR 3.1 (1.1–9.2), P=0.03 | Transfusion worsens patient survival
Agarwal SK, 2002 N=144 | NR | Number of blood transfusions | Patient survival | NR, P=NS | NA
CMTSG, 1986 CyA^†^ N=142 | Cox^*^ | Transfusion< 4 units | Patient death | RR 0.86, P=NS | NA
CMTSG, 1986 Control^‡^ N=149 | Cox^*^ | Transfusion< 4 units | Patient death | RR 0.98, P=NS | NA

* Cox proportional hazards regression analysis

† Patients received immunosuppression with cyclosporine

‡ Patients received control immunosuppression with azathioprine

CMTSG=Canadian Multicenter Transplant Study Group; CyA=cyclosporine; HR=hazard ratio; N=number of patients in analysis; NR=not reported; NS=not significant; RR=relative risk

## Key Question 1biii Is any such impact of red blood cell transfusions on renal transplant outcomes altered by the use of leukocyte-depleted blood?

Four unique studies were included in the evaluation of the use of leukocyte-depleted blood on renal transplant outcomes.77,83,157,158 One of the studies was a controlled clinical trial, two were prospective observational studies and one was a retrospective observational study. Two studies (50 percent) were rated as fair quality, and two studies (50 percent) were rated as poor quality. Of the 12 analyses reported in these studies, 16.7 percent were from the controlled clinical trial, 66.6 percent were from the prospective observational study, and 16.7 percent were from the retrospective observational study. None (0 percent), 10 (83.3 percent), and 2 (16.7 percent) included results for graft rejection, graft survival and patient survival, respectively (Table 36).

### Rejection

None of the included analyses evaluated the impact of leukocyte-depleted blood transfusions on rejection (Table 37). Thus, we concluded that the strength of the body of evidence was insufficient upon which to base any conclusion.

### Graft Survival

#### Leukocyte-depleted versus no transfusion

None of the included analyses evaluated the significant effects of leukocyte-depleted blood versus no transfusion on 1-year or maximum duration graft survival (Table 38). To be considered in this evaluation, studies had to provide a p-value, 95 percent confidence interval, or explicitly state whether or not statistical significance was achieved. As a result, we found that the body of evidence was insufficient.

Two analyses found the magnitude of effect of leukocyte-depleted transfusions versus no transfusion was greater than a 10 percent increase on 1-year and maximum duration graft survival.77,83 We concluded that the use of leukocyte-depleted blood versus no transfusion may have beneficial effect on 1-year and maximum duration graft survival, and that the strength of evidence for these effects was low.

#### Leukocyte-depleted versus therapeutic transfusion

One study evaluated the significant effects of leukocyte-depleted transfusions versus therapeutic transfusions, and reported no significant effect on 1-year and maximum duration graft survival.77 Leukocyte-depleted blood was not found to significantly increase or decrease graft survival (Table 39). Thus, leukocyte-depleted transfusions versus therapeutic transfusions may have a neutral effect on 1-year and maximum duration graft survival, but the strength of evidence was insufficient.

Two analyses found the magnitude of effect of leukocyte-depleted blood versus therapeutic transfusions to be a small change within 10 percent in either direction in survival with regard to 1-year graft survival.77,157 For maximum duration graft survival, one analysis found the magnitude of effect to be greater than 10 percent,77 and one analysis found the magnitude of effect to be a small change within 10 percent in either direction.157 We concluded that the use of leukocyte-depleted transfusions versus therapeutic transfusions may have a neutral to beneficial effect on 1-year and maximum duration graft survival, and that the strength of evidence for these effects was low.

One study examined the effects of leukocyte-depleted blood versus leukocyte-free blood and evaluated only the magnitude of effect on 1-year and maximum duration graft survival.158 For both 1-year and maximum duration graft survival, the use of leukocyte-depleted blood versus leukocyte-free blood resulted in a greater than 10 percent increase in graft survival. This study does not explicitly meet the requirement to answer this question.

### Patient Survival

#### Leukocyte-depleted versus no transfusion

None of the included analyses evaluated the significant effects of leukocyte-depleted blood versus no transfusion on 1-year patient survival (Table 38). One analysis determined that the use of leukocyte-depleted transfusion versus no transfusion had no significant effect on the maximum duration of patient survival.77 This analysis did not find that the use of leukocyte-depleted blood versus no transfusion resulted in a significant increase or decrease in maximum duration patient survival. As only one analysis provided evidence, we concluded that the strength of evidence was insufficient to determine any conclusion.

None of the included analyses determined the magnitude of effect of leukocyte-depleted blood versus no transfusion on 1-year patient survival. One analysis found that the use of leukocyte-depleted blood versus therapeutic transfusion had a greater than 10 percent increase in patient survival.77 We found that the strength of evidence was insufficient to determine a conclusion.

#### Leukocyte-depleted versus therapeutic transfusion

None of the included analyses evaluated the significant effects of leukocyte-depleted blood versus therapeutic transfusions on 1-year patient survival. One analysis determined that the use of leukocyte-depleted transfusion versus therapeutic transfusions had no significant effect on the maximum duration of patient survival.77 This analysis did not find that the use of leukocyte-depleted blood resulted in a significant increase or decrease in maximum duration patient survival (Table 39). As only one analysis provided evidence, we concluded that the strength of evidence was insufficient to determine any conclusion.

None of the included analyses determined the magnitude of effect of leukocyte-depleted transfusions versus therapeutic transfusions on 1-year patient survival. One analysis found that the use of leukocyte-depleted blood versus no transfusion had a greater than 10 percent increase in patient survival.77 We found that the strength of evidence was insufficient to determine a conclusion.

Table 36 Insight into body of literature: Leukocyte-depleted blood (KQ 1biii)

| Rejection | Graft Survival | Patient survival | Validity of Studies
KQ 1biii. Leukocyte-depleted blood | CCT | CCT | CCT | Good
KQ 1biii. Leukocyte-depleted blood | None | 1-year – 1 analysis Max time – 1 analysis | None | None
KQ 1biii. Leukocyte-depleted blood | POBS | POBS | POBS | Fair
KQ 1biii. Leukocyte-depleted blood | None | 1-year – 2 Analyses Max time – 2 Analysis | 1-year – None Max time – 2 analyses | 2 studies
KQ 1biii. Leukocyte-depleted blood | ROBS | ROBS | ROBS | Poor
KQ 1biii. Leukocyte-depleted blood | None | 1-year – 1 Analysis Max time – 1 Analysis | None | 2 studies

CCT=clinical controlled trial, KQ=key question, Max=maximum followup time, POBS=prospective observational studies, ROBS=retrospective observational studies

Table 37 Impact of leukocyte-depleted transfusions versus no or therapeutic transfusion on rejection (KQ 1biii)

KQ 1biii | Significant Decreases in Rejection | No Significant Effect on Rejection | Significant Increases in Rejection | Decreased Risk of Rejection^*^ | No Change in Rejection^†^ | Increased Risk of Rejection^*^
Graft Rejection Any Time Point | No data | No data | No data | No data | No data | No data

* Data either showing a decrease/increase of any magnitude or notation in text stating a decrease/increase

† Data either showing no difference, or notation in text stating no change

Table 38 Impact of leukocyte-depleted transfusions versus no transfusion on graft and patient survival (KQ 1biii)

KQ 1biii | Significant Increases in Survival | No Significant Effect | Significant Decreases in Survival | >10% Increase in Survival | 10% to −10% Change in Survival | >10% Decrease in Survival
1-Year Graft Survival | No data | No data | No data | 2/2 (100.0%) | 0/2 (0.0%) | 0/2 (0.0%)
Max Duration Graft Survival | No data | No data | No data | 2/2 (100.0%) | 0/2 (0.0%) | 0/2 (0.0%)
1-Year Patient Survival | No data | No data | No data | No data | No data | No data
Max Duration Patient Survival | 0/1 (0.0%) | 1/1 (100.0%) | 0/1 (0.0%) | 0/1 (0.0%) | 1/1 (100.0%) | 0/1 (0.0%)

Table 39 Impact of leukocyte-depleted transfusions versus therapeutic transfusions on graft and patient survival (KQ 1biii)

KQ 1biii | Significant Increases in Survival | No Significant Effect | Significant Decreases in Survival | >10% Increase in Survival | 10% to −10% Change in Survival | >10% Decrease in Survival
1-Year Graft Survival | 0/1 (0.0%) | 1/1 (100.0%) | 0/1 (0.0%) | 0/2 (0.0%) | 2/2 (100.0%) | 0/2 (0.0%)
Max Duration Graft Survival | 0/1 (0.0%) | 1/1 (100.0%) | 0/1 (0.0%) | 1/2 (50.0%) | 1/2 (50.0%) | 0/2 (0.0%)
1-Year Patient Survival | No data | No data | No data | No data | No data | No data
Max Duration Patient Survival | 0/1 (0.0%) | 1/1 (100.0%) | 0/1 (0.0%) | 1/1 (100.0%) | 0/1 (0.0%) | 0/1 (0.0%)

## Key Question 1biv–v Is any such impact of red blood cell transfusions on renal transplant outcomes altered by changes in immunosuppression regimens (pre-cyclosporine, cyclosporine, later multi-drug regimens) or other changes in management over time?

We answered these two key questions together. The time period before 1984 denoted the pre-cyclosporine era, 1984–1991 denoted the cyclosporine era, and 1992-present denoted the era of newer multidrug regimens. Doing the analysis via time periods also allowed the changes in organ procurement, preservation, and transplantation as well as other management changes occurring over these time periods to be reflected in the evaluations.

Ninety-two unique studies were included in the evaluation of the impact of transfusions from before 1984, 20,24–27,29,31–36,39–45,47–64,66,67,69,70,72–76,78–83,85,86,88–93,98–103,105–108,110,111,114–117,119,120 1984–1991,^17,23,37,38,65,71,84,112^ and 1992 to present,14–16,18,19,113 of which a majority of the studies (84.8 percent) evaluated the effect of transfusion on renal allograft outcomes before 1984, while 8.7 percent and 6.5 percent reported such effects during 1984 to 1991 and from 1992 to present, respectively. Sixty-eight (87.2 percent) of the 78 studies (conducted before 1984) were retrospective observational studies. 8 (10.2 percent) were prospective studies, and only two were controlled trials (2.6 percent). Over ninety percent of the studies conducted during this time period were rated as poor. Eight studies (rated as 1 good, 3 fair, and 4 poor quality) that evaluated transfusion effects during 1984 to 1992, were retrospective studies and controlled trials, respectively. For the four (66.7 percent) rated as good, and two fair (33.3 percent) quality studies that were conducted after 1992 to present, four (66.7 percent) were clinical trials and two (33.3 percent) were retrospective studies (Table 40).

### Rejection20,35,42,44,47,50,69,70,73,76,89,92,98,102,103,108

Seven, two, and two analyses evaluated the time periods before 1984, 1984–1991, and 1992–present, respectively. Five of seven (71.4 percent), two of two (100.0 percent), and one of two (50.0 percent) analyses found a significant decrease in rejection with the use of transfusion from before 1984, 1984–1991, and 1992-present, respectively (Table 41). The remainder of the analyses found significant increases in rejection with the use of transfusion over these time periods. So while the number of analyses in the time period 1992-present was very small, it appears some measure of the protective effect of transfusion in earlier time periods was lost with 50 percent of analyses showing a benefit and 50 percent showing a detriment with transfusion. The conclusion was that up to the year 1992, transfusion has a beneficial to neutral effect on rejection, but that after 1992 transfusion may or may not provide this effect. We graded the strength of the body of evidence for such effects to be low.

Nineteen, seven, and nine analyses evaluated the directional change in rejection associated with transfusion use. Fifteen of nineteen (78.9 percent), five of seven (71.4 percent), and three of nine (33.3 percent) analyses found a decrease in rejection from before 1984, 1984–1991, and 1992-present, respectively (Table 41). As the number of analyses finding a decrease in rejection went down from time periods before 1992 to the 1992–present, the number of analyses showing an increase in rejection increased from 3 of 19 (15.8 percent) and one of seven (14.3 percent) over the time periods before 1984 and 1984–1991 to 4 of 9 (44.5 percent) analyses in the time period from 1992 to the present. Like for the evaluation above looking at statistical significance, in the time period 1992-present it appears some measure of the protective effect of transfusion was lost, although a majority of analyses (55.5 percent) still found either a beneficial or neutral effect on rejection. The conclusion was that up to the year 1992, transfusion has a beneficial to neutral effect on rejection, but that after 1992 transfusion may or may not provide this effect. We graded the strength of the body of evidence for such effects to be low.

### Graft Survival20,24–27,29,31–36,39–45,47–64,66,67,70,72–83,85,86,88,90–93,98–103,105–108,110,111,114–117,119,120

We evaluated for significant 1-year and maximum duration graft survival with the use of transfusion over the time periods before 1984 (40 and 49 analyses), 1984–1991 (4 and 6 analyses), and 1992-present (3 and 2 analyses), respectively (Table 42). For 1-year and for maximum duration graft survival, for each time period evaluated all of the analyses found either a significant increase or no significant impact on graft survival associated with the use transfusion. No analysis found a significant decrease in graft survival. However, there was shift from most analyses showing a beneficial effect to a no significant effect over time. The conclusion was that regardless of the time period, transfusion has either a beneficial or neutral effect on graft survival with a shifting away from beneficial to solidly neutral in more contemporary practice. We graded the strength of the body of evidence for such effects to be low.

We evaluated for a greater than 10 percent increase or decrease or a less dramatic change (10 percent to −10 percent) on 1-year and maximum duration graft survival with the use of transfusion over the time periods before 1984 (93 and 102 analyses), 1984–1991 (6 and 8 analyses), and 1992-present (nine and nine analyses), respectively (Table 42). For 1-year and for maximum duration graft survival, for each time period evaluated a vast majority (96–100 percent) of the analyses found either a >10 percent increase or a small change within 10 percent in either direction on graft survival associated with the use transfusion. However, there was shift towards more analyses showing a small magnitude of change on graft survival over time. The conclusion was that regardless of the time period, transfusion has a beneficial to neutral effect on graft survival. We graded the strength of the body of evidence to be low.

### Patient Survival29,33,50,53,59,62,77,86,88,89,93,99,103,106,108,111,114,120

We evaluated for significant 1-year and maximum duration patient survival with the use of transfusion over the time periods before 1984 (9 and 12 analyses), 1984–1991 (5 and 5 analyses), and 1992-present (3 and 1 analyses), respectively (Table 42). For 1-year and for maximum duration patient survival, for each time period evaluated all of the analyses found either a significant increase or no significant impact on patient survival associated with the use transfusion. The predominant number of analyses found no significant effect over time and no analysis found a significant decrease in patient survival. The conclusion was that regardless of the time period, transfusion has a beneficial to neutral effect on patient survival. We graded the strength of the body of evidence for such effects to be low.

We evaluated for a greater than 10 percent increase or decrease or a less dramatic change (10 percent to −10 percent) on 1-year and maximum duration patient survival with the use of transfusion over the time periods before 1984 (19 and 23 analyses), 1984–1991 (5 and 8 analyses), and 1992-present (6 and 6 analyses), respectively (Table 42). For 1-year and for maximum duration patient survival, for each time period evaluated a vast majority (87–100 percent) of the analyses found either a >10 percent increase or a small change within 10 percent in either direction on patient survival associated with the use transfusion. The predominant number of analyses found no significant effect over time. The conclusion was that regardless of the time period, transfusion has a beneficial to neutral effect on patient survival. We graded the strength of the body of evidence to be low.

Table 40 Insight into body of literature: Impact of transfusions over different time periods (KQ 1biv–v)

KQ 1b(iv-v) | Rejection | Graft Survival | Patient survival | Validity of Studies
Before 1984 | CCT 1 Analyses | CCT 1-Year – 3 Analyses Max Time – 3 Analyses | CCT None | Good None
Before 1984 | POBS None | POBS 1-Year – 11 Analyses Max Time – 14 Analyses | POBS 1-Year – 1 Analyses Max Time – 3 Analyses | Fair 5 studies
Before 1984 | ROBS 18 Analyses | ROBS 1-Year – 79 Analyses Max Time – 85 Analyses | ROBS 1-Year – 18 Analyses Max Time – 20 Analyses | Poor 73 studies
Initiated 1984–1992 | CCT 2 Analyses | CCT 1-Year – 2 Analyses Max Time – 2 Analyses | CCT 1-Year – 2 Analyses Max Time – 2 Analyses | Good 1 study
Initiated 1984–1992 | POBS None | POBS None | POBS None | Fair 3 studies
Initiated 1984–1992 | ROBS 5 Analyses | ROBS 1-Year – 4 Analyses Max Time –6 Analyses | ROBS 1-Year – 3 Analyses Max Time – 5 Analyses | Poor 4 studies
1992-Present | CCT 5 Analyses | CCT 1-Year – 5 Analyses Max Time – 5 Analyses | CCT 1-Year – 5 Analyses Max Time – 5 Analyses | Good 4 studies
1992-Present | POBS None | POBS None | POBS None | Fair 2 studies
1992-Present | ROBS 4 Analyses | ROBS 1-Year – 4 Analyses Max Time – 4 Analyses | ROBS 1-Year – 1 Analyses Max Time – 1 Analyses | Poor 0 study

CCT=clinical controlled trial, KQ=key question, Max=maximum followup time, POBS=prospective observational studies, ROBS=retrospective observational studies

Table 41 Impact of transfusion over different time periods on rejection (KQ1biv-v)

Impact of transfusions on graft rejection | Significant Decreases in Rejection | No Significant Effect on Rejection | Significant Increases in Rejection | Decrease Risk of Rejection^*^ | No Change in Rejection^†^ | Increase Risk of Rejection^*^
Before 1984 | 5/7 (71.4%) | 0/7 (0.0%) | 2/7 (28.6%) | 15/19 (78.9%) | 1/19 (5.3%) | 3/19 (15.8%)
Initiated 1984 to 1991 | 2/2 (100.0%) | 0/2 (0.0%) | 0/2 (0.0%) | 5/7 (71.4%) | 1/7 (14.3%) | 1/7 (14.3%)
1992 – Present | 1/2 (50.0%) | 0/2 (0.0%) | 1/2 (50.0%) | 3/9 (33.3%) | 2/9 (22.2%) | 4/9 (44.5%)

* Data either showing a decrease/increase of any magnitude or notation in text stating a decrease/increase

† Data either showing no difference, or notation in text stating no change

Table 42 Impact of transfusions over different time periods on graft and patient survival (KQ 1biv-v)

Impact of transfusions on: | Significant Increases in Survival | No Significant Effect | Significant Decreases in Survival | >10% Increase in Survival | 10% to −10% Change in Survival | >10% Decrease in Survival
1 Year Graft Survival
Before 1984 | 24/40 (60.0%) | 16/40 (40.0%) | 0/40 (0.0%) | 60/93 (64.5%) | 30/93 (32.3%) | 3/93 (3.2%)
Initiated 1984 to 1991 | 0/4 (0.0%) | 4/4 (100.0%) | 0/4 (0.0%) | 1/6 (16.7%) | 5/6 (83.3%) | 0/6 (0.0%)
1992 – Present | 0/3 (0.0%) | 3/3 (100.0%) | 0/3 (0.0%) | 1/9 (11.1%) | 8/9 (88.9%) | 0/9 (0.0%)
Max Time Graft Survival
Before 1984 | 23/49 (46.9%) | 26/49 (53.1%) | 0/49 (0.0%) | 65/102 (63.7%) | 33/102 (32.4%) | 4/102 (3.9%)
Initiated 1984 to 1991 | 2/6 (33.3%) | 4/6 (66.7%) | 0/6 (0.0%) | 3/8 (37.5%) | 5/8 (62.5%) | 0/8 (0.0%)
1992 – Present | 0/2 (0.0%) | 2/2 (100.0%) | 0/2 (0.0%) | 2/9 (22.2%) | 7/9 (77.7%) | 0/9 (0.0%)
1 Year Patient Survival
Before 1984 | 0/9 (0.0%) | 9/9 (100.0%) | 0/9 (0.0%) | 1/19 (5.3%) | 16/19 (84.2%) | 2/19 (10.5%)
Initiated 1984 to 1991 | 0/5 (0.0%) | 5/5 (100.0%) | 0/5 (0.0%) | 0/5 (0.0%) | 5/5 (100.0%) | 0/5 (0.0%)
1992 – Present | 0/3 (0.0%) | 3/3 (100.0%) | 0/3 (0.0%) | 0/6 (0.0%) | 6/6 (100.0%) | 0/6 (0.0%)
Max Time Patient Survival
Before 1984 | 1/12 (8.3%) | 11/12 (91.7%) | 0/12 (0.0%) | 6/23 (26.1%) | 14/23 (60.9%) | 3/23 (13.0%)
Initiated 1984 to 1991 | 0/5 (0.0%) | 5/5 (100.0%) | 0/5 (0.0%) | 2/8 (25%) | 5/8 (62.5%) | 1/8 (12.5%)
1992 – Present | 0/1 (0.0%) | 1/1 (100.0%) | 0/1 (0.0%) | 0/6 (0.0%) | 6/6 (100.0%) | 0/6 (0.0%)

## Key Question 2a How have panel reactive antibody (PRA) assays changed over time? Do all PRA assays measure the same things? What things contribute to intra-assay variability (e.g., time, when during the dialysis cycle the sample was obtained, statin use)? How correlative or independent of one another are these measures?

### Panel Reactive Antibody Testing

This question was designed to be answered narratively rather than as a result of a systematic review. It is devised to provide background information to the stakeholder.

Panel reactive antibody (PRA) testing seeks to evaluate who is most at risk of hyperacute or humoralrejection.159 To orient the stakeholder, a PRA of eighty percent is supposed to reflect that the patient is crossmatch incompatible with 80 percent of donors. In general, patients with a PRA of more than 10 percent or more than 80 percent are considered sensitized or highly/broadly sensitized, respectively. However, different centers and investigators can use markedly different PRA cut offs for determining sensitized and highly/broadly sensitized. This system has been used since the 1960s in the United States.159

There are three types of assays used to determine PRA. The oldest is the Complement Dependent Cytotoxicity (CDC) test.159,160 In this test, patient serum is tested against donor lymphocytes (B and T cells). Patients antibodies will coat antigen expressing lymphocytes and upon administration of complement to the serum, lymphocytes are killed and detected by cell stain. This method has several limitations. It only detects complement fixing antibodies (HLA Class I), detects non-HLA antigens, depends on lymphocyte and complement quality (acquisition and storage variability), and is limited by the cell panel used. As such, the CDC cannot be the only test of sensitization. The next type of assay is the Enzyme-Linked Immunoabsorbant Assay (ELISA) which is a solid phase assay which is more sensitive than the CDC. Available kits include the Quickscreen and QuickID which only detects HLA Class I antibodies and the B-Screen, LATM, and PRA-STAT which detects HLA Class I and II antibodies. The final type of assay is the flow cytometry test. There is the house method where locally acquired whole lymphocytes are used and a microbead method which uses purified HLA antigen coated microbeads. These methods allow determination of HLA Class I and II antibodies and specifies which HLA mismatches occur. Commerical kits include the Flow PRA and Luminextests. The CDC is thought to be inferior to the HLA Class I and II ELISA and microbead flow cytometry tests which are similar to each other.159–161

In two main evaluations, the ELISA and flow cytometry assays were found to be well correlated. 161,162 In the first study, two ELISA assay kits (Quickscreen (QS) and LATM (LATM)) were compared against each other and against a flow cytometrymicrobead kit (FlowPRA). The correlation in detecting HLA Class I and II antibodies were determined separately. The correlations between the findings between the different assay kits are given below:

- ELISA Class I Assay (QS) with Flow Cytometry Class I (FPRAI); r = 0.72
- ELISA Class I Assay (QS) with ELISA Class I Assay (LATMI); r = 0.81
- Flow Cytometry Class I (FPRAI) with ELISA Class I (LATMI); r = 0.72
- ELISA Class II Assay (QSB) with Flow Cytometry Class II (FPRAII); r = 0.87
- ELISA Class II Assay (QSB) with ELISA Class I Assay (LATMII); r = 0.84
- Flow Cytometry Class II (FPRAII) with ELISA Class I (LATMII); r = 0.89

So there was a strong correlation between two ELISA assay kits and with either ELISA kit versus the flow cytometry kit.161 In the second study, an ELISA kit (PRA-STAT) was compared with a flow cytometry kit (Flowscreen) and with a CDC technique. The ELISA and flow cytometry assays for HLA Class I and II were well correlated (r=0.86, p<0.001). When evaluated in patients with graft failure, the correlation between these two assay types for HLA Class I and II was not as robust but still significant (r=0.49, p<0.001). In this population with graft failure, the correlation between CDC assay and the ELISA (r=0.28, p<0.001) or flow cytometry assay (r=0.30, p<0.001) for HLA Class I antibodies was low but still significant. CDC does not allow the determination of HLA Class II.162 The CDC correlation to ELISA for Class I antibodies in this study is similar to that seen in two previous studies but not seen in a third.163–165

There are some fundamental problems with PRA testing. There are different types of assays and differences within assay classes which alter sensitivity and specificity. Forty-four percent of centers used peak PRA while 56 percent of centers use current PRA. The superiority of one approach over another is debatable but important since PRA may be altered in response to stimuli but may moderate over time. PRA response may be altered by the use of medications (rituximab, immune globulin, statins, cyclophosphamide/predisolone with plasmapheresis) or certain Angiotensin Converting Enzyme genotypes.166–171 The composition of antigen panels can vary depending on the kit utilized or the cells that were locally procured. The antigen panels may differ in substantive ways from the donor population. Finally, even without altering PRA levels, the use of induction therapy with antithymocyte globulin might ameliorate or attenuate the negative impact of higher PRA levels on graft outcomes.

In one study, 241 transplanted patients were divided in to groups based on peak PRA levels. 172 Those with a peak PRA of 0–29 percent had better survival at one (90 percent vs. 79 percent, p<0.05) and three years (82 percent vs. 64 percent, p<0.05) than those with PRAs of 30–60 percent. Detailed analysis of those in the higher peak PRA group found that better compatibility on the DR locus, a primary kidney transplant, a dialysis duration of less than 6 months, and the prophylactic use of antithymocyte globulin significantly improved graft outcome. This shows that the impact of PRA on outcomes is multifactorial in nature.

### Calculated PRA Testing

In October 1, 2009, the United Network for Organ Sharing (UNOS) recommended against the current PRA system and for a calculated PRA (CPRA) system.159 CPRA is based on the unacceptable HLA antigens to which patients are sensitized and which, if present in the donor, would represent an unacceptable risk for the candidate. CPRA has much greater applicability than traditional PRA because CPRA is based on HLA antigen frequencies among 12,000 kidney donors in the United States between 2003 and 2005 and represents the percentage of actual organ donors that express one or more unacceptable HLA antigens. If an HLA antibody is identified in a patient, a kidney with that antigen would not be offered. The higher the CPRA, the fewer kidneys would be offered. By March of 2009, only 13 of 256 kidney transplant centers did not enter specific HLA antigen incompatibilities into the UNOS system showing wide adoption.159

### Impact of Sensitization on Eligibility for Transplantation

Of the 146 unique studies, 120 studies (82 percent) either did not report any sensitization results or evaluated sensitization results retrospectively only in those who received transplantation. As such, these data cannot be used to determine the impact of sensitization from transfusions on the ability to receive transplantation. The listing of these study results is included in Appendix E.

Twenty-six studies (18 percent) reported 37 analyses on the impact of transfusion on sensitization and its subsequent effect on eligibility for transplantation (Table 43). The sensitization rate in the 26 studies ranged from 1.9 percent to 45.5 percent, and it was assessed either based on the presence of cytotoxic antibodies or positive T-cell and/or B-cell crossmatches. Among sensitized patients, the percentage who were not subsequently transplanted with their planned kidney ranged from 0 percent to 100 percent. In many cases the outcomes of patients not originally transplanted were not given. However, where specified (Table 43), provides the known outcomes of these patients. In many cases, patients were subsequently transplanted although the time to transplant was prolonged, the type of kidney (cadaver versus living) given was different than originally planned, or patients were given interim therapy (plasmapheresis); although some patients died waiting for transplantation.

Of the 37 analyses: 10 analyses (27 percent) showed more sensitized patients were transplanted with their planned kidney than were not transplanted (including 6 analyses where all sensitized patients received transplantation)19,52,77,95,102,131,135,173,174 while 21 analyses (57 percent),14,30,65,70,86,92–94,97,99,103,104,108,122,132,133,136 found that more patients were precluded from receiving their planned transplantations (including 19 analyses where all sensitized patients were not transplanted with their planned kidneys). The remaining six analyses were part of DST versus random transfusion studies and in the random transfusion arms, they did not report transplantation status in sensitized patients.19,65,86,97,133,135

Amongst the 37 analyses, 21 and 16 analyses reported sensitization outcomes on subgroups of patients who received DST and other non-DST transfusions, respectively. Eighteen of the 21 DST (86 percent) analyses14,19,30,65,70,86,92–94,97,99,104,108,122,132,133,136 found that more sensitized patients were precluded from transplantation with their planned kidneys, while this was seen only in 3 of the 16 (19 percent) non-DST analyses.103,122,132

Table 43 The impact of sensitization on the eligibility for transplantation in transfused patients

Study, Year (N=) | Type of transfusion | Number of transfused patients (N_T_=) | Assessment | Number of transfused patients who were sensitized Ns/N_T_(%) | Number of sensitized patients who were transplanted with planned kidney n/Ns (%) | Number of sensitized patients who were not transplanted with planned kidney n/Ns (%) | Comments
Jovicic S, 2010 (N=272) | DST RT | 22 132 | DST: presence of donor-specific antibodies RT: NR | 3/22 (13.6) NR | 0/3 (0) NR | 3/3 (100) NR | DST: Of the 3 patients not transplanted with the planned grafts, 1 received cadaveric transplant, and 2 remained on HD RT: NR
Aalten J, 2009 (N=859) | DST mPTF RT | 100 86 620 | Presence of anti-HLA antibodies in the CDC | 27/100 (27.0) 7/86 (8.1) 131/620 (21.1) | 2/27 (7.4) 6/7 (85.7) NR | 25/27 (92.6) 1/7 (14.3) NR | DST & mPTF: Kidney transplantations from the intended living donor were cancelled
Marti HP, 2006 (N=110) | DST | 61 | Sensitization: positive T-cell crossmatch | 6/61 (9.8) | 0/6 (0) | 6/6 (100) | Of the 6 patients not transplanted with the planned grafts, 5 received cadaveric transplants instead of living transplants without delay, and 1 was lost to follow-up
Sakagami K, 1992 (N=109) | DST | 57 | T-cell crossmatch | 4/57 (7.0) | 0/4 (0) | 4/4 (100) | Of the 4 patients not transplanted with the planned grafts, all were placed on cadaveric waiting list
Potter DE, 1991 (N=739) | DST RT | 105 453 | T-cell crossmatch | 22/105 (21.0)^*^ NR | 0/22 (0) NR | 22/22 (100) NR | DST; NR RT: NR
Reed A, 1991 (N=127) | DST RT | 74 53 | Crossmatch | 7/74 (9.5) 1/53 (1.9) | 0/7 (0) 0/1 (0) | 7/7 (100) 1/1 (100) | DST: Of the 7 patients not transplanted with the planned grafts, 5 received cadaver transplant, 1 received HLA-identical living-related transplant, 1 did not receive any transplant RT: 1 received cadaver transplant
Salvatierra O, 1991 (N=118) | DST | 71 | NR | 6/71 (8.4) | 6/6 (100) | 0/6 (0) | NA
Sells RA, 1989 (N=171) | DST RT | 81 37 | A permanent antidonor T cell or B cell antibody | 12/81 (14.8) NR | 0/12 (0) NR | 12/12 (100) NR | Outcomes not reported for the 12 patients who were not transplanted
Casadei DH, 1987 (N=46) | DST | 26 | Crossmatch | 2/26 (7.7) | 0/2 (0) | 2/2 (100) | Outcomes not reported for the 2 patients who were not transplanted
Cheigh JS, 1987 (N=60) | DST | 60 | Donor-specific lymphocytotoxic antibodies | 5/60 (8.3) | 0/5 (0) | 5/5 (100) | Outcomes not reported for the 5 patients who were not transplanted
Huprikar AG, 1987 (N=66) | DST RT | 33 33 | Cytotoxic lymphocyte crossmatch | 3/33 (9.1) 4/33 (12.1) | 0/3 (0) 0/4 (0) | 3/3 (100) 4/4 (100) | DST: Of the 3 patients not transplanted with the planned grafts, 2 delayed transplant by 1–2 weeks, and 1 had plasmapheresis, then transplant RT: All 4 patients delayed transplants by 2–8 weeks
Salvatierra O, 1987 a^†^ (N=493) | DST | 184 | A positive T warm crossmatch or a positive B warm crossmatch with a concomitant positive fluorescence-activated cell sorter crossmatch | 44/184 (23.9) | 0/44 (0) | 44/44 (100) | Outcomes not reported for the 44 patients who were not transplanted
Takahashi K, 1987 (N=290) | DST RT | 171 119 | T cells and (warm and cold) B cells crossmatch | 21/171 (12.3)^‡^ NR | 21/21 (100) NR | 0/21 (0) NR | DST: NA RT: NA
Leivestad T, 1986 (N=151) | DST | 52 | Persistent cytotoxic antibodies to donor T and B cells | 9/52 (17.3) | 0/9 (0) | 9/9 (100) | Of the 9 patients not transplanted with the planned grafts, 1 received alternative live donor transplant, and 8 received cadaver transplant after waiting 2–42 months
Glass NR, 1985 (N=250) | DST DST+AZA RT | 62 113 75 | Donor leukocyte crossmatch | 19/62 (30.6) 16/113 (14.2) NR | 0/19 (0) 0/16 (0) NR | 19/19 (100) 16/16 (100) NR | Outcomes reported include patients who were sensitized and those with “unsuitable donors.”
Sommer BG, 1985 (N=49) | DST | 32 | Cross-match testing against donor T- and B-lymphocytes Transplant done only with negative crossmatch | 3/32 (9.4) | 0/3 (0) | 3/3 (100) | 2 of the 3 patients received cadaver transplants, and the remaining patient had DST stopped & received original donor transplant
Akiyama N, 1984 (N=81) | DST | 63 | Cross-match | 8/63 (12.7) | 6/8 (75.0) | 2/8 (25.0) | Of the 2 patients not transplanted with the planned grafts, 1 not transplanted due to positive crossmatch, and the other patient received graft after some period of time
Gardner B, 1984 (N=100) | RT | 75 | NR | 16/75 (21.3) | 16/16 (100) | 0/16 (0) | NA
Sijpkens YWJ, 1984 (N=59) | DST | 33 | Crossmatch; PRA | 15/33 (45.5)^‡^ | 0/15 (0) | 15/15 (100) | Of the 15 patients not transplanted with the planned grafts, 4 received permanent dialysis, another 4 received cadaver transplant, and 7 patients awaited cadaver transplant
Nubé MJ, 1983 (N=55) | PT RT | 15 26 | Antibody positive : >5% reactive with panel | 4/15 (26.7) 11/26 (42.3) | 4/4 (100) 11/11 (100) | 0/4 (0) 0/11 (0) | NA NA
d’Apice AJ, 1982 (N=63) | RT | 63 | Development of lymphocytotoxic antbodies to 10% or more of the panel | 20/63 (31.7) | 18/20 (90.0) | 2/20 (10.0) | Of the 2 patients not transplanted with the planned grafts, 1 was refused for transplant, and the other patient remained on dialysis
Takahashi I, 1982 (N=40) | DST | 24 | Antibodies for donor T and B lymphocytes | 1/24 (4.2) | 0/1 (0) | 1/1 (100) | Outcomes not reported for the patient who was not transplanted
Salvatierra O, 1980 (N=45) | DST | 45 | Crossmatch (cold and warm T- and B-lymphocytes) | 13/45 (28.9)^‡^ | 0/13 (0) | 13/13 (100) | Of the 13 patients not transplanted with the planned grafts, 4 patients received cadaver transplant. Outcomes not reported for remaining 9 patients
Solheim BG, 1980 (N=395) | RT | 196 | Lymphocytotoxic antibodies | 48/196 (24.5) | 32/48 (66.7) | 16/48 (33.3) | Of the 16 patients not transplanted with the planned grafts, 14 died, and 2 were on a waiting list
Solheim BG, 1980 (N=191) | RT | 85 | Crossmatch; Presence of HLA antibodies | 11/85 (10.6) [described as having HLA antibodies] | 0/11 (0) | 7/11 (63.6) | Outcomes for 4 patients not reported (transplant status unknown) Of the 7 patients who not transplanted with the planned grafts, 3 received cadaver transplant, another 3 still waiting for cadaver transplant, and 1 patient died while waiting for cadaver transplant
Opelz G, 1973 (N=144) | RT | 144 | Cytotoxicity positive: ≥5% reactivity against random donor panel | 63/144 (43.8) | 63/63 (100) | 0/63 (0) | NA

* Sensitization based on positive crossmatch

† Salvatierra 1987a included a subgroup of transfused population whose crossmatches were performed

‡ Patients with a positive Tcell crossmatch or persistant positive warm Bcell crossmatch were considered as sensitized.

Anti-PBL=antiperipheral blood lymphocytes, CD=cadaveric donor transplantation, CMTSG=Canadian Multicenter Transplant Group, DST=donor specific transfusion, HLA=human leukocyte antigen, LD=living donor transplantation, LP=leukocyte-poor transfusions, mPTF=matched pretransplant transfusion, PRC=packed red cell transfusion, PT=protocol transfusion, RT=random transfusion, NA=not applicable, N=Total number of study population, n=number of patients in the subgroup, NR=not reported, NT=Number of transfused patients, Ns=number of sensitized patients

## Key Question 2b How useful are PRA assays in predicting sensitization from blood transfusions, donor specific antigen (DSA) sensitization, and renal transplant rejection/survival—especially in the setting of Q2a?

### Univariate Analysis Results

#### Rejection

Two studies with two analyses evaluated the impact of PRA on graft rejection (Table 44).35,175 In both analyses, the risk of rejection was not significantly elevated for the higher PRA group but was qualitatively lower when lower PRA groups were compared with higher PRA groups. Thus, we concluded that lower PRA is associated with a non-significant effect on rejection and graded the strength of the body of evidence as low.

#### Graft Survival

Fourteen studies with eighteen analyses evaluated the impact of different PRA levels (Table 45). Eleven of these analyses evaluated graft survival at 1-year 24,24,41,45,109,149,173–177 and all 18 of these analyses evaluated maximum duration graft survival (Table 45). In many cases, the use of peak or current PRA was not specified.

The 1-year graft survival was significantly better with lower versus higher PRA levels in four of eight (50.0 percent)109,175,177 analyses that assessed for significance and not significantly different in the other analyses. The 1-year graft survival, where the direction of effect regardless of significance was assessed, for the lower PRA groups had higher graft survival in 10 of 11 (90.9 percent) analyses and lower survival in 1 of 11 (9.1 percent)41 analyses. We concluded that lower PRA is associated with a beneficial to neutral effect on 1-year graft survival and graded the strength of the body of evidence as low.

The maximum duration graft survival was significantly better with lower versus higher PRA levels in 5 of 14 (35.7 percent) analyses that assessed for significance and not significantly different in the other analyses. The maximum duration graft survival, where the direction of effect regardless of significance was assessed, for the lower PRA groups had higher graft survival in 16 of 18 (88.9 percent) analyses and lower survival in 2 of 18 (11.1 percent) analyses. We concluded that lower PRA is associated with a beneficial to neutral effect on maximum duration graft survival and graded the strength of the body of evidence as low.

#### Patient Survival

One study with two analyses evaluated the impact of different PRA levels (Table 46).53 Neither of these analyses evaluated the patient survival at 1 year and both of these analyses evaluated maximum duration of patient survival. The maximum duration patient survival was not significantly better for the lower PRA groups. We concluded that lower PRA is associated with a neutral effect on maximum duration patient survival and graded the strength of the body of evidence as low.

### Multivariate Analysis Results

Seven studies were conducted evaluating the multivariate predictors of rejection, graft survival, or patient survival (Table 47). One study with two analyses (one for current and one for peak PRA) evaluated for rejection122 and neither found that having a PRA >40 percent was an independent predictor of rejection. Seven analyses from six studies evaluated for graft survival84,87,123,124,128,153 and in four analyses (57.1 percent),123,124,128,153 having a lower PRA was a multivariate predictor of better graft survival. In the other three analyses,85,87 having a lower PRA was not an independent predictor of graft survival and in no cases was it an independent predictor or worse graft survival. Three analyses124,128 evaluated for patient survival and in one of the three (33.3 percent),124 having a lower PRA was an independent predictor of better patient survival. In the other two cases,128 it was not an independent predictor of patient survival and in no case was it an independent predictor of worse patient survival.

Table 44 Evidence depicting the association between PRA assays in predicting rejection (KQ 2b)

Study, Year (n) | Study Design | Transfused | PRA cut-off (%) | Rejection (%) 12 Months | Rejection (%) Max | Results
De Mattos, 1999 (N= 108) | RO | Heterogeneous | Peak PRA ≤ 2 Peak PRA >2 | NR | 44 52 Followup NR P = 0.6 | The incidence of rejection episodes was not significantly increased in the Peak PRA >2 group in comparison to the Peak PRA ≤ 2 group
Albrechtsen, 1987 (N= 214) | CCT | Heterogeneous | PRA <10 PRA >10 | 46 69 P = NS | 46 69 Followup 1 Year P = NS | The incidence of rejection episodes was not significantly increased in the PRA >10 group in comparison to the PRA <10 group

CCT = controlled clinical trial; NR = not reported, NS = not significant; P=p-value; PRA = Panel Reactive Antibodies; RO = retrospective observational

Table 45 Evidence depicting the association between PRA assays in predicting graft survival (KQ 2b)

Study, Year (n) | Study Design | Transfused | PRA cut-off (%) | Graft Survival (%) 12 Months | Graft Survival (%) Max | Results
Opelz, 2005a * (N= 4,048) | RO | Heterogeneous | Negative PRA 1–50 PRA >50 | 83 80 72 P < 0.0001 | 72 63 56 Followup 10 - Year P < 0.0001 | Graft survival significantly better for PRA negative group at 1 year and 10 years
Opelz, 2005b † (N= 160,486) | RO | Heterogeneous | Negative PRA 1–50 PRA >50 | 95 94 93 P = 0.0831 | 48 40 See footnote^‡^ Followup 10 - Year P = < 0.0001 | Graft survival better for “PRA Negative” but not significant at 1 year Graft survival significantly better for PRA negative group at 10 year
Albrechtsen, 1987 (N= 214) | CCT | Heterogeneous | PRA <10 PRA >10 | 93 69 P < 0.01 | 93 69 Followup 1-Year P < 0.01 | Graft survival significantly better for PRA <10 group at 1 year
Bucin, 1988a (N=116) | RO | Yes | Antibodies absent^§^ Antibodies present^§^ | NR | 49 63 Followup 2-Year P=NR | Graft survival worse for “antibodies absent” but with no statistical analysis at 2 years
Bucin, 1988b (N=116) | RO | No | Antibodies absent § Antibodies present § | NR | 61 50 Followup 2-Year P=NR | Graft survival better for “antibodies absent” group but with no statistical analysis at 2 years
Alarif, 1987 (N= 121) | RO | Yes | PRA <10 PRA ≥ 10 | NR | 90 63 Followup NR P = 0.011 | Graft survival significantly better for PRA <10 group at not specified time point
Betuel, 1982 (N=278) | RO | Heterogeneous | Negative PRA 5–50 PRA >50 | 81 78 74 P = NR | 74 66 NR Followup 2 Year P=NS | Graft survival better for “PRA Negative” but with no statistical analysis at 1 year Graft survival better for “PRA Negative” but not significant at 2 years
d’Apice, 1982 (N= 54) | RO | Yes | PRA <10 PRA ≥ 10 | 68 55 P = NS | 65 55 Followup 1.5 Year P=NS | Graft survival better for PRA <10 but not significant at 1 and 1.5 year
Cho, 1983 (N= 647) | RO | Yes | PRA <10 PRA 10–50 PRA >50 | 74 67 48 P = NS | 74 62 48 Followup 2 Year P=NS | Graft survival better for PRA <10 but not significant at 1 year and 2 year
De Mattos, 1999 (N= 108) | RO | Heterogeneous | Peak PRA ≤ 2 Peak PRA >2 | NR | 76 75 Followup 10 Year P = 0.9 | Graft survival better for PRA ≤2 but not significant at 10 years
Feduska, 1981 (N= 732) | RO | Heterogeneous | PRA 0–10 PRA 11–50 PRA >50 | 50 52 61 P=NR | 34 24 36 Followup 5 Year P=NR | Graft survival better for >50 than lower levels with no statistical analysis at 1 year and 5 years
Flechner, 1982 (N= 100) | RO | Heterogeneous | PRA < 10 PRA > 10 | 67 56 P=NS | 67 56 Followup 1 Year P=NS | Graft survival better for PRA <10 but not significant at 1 year
Garvin, 1983a (N= 118) | RO | Heterogeneous | PRA < 10 PRA > 10 | NR | 58.3 50 Followup NR P=NS | Graft survival better for PRA <10 but not significant
Garvin, 1983b (N= 118) | RO | Heterogeneous | PRA < 10 PRA > 10 | NR | 73.3 50 Followup NR P=NS | Graft survival better for PRA <10 but not significant
Opelz, 1973 (N= 144) | RO | Yes | PRA <5 PRA ≥ 5 | NR | 47 6 Followup NR P<0.001 | Graft survival significantly better for PRA <5 at non specified time point
Opelz, 1972 (N= 829) | RO | NR | PRA <5 PRA ≥ 5 | 55 36 P = NR | 52 30 Followup 1.5 Year P = NR | Graft survival better for PRA <5 but with no statistical analysis at 1 and 1.5 year
Takiff, 1988a (N= 33,594) | RO | Heterogeneous | Curent PRA 0–10 Curent PRA 11–20 Curent PRA 21–50 Curent PRA >50 | 61 62 62 57 P < 0.025 | 30 30 31 23 Followup 10 Year P=NS | Graft survival significantly better for Current PRA <50 groups at 1 year but not at 10 year
Takiff, 1988b (N= 33,594) | RO | Heterogeneous | Peak PRA 0–10 Peak PRA 11–20 Peak PRA 21–50 Peak PRA >50 | 62 60 61 55 P <0.005 | 27 30 28 22 Followup 10 Year P=NS | Graft survival significantly better for Peak PRA <50 groups at 1 year but not at 10 year

* Cadaver kidney transplant populations

† HLA-identical sibling transplant populations

‡ Cannot be extrapolated from the figure

§ Study reported results of presence or absence of antibody assessed by local panel of donors

CCT = controlled clinical trial; N = number; NR = not reported; NS = not significant; P=p value; PRA = Panel Reactive Antibodies; RO = retrospective observational

Table 46 Evidence depicting the association between PRA assays in predicting patient survival (KQ 2b)

Study, Year (n) | Study Design | Transfused | PRA cut-off (%) | Patient Survival (%) 12 Months | Patient Survival (%) Max | Results
Garvin, 1983a (N= 118) | RO | Heterogeneous | PRA < 10 PRA > 10 | NR | 92.3 91.6 Followup NR P=NS | Patient survival better for PRA <10 but not significant
Garvin, 1983b (N= 118) | RO | Heterogeneous | PRA < 10 PRA > 10 | NR | 93.7 92.3 Followup NR P=NS | Patient survival better for PRA <10 but not significant

n=number; NR = not reported; NS = not significant; P=p value; PRA = Panel Reactive Antibodies; RO = retrospective observational

Table 47 Multivariate results depicting the association between PRA assays in predicting renal transplant outcomes (KQ 2b)

Study, Year (n) | Study Design | Analysis Type | Other Variables | PRA cut-off | Evaluated Outcomes | Multivariate Results (95% CI) | Multivariate P-value
Tang, 2008 (N= 2882) | RO | Cox proportional hazard model | Extensive number | Peak PRA level (each 10% increase) | Graft Failure | HR 1.06 (1.03–1.10) | P < 0.001
Tang, 2008 (N= 2882) | RO | Cox proportional hazard model | Extensive number | Peak PRA level (each 10% increase) | Recipient Death | HR 1.04 (1.00–1.07) | P < 0.05
Opelz, 2005 (N= 164,534) | RO | Cox’s regression analysis | Transplant Number Year of transplantation Immunosuppression Donor & recipient age, sex and race Pre-tx transfusion | PRA 1–50% vs. PRA negative before transplantation PRA > 50 vs. PRA negative before transplantation | Graft Loss Graft Loss | RR 1.29 (1.09–1.53) RR 1.87 (1.47–2.37) | P = 0.003 P < 0.0001
Bunnapradist, 2003 (N= 7079) | RO | Cox regression analysis | Recipient age >55 Male Pre-Tx transfusion Donor age HLA mismatch | PRA > 30% | Graft Failure | HR 1.39 (1.06–1.81) | 0.016
Poli, 1995 (N= 416) | RO | Cox model stepwise regression | HLA-DRB1 HLA-A,B Donor age Graft number Pre-tx transfusioin | PRA 0 (0, >0) | Graft Survival | RR 1.3 (0.6–2.8) | 0.6
Reed, 1991 (N= 127) | RO | Cox proportional hazards; Poisson random variable methods | DST Pregnancy Age Sex AB match DR match Prior transplant | Baseline PRA > 40% Peak PRA > 40% | Rejection Rejection | NR NR | P = 0.73 P = 0.91
Sanfilippo, 1986 (N= 3811 ) | RO | Cox regression model | Extensive number | Peak PRA ≥ 60% | Graft failure | RR 1.346 (NR) | 0.003
CMTSG, 1986 (N= 291) | CCT | Cox proportional-hazards model | Extensive number | Current PRA >10% | Patient Death | RR 1.28 (NR) | NS
CMTSG, 1986 (N= 291) | CCT | Cox proportional-hazards model | Extensive number | Current PRA >10% | Graft Loss | RR 2.29 (NR) | P < 0.05
CMTSG, 1986 (N= 291) | CCT | Cox proportional-hazards model | Extensive number | Highest PRA >50% | Patient Death | RR 1.15 (NR) | NS
CMTSG, 1986 (N= 291) | CCT | Cox proportional-hazards model | Extensive number | Highest PRA >50% | Graft Loss | RR 1.45 (NR) | NS
Rao, 1983 (N= 300) | RO | Exploratory multivariate regression analysis | Extensive number | PRA ≥ 50% | Graft Survival | RR NR (NR) (unfavorable effect) | P = 0.10

CCT= controlled clinical trial; CMTSG=Canadian Multicenter Transplant Study Group, DST= donor specific transfusion; HLA-A,B= human leukocyte antigen-AB; HLA-DRB= human leukocyte antigen DRB; HR= hazard ratio; N= number; NR=not reported; NS= not significant; P= p-value; PRA= Panel Reactive Antibodies; RO= retrospective observational; RR= relative risk; Tx= transfusion