# Methods

## Literature Search Strategy

A systematic literature search of Medline and the Cochrane CENTRAL (from the earliest possible date through August 2010) was conducted by two independent investigators. A search of Embase (from the earliest possible date through August 2010) was conducted to identify any additional articles that were published in non-English languages. A manual review of references from pertinent articles or review articles (backward citation tracking) was conducted to identify additional articles. No language restrictions were imposed during the literature identification stage. The search strategy was designed to answer both key questions 1 and 2, and is available in Appendix A.

## Study Eligibility Criteria

Two investigators independently determined study eligibility, with disagreements resolved by discussion or by a third investigator. Titles and/or abstracts of citations identified from our literature search were assessed for full-text review if they: (1) were controlled human studies, (2) included patients who received red blood cell transfusions prior to kidney (with or without pancreas) transplantation, and (3) reported on the relationship between pretransplant blood transfusion whether done for anemia management or for immune modulation or PRA assays and any renal allograft outcomes. Outcomes of interest pertaining to key question 1 include: (1) rejection, (2) graft survival, and (3) patient survival. Since the objective of key question 2a was to provide an overview of the use of panel reactive antibody (PRA) assay in renal transplant patients, there are no outcome restrictions in this section and were not systematically conducted. For key question 2b, studies reporting data related to the predictability of PRA assay in assessing the sensitization from blood transfusions, donor specific antigen sensitization, and renal transplant rejection/survival were included. Results published only as abstracts or poster presentations were not included in this technology assessment.

## Data Abstraction

For each included study, data were collected by two investigators independently using a standardized data abstraction tool. The following information was obtained from each study (where applicable): author identification, year of publication, source of study funding, study design characteristics, population size, study period, length of study, duration of patient followup, patient baseline characteristics (e.g., donor/recipient age, duration on dialysis, cause of renal disease, and pregnancy history), prior transplantation, type of transplant, type and number of transfusions received, reason for transfusion, and PRA levels. Endpoints included: rejection, graft survival, patient survival, and degree of sensitization.

## Validity Assessment

Validity assessment was performed using the recommendations in the Methods Guide for Effectiveness and Comparative Effectiveness Reviews. The following individual criteria were assessed (where applicable): comparable study groups at baseline, detailed description of study outcomes, blinding of subjects, blinding of outcome assessors, intent-to-treat analysis, description of participant withdrawals, and potential conflicts of interest. Additionally, randomized controlled trials were evaluated for randomization technique and allocation concealment. Observational studies were assessed for sample size, participant selection method, exposure measurement method, potential design biases, and appropriate analyses to adjust for confounding. Studies were assigned an overall score of good, fair, or poor (Table 3). This rating system does not attempt to assess the comparative validity across different types of study design. For example, a “fair” randomized controlled trial should not be implied to have the same methodological criteria as a “fair” observational study. Both study design and quality rating should be considered when interpreting the methodological quality of a study.

Table 3 Summary ratings of quality of individual studies

Quality Rating | Definition
Good (low risk of bias) | These studies have the least bias and results are considered valid. A study that adheres mostly to the commonly held concepts of high quality include the following: a formal randomized, controlled study; clear description of the population, setting, interventions, and comparison groups; appropriate measurement of outcomes; appropriate statistical and analytic methods and reporting; no reporting errors; less than 20 percent dropout; and clear reporting of dropouts.
Fair | These studies are susceptible to some bias, but it is not sufficient to invalidate results. They do not meet all the criteria required for a rating of good quality because they have some deficiencies, but no flaw is likely to cause major bias. The study may be missing information, making it difficult to assess limitations and potential problems.
Poor (high risk of bias) | These studies have significant flaws that imply biases of various types that may invalidate the results. They have serious errors in design, analysis, or reporting; large amounts of missing information, or discrepancies in reporting.

## Data Synthesis

In this technology assessment, we utilized in-depth tables and figure to summarize the totality of the literature. Given severe clinical and methodological heterogeneity, the retrospective nature of virtually all studies, and the inherently poor quality of individual studies upon validity assessment, we did not pool results.

Heterogeneity came from the type of transfusion (therapeutic for anemia management or donor specific for immune modulation), different definitions of endpoints, subpopulations, and etiologies of renal failure, role of HLA-matching, living versus cadaver donor, use of perioperative transfusion, previous transplant and pregnancy, history of previous random transfusion with donor-specific transfusion (DST) trials, different time periods, and ABO blood group compatibilities. In many cases, demographics were not adequately described.

## Grading the Body of Evidence for Each Key Question

We used the criteria and methods of GRADE (Grading of Recommendations Assessment, DEvelopment) to assess the strength of evidence. This system uses four required domains – risk of bias, consistency, directness, and precision. All assessments were made by two investigators (with disagreements resolved through discussion). The evidence pertaining to each key question was classified into four broad categories: (1) “high”, (2) “moderate”, (3) “low”, or (4) “insufficient” grade. Below we describe in more detail the features that determined the strength of evidence for the different outcomes evaluated in this report (Table 4).

Table 4 Definitions for grading the strength of evidence

Grade | Definition
High | There is high confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
Moderate | Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
Low | Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of effect and is likely to change the estimate.
Insufficient | Evidence either is unavailable or does not permit estimation of an effect

### Risk of bias

Risk of bias is the degree to which the included studies, for any given outcome or comparison, have a high likelihood of adequate protection against bias. This can be assessed through the evaluation of both design and study limitations.

### Consistency

Consistency refers to the degree of similarity in the direction of the effect sizes from included studies within an evidence base. This was assessed in two main ways: 1) the effect sizes had the same sign, in that they were on the same side of unity; 2) the range of effect sizes was narrow.

### Directness

Directness refers to whether the evidence links the compared interventions directly with health outcomes, and compares two or more interventions in head-to-head trials. Indirectness implies that more than one body of evidence is required to link interventions to the most important health outcomes.

### Precision

Precision refers to the degree of certainty surrounding effect estimate(s) with respect to a given outcome. A precise estimate is an estimate that would allow a clinically useful conclusion. An imprecise estimate is one for which the confidence interval is wide enough to include clinically distinct conclusions (e.g. both clinically important superiority and inferiority), a circumstance that will preclude a conclusion.