# Executive Summary

## Background

Over 450,000 patients in the United States have end stage renal disease (ESRD).1 There are important morbidity and survival advantages to receiving renal transplantation versus dialysis.2

Human leukocyte antigens (HLA) are a set of human major histocompatibility complex derived glycoproteins that are expressed on cell surfaces and allow for discrimination of self from non-self.1 HLA have been classified into two major groups, Class I (HLA-A, HLA-B, and HLA-C) and Class II (HLA-DP, HLA-DQ, and HLA-DR). Recognition of the antigens displayed by the transplanted organ (alloantigen) is the prime event initiating the immune response against an allograft.1

Hyperacute rejection is an immediate recipient immune response against an allograft due to preformed recipient antibodies directed against the donor’s HLA.1 Acute rejection is a cell mediated process that generally occurs within 5 to 90 days after a transplant, although it can rarely occur after this time. Outside of the hyperacute rejection state, humoral rejection can still occur although less frequently than cell mediated acute rejection.3 Humoral rejection is characterized by B lymphocytes injuring the allograft through immunoglobulin and complement activities.1 The definition of chronic rejection is ambiguous, and is sometimes recognized as chronic allograft nephropathy or any immunological responses that results in slow loss of graft function with histopathological processes: tubular atrophy, interstitial fibrosis, and fibrous intimal thickening of arteries.4

There have been major advances in immunosuppressive therapy.1 Immunosuppressive therapy is broken into three categories: induction therapy, maintenance therapy, and treatment of acute rejection episodes.1 A major advance was the use of cyclosporine and newer immunosuppressants occur in the mid 1980s and early 1990s.

High-volume use of blood transfusion was originally used in attempts to maintain ESRD patients who were anemic with red cell mass ranges of 20 – 25 percent. Due to concerns with transfusion-induced infections such as hepatitis and the production of anti-HLA antibodies resulting from the exposure to blood products, efforts were made in the 1970s to avoid the use of blood transfusions in renal transplant recipients.3 During the pre-cyclosporine era, studies suggested that non-transfused renal graft recipients were at higher risk for graft rejection as compared to those transfused recipients.5,6 Subsequently, many studies attempted to define the optimal dose and timing for the transfusion effect. With the introduction of cyclosporine in the early 1980s, leading to improved renal graft and patient survival, the beneficial role of blood transfusions and HLA matching was again being questioned. Meanwhile, some preliminary trials had shown the use of matched pretransplant blood transfusion or donor-specific transfusion (DST) to be beneficial. The evidence supporting the effects (positive, negative, neutral) of pretransplant blood transfusion, regardless of therapeutic or protocol transfusion, in renal transplantation is still not well-established. It is unclear whether the benefits, if any, of pretransplant blood transfusion may be due to the modulation of immune response in which tolerance is induced.

## Objectives

This Technology Assessment evaluated data on the impact of red blood cell transfusions on renal allograft outcomes. There were two key questions with several subparts.

### Key Question 1

1a) Do red blood cell transfusions prior to renal transplant impact allograft rejection/survival and what is the magnitude of that effect relative to other factors (e.g., pregnancy, prior transplantation?)
1b) Is any such impact of red blood cell transfusions on renal transplant outcomes altered by variables such as:
  i. planned DST vs. therapeutic transfusions
  ii. the number of transfusions, the number of units of blood, and/or the number of donors
  iii. the use of leukocyte depleted blood
  iv. changes in immune-suppression regimens (pre-cyclosporine, cyclosporine, later multi-drug regimens)
  v. other changes in management over time

### Key Question 2

2a) How have panel reactive antibody (PRA) assays changed over time? Do all PRA assays measure the same things? What things contribute to intra-assay variability (e.g., time, when during the dialysis cycle the sample was obtained, statin use)? How correlative or independent of one another are these measures?
2b) How useful are PRA assays in predicting sensitization from blood transfusions, donor specific antigen (DSA) sensitization, and renal transplant rejection/survival—especially in the setting of Q2a?

## Methods

### Data Sources and Selection

A systematic literature search of Medline and the Cochrane CENTRAL (from the earliest possible date through August 2010) was conducted by two independent investigators. A search of Embase (from the earliest possible date through August 2010) was conducted to identify any additional articles that were published in non-English languages. A manual review of references from pertinent articles or review articles (backward citation tracking) was conducted to identify additional articles. No language restrictions were imposed during the literature identification stage.

Titles and/or abstracts of citations identified from our literature search were assessed for full-text review if they: (1) are controlled human studies, (2) include patients who received red blood cell transfusions prior to kidney (with or without pancreas) transplantation, and (3) report on the relationship between pretransplant blood transfusion whether done for anemia management or for immune modulation or PRA assays and any renal allograft outcomes. Outcomes of interest pertaining to key question 1 include: (1) rejection, (2) graft survival, and (3) patient survival. Since the objective of key question 2a is to provide an overview of the use of panel reactive antibody (PRA) assay in renal transplant patients, there was no outcome restriction in this section and was not systematically conducted. For key question 2b, studies in a renal transplant population with use of transfusions reporting data related to the predictability of PRA assay in assessing for renal transplant rejection/survival will be included. Results published only as abstracts or poster presentations were not included in this technology assessment.

### Data Extraction and Quality Assessment

For each included study, data were collected by two investigators independently using a standardized data abstraction tool. The following information was obtained from each study (where applicable): author identification, year of publication, source of study funding, study design characteristics, population size, study period, length of study, duration of patient followup, patient baseline characteristics (e.g., donor/recipient age, duration on dialysis, cause of renal disease, and pregnancy history), prior transplantation, type of transplant, type and number of transfusions received, reason for transfusion, and PRA levels. Endpoints included: rejection, rejection, graft survival, patient survival, and degree of sensitization.

Validity assessment was performed using the recommendations in the Methods Guide for Effectiveness and Comparative Effectiveness Reviews. The following individual criteria were assessed (where applicable): comparable study groups at baseline, detailed description of study outcomes, blinding of subjects, blinding of outcome assessors, intent-to-treat analysis, description of participant withdrawals, and potential conflicts of interest. Additionally, randomized controlled trials were evaluated for randomization technique and allocation concealment. Observational studies were assessed for sample size, participant selection method, exposure measurement method, potential design biases, and appropriate analyses to adjust for confounding. Studies were assigned an overall score of good, fair, or poor.

### Data Synthesis and Analysis

In this technology assessment, we utilized in-depth tables and figure to summarize the totality of the literature. Given severe clinical and methodological heterogeneity, the retrospective nature of virtually all studies, and the inherently poor quality of individual studies upon validity assessment, we did not pool results.

Heterogeneity came from the type of transfusion (therapeutic for anemia management or donor specific for immune modulation), different definitions of endpoints, subpopulations, and etiologies of renal failure, role of HLA-matching, living versus cadaver donor, use of perioperative transfusion, previous transplant and pregnancy, history of previous random transfusion with donor-specific transfusion (DST) trials, different time periods, and ABO blood group compatibilities. In many cases, demographics were not adequately described.

We used the methods of GRADE (Grading of Recommendations Assessment, DEvelopment) to assess the strength of evidence. This system uses four required domains – risk of bias, consistency, directness, and precision. The evidence pertaining to each key question was classified into four broad categories: (1) “high”, (2) “moderate”, (3) “low”, or (4) “insufficient” grade.

## Results

There were 1274 citations identified upon our literature search with 1198 citations remaining after duplicates were removed. After title and abstract and full text review, 271 citations remained that met inclusion and exclusion criteria. One-hundred seven of these citations were duplicate reports, had overlapping populations with other studies in the search, or were summary studies without unique data not already encompassed in the search. As such, 146 unique studies were included in this technology assessment, as were 18 supplemental studies.

A summary of the results with ratings of the strength of evidence for all key questions can be found in Table ES-1. However, we are not able to provide all of the individual analyses in the limited space within the executive summary. Please see the full report for the detailed results which is vital in fully understanding the topic area.

Table ES-1 Overview of Study Outcomes

Outcome | Total Number of Analyses | Conclusion | Strength of Evidence
KEY QUESTION 1a ENDPOINTS
REJECTION: Significant Findings Direction of Effect | 25 47 | Transfusion has a: Beneficial to no significant effect on rejection Beneficial to no effect on rejection | Low Insufficient
1-YR GRAFT SURVIVAL: Significant Findings Magnitude of Effect | 55 132 | Transfusion has a: Beneficial to no significant effect on graft survival Large beneficial impact or small impact on graft survival | Low Low
MAX DURATION GRAFT SURVIVAL: Significant Findings Magnitude of Effect | 65 146 | Transfusion has a: Beneficial to no significant effect on graft survival Large beneficial impact or small impact on graft survival | Low Low
1-YR PATIENT SURVIVAL: Significant Findings Magnitude of Effect | 16 35 | Transfusion has a: Beneficial to no significant effect on patient survival Large beneficial impact or small impact on patient survival | Low Low
MAX DURATION PATIENT SURVIVAL: Significant Findings Magnitude of Effect | 18 41 | Transfusion has a: Beneficial to no significant effect on patient survival Large beneficial impact or small impact on patient survival | Low Low
MULTIVARIATE ANALYSES: Prior Transplant Transfusion Pregnancy | 22 13 5 | The covariate has: Detrimental to no significant effect on rejection, graft survival, and patient survival Beneficial to no significant effect on rejection and graft survival Beneficial effect on rejection but detrimental to no significant effect on graft survival | Low Low Insufficient (rejection), Low (Graft Survival)
KEY QUESTION 1b i ENDPOINTS
REJECTION: Significant Findings Direction of Effect | 3 7 | DST Transfusion has a: Beneficial to no significant effect on rejection Beneficial to no effect on rejection | Low Insufficient
1-YR GRAFT SURVIVAL: Significant Findings Magnitude of Effect | 4 16 | Transfusion has a: Beneficial to no significant effect on graft survival Large beneficial impact or small impact on graft survival | Low Low
MAX DURATION GRAFT SURVIVAL: Significant Findings Magnitude of Effect | 5 17 | Transfusion has a: Beneficial to no significant effect on graft survival Large beneficial impact or small impact on graft survival | Low Low
1-YR PATIENT SURVIVAL: Significant Findings Magnitude of Effect | 2 4 | Transfusion has a: Non-significant effect on patient survival Small impact on patient survival | Insufficient Low
MAX DURATION PATIENT SURVIVAL: Significant Findings Magnitude of Effect | 2 4 | Transfusion has a: Non-significant effect on patient survival Small impact on patient survival | Insufficient Low
MULTIVARIATE ANALYSES: DST vs Non-DST | 5 | The covariate has: Beneficial to no significant effect on rejection or graft survival | Low
KEY QUESTION 1b ii ENDPOINTS
REJECTION: NUMBER OF TRANSFUSIONS: Significant Findings Direction of Effect NUMBER OF UNITS TRANSFUSED: Significant Findings Direction of Effect | 5 18 1 1 | Versus a lower number of transfusions, a higher number of transfusions is: Beneficial to no significant effect on rejection Beneficial to no effect on rejection Versus no units of blood transfused, increasing number of units: Non-significant effect on rejection No effect on rejection | Low Insufficient Insufficient Insufficient
1-YR GRAFT SURVIVAL: NUMBER OF TRANSFUSIONS VERSUS NO TRANSFUSION: Significant Findings Magnitude of Effect HIGHER VERSUS LOWER NUMBER OF TRANSFUSIONS: Significant Findings Magnitude of Effect NUMBER OF UNITS TRANSFUSED VERSUS NO TRANSFUSION: Significant Findings Magnitude of Effect HIGHER VERSUS LOWER NUMBER OF UNITS TRANSFUSED: Significant Findings Magnitude of Effect | 12 51 11 43 11 21 6 12 | 1–5, 5–10, or >10 transfusions versus no transfusions has a: Beneficial to no significant effect on graft survival Large beneficial impact or small impact on graft survival ≥5 vs. 1–5, ≥10 vs. 1–5, ≥10 vs. ≥5 transfusions has a: Beneficial to no significant effect on graft survival Large beneficial impact or small impact on graft survival 1–5, 5–10, or >10 transfusions versus no transfusions has a: Beneficial to no significant effect on graft survival Large beneficial impact or small impact on graft survival ≥5 vs. 1–5, ≥10 vs. 1–5, ≥10 vs. ≥5 transfusions has a: Beneficial to no significant effect on graft survival Large beneficial impact or small impact on graft survival | Low Low Low Low Low Low Low Low
MAX DURATION GRAFT SURVIVAL: NUMBER OF TRANSFUSIONS VERSUS NO TRANSFUSION: Significant Findings Magnitude of Effect HIGHER VERSUS LOWER NUMBER OF TRANSFUSIONS: Significant Findings Magnitude of Effect NUMBER OF UNITS TRANSFUSED VERSUS NO TRANSFUSION: Significant Findings Magnitude of Effect HIGHER VERSUS LOWER NUMBER OF UNITS TRANSFUSED: Significant Findings Magnitude of Effect | 9 53 10 47 16 22 12 16 | 1–5, 5–10, or >10 transfusions versus no transfusions has a: Beneficial to no significant effect on graft survival Large beneficial impact or small impact on graft survival ≥5 vs. 1–5, ≥10 vs. 1–5, ≥10 vs. ≥5 transfusions has a: Beneficial to no significant effect on graft survival Large beneficial impact or small impact on graft survival 1–5, 5–10, or >10 transfusions versus no transfusions has a: Beneficial to no significant effect on graft survival Large beneficial impact or small impact on graft survival ≥5 vs. 1–5, ≥10 vs. 1–5, ≥10 vs. ≥5 transfusions has a: Beneficial to no significant effect on graft survival Large beneficial impact or small impact on graft survival | Low Low Low Low Low Low Low Low
1-YR PATIENT SURVIVAL: NUMBER OF TRANSFUSIONS VERSUS NO TRANSFUSION: Significant Findings Magnitude of Effect HIGHER VERSUS LOWER NUMBER OF TRANSFUSIONS: Significant Findings Magnitude of Effect MAX DURATION PATIENT SURVIVAL: NUMBER OF TRANSFUSIONS VERSUS NO TRANSFUSION: Significant Findings Magnitude of Effect HIGHER VERSUS LOWER NUMBER OF TRANSFUSIONS: Significant Findings Magnitude of Effect | 8 8 7 7 8 7 7 5 | 1–5, 5–10, or >10 transfusions versus no transfusions has a: Non-significant effect on patient survival Large beneficial impact or small impact on patient survival ≥5 vs. 1–5, ≥10 vs. 1–5, ≥10 vs. ≥5 transfusions has a: No significant effect on patient survival Small impact on patient survival 1–5, 5–10, or >10 transfusions versus no transfusions has a: Non-significant effect on patient survival Large beneficial impact or small impact on patient survival ≥5 vs. 1–5, ≥10 vs. 1–5, ≥10 vs. ≥5 transfusions has a: No significant effect on patient survival Small impact on patient survival | Low Low Low Low Low Low Low Low
MULTIVARIATE ANALYSES: Transfusion of Varying Numbers vs. No Transfusion >5 transfusions vs. 1–5 transfusions | 16 4 | Transfusion has a: Detrimental to no significant effect on rejection or graft survival Versus 1–5 transfusions, >5 transfusions has a: Detrimental to neutral effect on rejection and graft survival | Low Low
KEY QUESTION 1b iii ENDPOINTS
1-YR GRAFT SURVIVAL: LEUKOCYTE DEPLETED VS. NO TRANSFUSION Magnitude of Effect LEUKOCYTE DEPLETED VS. TRANSFUSION: Significant Findings Magnitude of Effect | 2 1 2 | Versus no transfusion, leukocyte depleted transfusion has a: Large beneficial impact on graft survival Versus transfusion, leukocyte depleted transfusion has a: Non-significant effect on graft survival Small change in graft survival | Low Insufficient Low
MAX DURATION GRAFT SURVIVAL: LEUKOCYTE DEPLETED VS. NO TRANSFUSION Magnitude of Effect LEUKOCYTE DEPLETED VS. TRANSFUSION: Significant Findings Magnitude of Effect | 2 1 2 | Versus no transfusion, leukocyte depleted transfusion has a: Large beneficial impact on graft survival Versus transfusion, leukocyte depleted transfusion has a: Non-significant effect on graft survival Large beneficial effect or small change in graft survival | Low Insufficient Low
MAX DURATION PATIENT SURVIVAL: LEUKOCYTE DEPLETED VS. NO TRANSFUSION Magnitude of Effect LEUKOCYTE DEPLETED VS. TRANSFUSION: Significant Findings Magnitude of Effect | 1 1 1 | No effect on rejection No significant effect on rejection No effect on rejection | Insufficient Insufficient Insufficient
KEY QUESTION 1b iv-v ENDPOINTS
REJECTION: Significant Findings Direction of Effect | 11 35 | Over progressive time periods transfusion has a: Up to the year 1992, transfusion had a significant beneficial to neutral effect but after 1992, it may not have this effect Up to the year 1992, transfusion had a beneficial to neutral effect but after 1992, it may not have this effect | Low Low
1-YR GRAFT SURVIVAL: Significant Findings Magnitude of Effect | 47 108 | Over progressive time periods transfusion has a: Transfusion had a significant beneficial to neutral effect Transfusion has a large beneficial impact or small impact on graft survival | Low Low
MAX DURATION GRAFT SURVIVAL: Significant Findings Magnitude of Effect | 57 119 | Over progressive time periods transfusion has a: Transfusion had a significant beneficial to neutral effect Transfusion has a large beneficial impact or small impact on graft survival | Low Low
1-YR PATIENT SURVIVAL: Significant Findings Magnitude of Effect | 17 30 | Over progressive time periods transfusion has a: Transfusion had a significant beneficial to neutral effect Transfusion has a large beneficial impact or small impact on patient survival | Low Low
MAX DURATION PATIENT SURVIVAL: Significant Findings Magnitude of Effect | 18 37 | Over progressive time periods transfusion has a: Transfusion had a significant beneficial to neutral effect Transfusion has a large beneficial impact or small impact on patient survival | Low Low
KEY QUESTION 2b ENDPOINTS
REJECTION: Significant Findings Direction of Effect | 2 2 | Lower PRA% is associated with a: Non-significant effect on rejection Directionally less rejection | Low Insufficient
1-YR GRAFT SURVIVAL: Significant Findings Direction of Effect | 8 11 | Lower PRA% is associated with a: Significant beneficial to neutral effect Large beneficial impact or small impact on graft survival | Low Low
MAX DURATION GRAFT SURVIVAL: Significant Findings Direction of Effect | 14 18 | Lower PRA% is associated with a: Significant beneficial to neutral effect on graft survival Large beneficial impact or small impact on graft survival | Low Low
MAX DURATION PATIENT SURVIVAL: Significant Findings | 2 | Lower PRA% is associated with a: Non-significant effect on patient survival | Low
MULTIVARIATE ANALYSES: Rejection Graft Survival Patient Survival | 2 7 3 | Lower PRA is: Not an independent predictor of lower rejection Significant beneficial to neutral effect of graft survival Significant beneficial to neutral effect on patient survival | Low Low Low

PRA = Panel Reactive Antibodies, YR = Year

## Discussion

Although we evaluated a voluminous literature set, the studies were predominantly retrospective, did not account for confounding, and in many cases had sparse reporting of demographics. The studies also had very high clinical and methodological heterogeneity precluding the ability to pool results. This heterogeneity was due to the different definitions of endpoints of interest, differing subpopulations of patients, different etiologies of renal failure, studies with and without any HLA-matching, differing cold ischemia times, the use of or different mixture of living versus deceased donors, use of perioperative transfusion, previous transplant or pregnancy history, history of previous random transfusions in patients receiving DST, differing followup periods, and ABO blood incompatibilities. This high degree of clinical and methodological heterogeneity precluded the ability to pool the results.

We chose to evaluate our data based on the percentage of analyses evaluating an endpoint that either showed a significant effect (either beneficial or detrimental) or a non-significant effect. We then evaluated our data based on the direction and/or magnitude of effect (either beneficial or detrimental). This approach has limitations because analyses of varying quality and sample size were evaluated together but it provides that only type of independent qualitative analyses that can be done on such a literature base.

In the vast majority of analyses reporting the significance of their findings, the use of transfusions versus no transfusions either resulted in a significantly beneficial or insignificant effect on rejection, graft survival, or patient survival. When analyses were evaluated regardless of the significance of the findings, which allows underpowered analyses and analyses for which the original study authors did not discern the significance of their findings to be included, we found that the use of transfusions versus no transfusions either resulted in either beneficial or small/null effects on rejection, graft survival, or patient survival. For the analyses evaluating the impact of the use of larger number of transfusion/transfused units versus no, or a smaller number of transfusions/transfused units, we found mixed effect on rejection, graft survival or patient survival. So the literature, weak as it is, demonstrates a neutral to positive effect resulting from transfusion and does not reflect a detrimental effect resulting from transfusion. The same results were found when comparing DST with non-DST transfusions or leukocyte depleted/free transfusions with no or non-leukocyte depleted/free transfusions with either neutral or beneficial effects resulting.

In our Technology Assessment, having a lower PRA due to transfusion generally has a beneficial to neutral effect on outcomes. These data are limited because it does not consistently define PRA in the same manner (Peak or Current PRA), does not allow assessment for the specific HLA antibodies that the patients are incompatible with (like is becoming the standard of care with “calculated PRA”), the assays for PRA have inter and intra-assay variability, there are modulators of PRA level and the use of these modulators are not specified in the studies, the time course from exposure to transfusion or other stimuli to the time the PRA is recorded is not defined, and most importantly that the degree to which the elevated PRA in these studies were due to transfusions versus other stimuli such as transplants or other factors such as pregnancy cannot be determined. It should be noted that PRA is a surrogate measure for immunization, and its link to renal allograft outcomes is tenuous due to the myriad confounding factors such as donor types, immunosuppression used, and other factors that can influence the transplant outcomes. The purpose of this TA is not to identify a specific causal link between PRA and renal allograft outcomes, but rather to examine the available data to identify the correlation between the two in studies that did assess transfusion use and final health outcomes.

There are problems with internal validity and heterogeneity with these individual studies. As such, we have low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of effect and likely change the estimate as well. In addition, the findings of our Technology Assessment need to be viewed in light of one very important limitation. The studies, as devised, evaluated the impact of transfusions on transplantation outcomes but could only be determined among those patients who actually received transplantation. In several of our included studies, we found that a proportion of patients who were sensitized after transfusion ended up not being considered for their planned kidney and had a delay in transplantation, received a different organ type (deceased versus living), had to undergo a procedure to attenuate sensitization such as plasmapheresis, or went back on the waiting list. In some cases, patients reportedly died while on the waiting list. As such, we cannot be sure that transfusions have a beneficial to neutral effect on transplantation outcomes or select out those most likely to be successful after transplantation. It is unclear why intention-to-treat analyses were not utilized by investigators, where possible.

There are data from large registries that are published in non-peer reviewed book chapters, do not have an adequate description of methods, and in most cases do not account for a myriad of confounders. While they did not make our a priori criteria for study inclusion, they do provide provocative data that should be noted. There are at least six book chapters within the Clinical Transplants textbook that uses data from the UCLA or UNOS registries. In one book chapter using the UCLA Transplant Registry over a ten year period (1981 to 1990), the 1-year graft survival in patients undergoing first transplants was significantly better in unsensitized patients (PRA 0–10%) versus those with a PRA >50% in 5 of the 10 years.7 In the same book chapter, using data from the UCLA Transplant Registry from 1985 to 1990 or the UNOS Registry from 1987 to 1990 (the source of the evidence was not specified), the authors found that receiving more transfusions increased the number of patients undergoing a first transplant becoming sensitized. Given these two pieces of indirect evidence, it would seem intuitive that transfusions would negatively impact 1-year graft survival but like the analyses that made it into our Technology Assessment, transfusions either had a beneficial or neutral effect in both males and females who had a PRA of 0–10%, PRA of 11–50%, or PRA of >50%. Clearly there is a disconnect in logic that may suggest: (1) the benefits of reducing graft rejection through a non-PRA mechanism of transfusion overcomes the negative effect of raising PRA on graft rejection; (2) transfusions self-select those with the greater ability to do well after transplantation; or (3) another confounder explains the discrepancy but has not been evaluated. It is possible that the avoidance of incompatible organs attenuates the negative impact of elevated PRA on outcomes but in so doing, decreases the available pool of organs. This is plausible since in this book chapter, the waiting time for an organ is prolonged in both males and females when PRAs are elevated. Another chapter from this textbook using UNOS data from 1995 to 2000 shows that increasing the number of transfusions qualitatively increased the number of sensitized patients and reduced graft survival, although statistical analyses were not provided.8 In book chapter from an earlier edition of the textbook, UNOS Registry data from 1988 to 1996 was reported. It reported that increasing numbers of transfusions significantly increased sensitization (higher PRAs) and that elevated PRA (from any cause) was qualitatively associated with worse graft survival although statistical results for this latter analysis were not provided.9 In another book chapter, UCLA Registry data from 1981 to 1990 found qualitatively better 1-year graft survival annually from 1981 through 1987, similar 1-year graft survival from 1988 to 1989, and worse survival in 1990 in those with one or more transfusions versus no transfusions although the authors suggested that the 1990 data could be a spurious result produced by late reporting of followup.10 UNOS Registry data from 1987 to 1990 found similar 1-year graft survival in those with one or more transfusions versus no transfusions. Another book chapter using UNOS data reiterated similar risks of higher numbers of transfusions increasing risk of developing higher PRAs and higher PRAs (from any source) increasing risk of graft failure11 while another book chapter reiterated that patients with PRAs >50% (from any cause) have longer waiting times for transplantation.12

In the USRDS Annual Data Report in 2010, patients with higher PRAs have longer waiting times.13 Receiving a transfusion while on the transplant waiting list is associated with a 5-fold higher risk of dying while on the wait list within the first five years and an 11% reduction in the likelihood of receiving a transplant within the first 5-years. Why such a disparity exists between the relatively small reduction in transplantation and the large increase in the likelihood of death of the waiting list is unclear. The data was adjusted for age, gender, race, ethnicity, cause of end stage renal disease, blood type, body mass index, pretransplant time on dialysis, education, dialysis type, and comorbid conditions. It could be that while the risk of having no transplant within 5 years is low, the prolongation of waiting time leads to poorer outcomes, there is ultimately a poorer match, or transfusion may be a marker of some other underlying disorder that hastens death unrelated to the transfused product itself. Ultimately, these data did not meet our inclusion criteria and were not included in our results section. While the data provided by USRDS on overall transplant outcomes is extensive, the USRDS report was not focused on the direct impact of transfusions on transplant outcomes. The USRDS data collection system is limited to self-reporting of transfusion status in transplant candidates and recipients, in which it is limited to discrete data (i.e. yes, no, or unknown) on whether patients have received transfusions while the indications and/or appropriateness of the transfusions are often unknown. As such, the direct correlation of sensitization and transfusion cannot be established.

### Future Research Directions

We believe that additional adequately powered studies should be conducted. In these studies we believe that they should be multi-institutional because individual center practices and procedures are so variable, have adequate reporting of demographics and either use statistical means to account for confounders (propensity score adjustment or matching) or use of randomization, have standard definitions of outcomes, and have a standard followup time of at least 1-year. Patients receiving or being randomized to no transfusions should be screened to assure that this not only includes transfusions within the dialysis or transplant center but other transfusions as well. We believe that standard PRA testing should be supplanted with updated CPRA testing so that specific HLA antigen sensitivities resulting from transfusions can be identified and perhaps correlated with outcomes. Outcomes such as sensitization rate, access to transplantation, and waiting time to transplantation during the pretransplant time period as well as graft outcomes during post-transplant period should be evaluated.

The impact of different immunosuppressive regimens (induction and maintenance as well as novel therapies such as statins) on outcomes in patients receiving transfusions to identify those regimens which can suppress the advantageous or detrimental effects of transfusion on outcomes is needed. This should be specifically evaluated to determine whether transfusions need to be encouraged, avoided, or matched with certain regimens. Such evaluations should adhere to good study conduction practices.

Data from large scale registries could be used for future research but should be published in peer reviewed journals, have an adequate use and description of methods, have a reliable and objective data collection system, as well as account for a myriad of confounders.

## Conclusion

Transfusions generally have beneficial to neutral effects on renal allograft outcomes, and have minimal detrimental effects on the outcomes for renal transplant recipients. There is not much support for the notion that transfusions increase the risk of graft rejection among those receiving transplantation. Although there is evidence that patients receiving pretransplant transfusions have increased levels of sensitization as assessed by PRA, the relationship between the number of pretransplant transfusions and the extent of levels of sensitization is still not established. It should be noted that in some studies, patients who were candidates for transplantation were ultimately not offered the transplant due to high PRA levels. Some other studies did not disclose the number of patients who were ultimately not transplanted due to a high PRA as they focused on the population undergoing transplant. This is a major confounder in these studies.

When we examine results based on advancing time periods (before 1942, 1984 – 1991, and 1992 to the present), the percentage of analyses showing benefit is attenuated in more recently conducted studies. With regard to rejection, the data are more ambiguous with some analyses showing benefit, some showing a neutral effect, and other analyses showing harm, although the number of studies evaluating more recent time periods is quite limited.

In essence, the literature base is weak and future research conducted with proper control for confounders, disclosure of baseline characteristics, and use of other good study design techniques is needed to assess the impact of transfusions on allograft and patient survival outcomes in renal transplant recipients.

## Glossary

DST: Donor Specific Transfusion. Transfusions using the donor’s blood.
ESRD: End Stage Renal Disease. The final and most severe stage of renal disease.
HLA: Human Leukocyte Antigen. Antigens that allow the immune system to discern self from non-self.
PRA: Panel Reactive Antibodies. A determination of the extent to which a recipient is sensitized.

## References

Please refer to the reference list in the full report for documentation of statements contained in the Executive Summary.