# Discussion

Although we evaluated a voluminous literature set, the studies were predominantly retrospective, did not account for confounding, and in many cases had sparse reporting of demographics. The studies also had very high clinical and methodological heterogeneity precluding the ability to pool results. This heterogeneity was due to the different definitions of endpoints of interest, differing subpopulations of patients, different etiologies of renal failure, studies with and without any HLA-matching, differing cold ischemia times, the use of or different mixture of living versus deceased donors, use of perioperative transfusion, previous transplant or pregnancy history, history of previous random transfusions in patients receiving DST, differing followup periods, and ABO blood incompatibilities. This high degree of clinical and methodological heterogeneity precluded the ability to pool the results.

We chose to evaluate our data based on the percentage of analyses evaluating an endpoint that either showed a significant effect (either beneficial or detrimental) or a non-significant effect. We then evaluated our data based on the direction and/or magnitude of effect (either beneficial or detrimental). This approach has limitations because analyses of varying quality and sample size were evaluated together but it provides that only type of independent qualitative analyses that can be done on such a literature base.

In the vast majority of analyses reporting the significance of their findings, the use of transfusions versus no transfusions either resulted in a significantly beneficial or insignificant effect on rejection, graft survival, or patient survival. When analyses were evaluated regardless of the significance of the findings, which allows underpowered analyses and analyses for which the original study authors did not discern the significance of their findings to be included, we found that the use of transfusions versus no transfusions either resulted in either beneficial or small/null effects on rejection, graft survival, or patient survival. For the analyses evaluating the impact of the use of larger number of transfusion/transfused units versus no, or a smaller number of transfused/transfused units, we found mixed effects on rejection, graft survival, or patient survival. So the literature, weak as it is, demonstrates a neutral to positive effect resulting from transfusion and does not reflect a detrimental effect resulting from transfusion. The same results were found when comparing DST with non-DST transfusions or leukocyte depleted/free transfusions with no or non-leukocyte depleted/free transfusions with either neutral or beneficial effects resulting.

In our technology assessment, having a lower PRA due to transfusion generally has a beneficial to neutral effect on outcomes. These data are limited because it does not consistently define PRA in the same manner (Peak or Current PRA), does not allow assessment for the specific HLA antibodies that the patients are incompatible with (like is becoming the standard of care with “calculated PRA”), the assays for PRA have inter and intra-assay variability, there are modulators of PRA level and the use of these modulators are not specified in the studies, the time course from exposure to transfusion or other stimuli to the time the PRA is recorded is not defined, and most importantly that the degree to which the elevated PRA in these studies were due to transfusions versus other stimuli such as transplants or other factors such as pregnancy cannot be determined. It should be noted that PRA is a surrogate measure for immunization, and its link to renal allograft outcomes is tenuous due to the myriad confounding factors such as donor types, immunosuppression used, and other factors that can influence the transplant outcomes. The purpose of this TA is not to identify a specific causal link between PRA and renal allograft outcomes, but rather to examine the available data to identify the correlation between the two in studies that did assess transfusion use and final health outcomes.

There are problems with internal validity and heterogeneity with these individual studies. As such, we have low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of effect and likely change the estimate as well. In addition, the findings of our technology assessment need to be viewed in light of one very important limitation. The studies, as devised, evaluated the impact of transfusions on transplantation outcomes but could only be determined among those patients who actually received transplantation. In several of our included studies, we found that a proportion of patients who were sensitized after transfusion ended up not being considered for their planned kidney and had a delay in transplantation, received a different organ type (deceased versus living), had to undergo a procedure to attenuate sensitization such as plasmapheresis, or went back on the waiting list. In some cases, patients reportedly died while on the waiting list. As such, we cannot be sure that transfusions have a beneficial to neutral effect on transplantation outcomes or select out those most likely to be successful after transplantation. It is unclear why intention-to-treat analyses were not utilized by investigators, where possible.

There are data from large registries that are published in non-peer reviewed book chapters, do not have an adequate description of methods, and in most cases do not account for a myriad of confounders. While they did not make our a priori criteria for study inclusion, they do provide provocative data that should be noted. There are at least six book chapters within the Clinical Transplants textbook that uses data from the UCLA or UNOS registries. In one book chapter using the UCLA Transplant Registry over a ten year period (1981 to 1990), the 1-year graft survival in patients undergoing first transplants was significantly better in unsensitized patients (PRA 0–10%) versus those with a PRA >50% in 5 of the 10 years.7 In the same book chapter, using data from the UCLA Transplant Registry from 1985 to 1990 or the UNOS Registry from 1987 to 1990 (the source of the evidence was not specified), the authors found that receiving more transfusions increased the number of patients undergoing a first transplant becoming sensitized. Given these two pieces of indirect evidence, it would seem intuitive that transfusions would negatively impact 1-year graft survival but like the analyses that made it into our Technology Assessment, transfusions either had a beneficial or neutral effect in both males and females who had a PRA of 0–10%, PRA of 11–50%, or PRA of >50%. Clearly there is a disconnect in logic that may suggest: (1) the benefits of reducing graft rejection through a non-PRA mechanism of transfusion overcomes the negative effect of raising PRA on graft rejection; (2) transfusions self-select those with the greater ability to do well after transplantation; or (3) another confounder explains the discrepancy but has not been evaluated. It is possible that the avoidance of incompatible organs attenuates the negative impact of elevated PRA on outcomes but in so doing, decreases the available pool of organs. This is plausible since in this book chapter, the waiting time for an organ is prolonged in both males and females when PRAs are elevated. Another chapter from this textbook using UNOS data from 1995 to 2000 shows that increasing the number of transfusions qualitatively increased the number of sensitized patients and reduced graft survival, although statistical analyses were not provided.8 In book chapter from an earlier edition of the textbook, UNOS Registry data from 1988 to 1996 was reported. It reported that increasing numbers of transfusions significantly increased sensitization (higher PRAs) and that elevated PRA (from any cause) was qualitatively associated with worse graft survival although statistical results for this latter analysis were not provided.9 In another book chapter, UCLA Registry data from 1981 to 1990 found qualitatively better 1-year graft survival annually from 1981 through 1987, similar 1-year graft survival from 1988 to 1989, and worse survival in 1990 in those with 1 or more transfusions versus no transfusions although the authors suggested that the 1990 data could be a spurious result produced by late reporting of followup.10,178 UNOS Registry data from 1987 to 1990 found similar 1-year graft survival in those with 1 or more transfusions versus no transfusions. Another book chapter using UNOS data reiterated similar risks of higher numbers of transfusions increasing risk of developing higher PRAs and higher PRAs (from any source) increasing risk of graft failure11 while another book chapter reiterated that patients with PRAs >50% (from any cause) have longer waiting times for transplantation.12

In the USRDS Annual Data Report in 2010, patients with higher PRAs have longer waiting times. 13 Receiving a transfusion while on the transplant waiting list is associated with a 5-fold higher risk of dying while on the wait list within the first five years and an 11% reduction in the likelihood of receiving a transplant within the first 5 years. Why such a disparity exists between the relatively small reduction in transplantation and the large increase in the likelihood of death of the waiting list is unclear. The data was adjusted for age, gender, race, ethnicity, cause of end stage renal disease, blood type, body mass index, pretransplant time on dialysis, education, dialysis type, and comorbid conditions. It could be that while the risk of having no transplant within 5 years is low, the prolongation of waiting time leads to poorer outcomes, there is ultimately a poorer match, or transfusion may be a marker of some other underlying disorder that hastens death unrelated to the transfused product itself. Ultimately, these data that were not included in our results section supports our general findings about the implications of receiving transfusions in those who actually receive transplants and underscores the potential for adverse outcomes in those who are not ultimately transplanted due to sensitization.

While the data provided by USRDS on overall transplant outcomes is extensive, the USRDS report was not focused on the direct impact of transfusions on transplant outcomes. The USRDS data collection system is limited to self-reporting of transfusion status in transplant candidates and recipients, in which it is limited to discrete data (i.e. yes, no, or unknown) on whether patients have received transfusions while the indications and/or appropriateness of the transfusions are often unknown. As such, the direct correlation of sensitization and transfusion cannot be established.

## Future Research Directions

We believe that additional adequately powered studies should be conducted. In these studies we believe that they should be multi-institutional because individual center practices and procedures are so variable, have adequate reporting of demographics and either use statistical means to account for confounders (propensity score adjustment or matching) or use of randomization, have standard definitions of outcomes, and have a standard followup time of at least 1-year. Patients receiving or being randomized to no transfusions should be screened to assure that this not only includes transfusions within the dialysis or transplant center but other transfusions as well. We believe that standard PRA testing should be supplanted with updated CPRA testing so that specific HLA antigen sensitivities resulting from transfusions can be identified and perhaps correlated with outcomes. Outcomes such as sensitization rate, access to transplantation, and waiting time to transplantation during the pretransplant time period as well as graft outcomes during post-transplant period should be evaluated.

The impact of different immunosuppressive regimens (induction and maintenance as well as novel therapies such as statins) on outcomes in patients receiving transfusions to identify those regimens which can suppress the advantageous or detrimental effects of transfusion on outcomes is needed. This should be specifically evaluated to determine whether transfusions need to be encouraged, avoided, or matched with certain regimens. Such evaluations should adhere to good study conduction practices.

Data from large scale registries could be used for future research but should be published in peer reviewed journals, have an adequate use and description of methods, have a reliable and objective data collection system, as well as account for a myriad of confounders.