# Conclusion

The conclusions to the key questions of this technology assessment and the grading of the strength of the body of evidence are summarized in Table 48.

Unlike prior renal transplants which seem to worsen renal allograft outcomes, transfusions generally have beneficial to neutral effects on renal allograft outcomes, and have minimal detrimental effects on the outcomes for renal transplant recipients. There is not much support for the notion that transfusions increase the risk of graft rejection among those receiving transplantation. Although there is evidence that patients receiving pretransplant transfusions have increased levels of sensitization as assessed by PRA, the relationship between the number of pretransplant transfusions and the extent of levels of sensitization is still not established. It should be noted that in some studies, patients who were candidates for transplantation were ultimately not offered the transplant due to high PRA levels. Some other studies did not disclose the number of patients who were ultimately not transplanted due to a high PRA as they focused on the population undergoing transplant. This is a major confounder in these studies.

When we examine results based on advancing time periods (before 1942, 1984–1991, and 1992 to the present), the percentage of analyses showing benefit is attenuated in more recently conducted studies. With regard to rejection, the data are more ambiguous with some analyses showing benefit, some showing a neutral effect, and other analyses showing harm, although the number of studies evaluating more recent time periods is quite limited.

In essence, the literature base is weak and future research conducted with proper control for confounders, disclosure of baseline characteristics, and use of other good study design techniques is needed to assess the impact of transfusions on allograft and patient survival outcomes in renal transplant recipients.

Table 48 Overview of Study Outcomes

Outcome | Total Number of Analyses | Conclusion | Strength of Evidence
KEY QUESTION 1a ENDPOINTS
REJECTION: Significant Findings Direction of Effect | 25 47 | Transfusion has a: Beneficial to no significant effect on rejection Beneficial to no effect on rejection | Low Insufficient
1-YR GRAFT SURVIVAL: Significant Findings Magnitude of Effect | 55 132 | Transfusion has a: Beneficial to no significant effect on graft survival Large beneficial impact or small impact on graft survival | Low Low
MAX DURATION GRAFT SURVIVAL: Significant Findings Magnitude of Effect | 65 146 | Transfusion has a: Beneficial to no significant effect on graft survival Large beneficial impact or small impact on graft survival | Low Low
1-YR PATIENT SURVIVAL: Significant Findings Magnitude of Effect | 16 35 | Transfusion has a: Beneficial to no significant effect on patient survival Large beneficial impact or small impact on patient survival | Low Low
MAX DURATION PATIENT SURVIVAL: Significant Findings Magnitude of Effect | 18 41 | Transfusion has a: Beneficial to no significant effect on patient survival Large beneficial impact or small impact on patient survival | Low Low
MULTIVARIATE ANALYSES: Prior Transplant Transfusion Pregnancy | 22 13 5 | The covariate has: Detrimental to no significant effect on rejection, graft survival, and patient survival Beneficial to no significant effect on rejection and graft survival Beneficial effect on rejection but detrimental to no significant effect on graft survival | Low Low Insufficient (rejection), Low (Graft Survival)
KEY QUESTION 1b i ENDPOINTS
REJECTION: Significant Findings Direction of Effect | 3 7 | DST Transfusion has a: Beneficial to no significant effect on rejection Beneficial to no effect on rejection | Low Insufficient
1-YR GRAFT SURVIVAL: Significant Findings Magnitude of Effect | 4 16 | Transfusion has a: Beneficial to no significant effect on graft survival Large beneficial impact or small impact on graft survival | Low Low
MAX DURATION GRAFT SURVIVAL: Significant Findings Magnitude of Effect | 5 17 | Transfusion has a: Beneficial to no significant effect on graft survival Large beneficial impact or small impact on graft survival | Low Low
1-YR PATIENT SURVIVAL: Significant Findings Magnitude of Effect | 2 4 | Transfusion has a: Non-significant effect on patient survival Small impact on patient survival | Insufficient Low
MAX DURATION PATIENT SURVIVAL: Significant Findings Magnitude of Effect | 2 4 | Transfusion has a: Non-significant effect on patient survival Small impact on patient survival | Insufficient Low
MULTIVARIATE ANALYSES: DST vs Non-DST | 5 | The covariate has: Beneficial to no significant effect on rejection or graft survival | Low
KEY QUESTION 1b ii ENDPOINTS
REJECTION: NUMBER OF TRANSFUSIONS: Significant Findings Direction of Effect NUMBER OF UNITS TRANSFUSED: Significant Findings Direction of Effect | 5 18 1 1 | Versus a lower number of transfusions, a higher number of transfusions is: Beneficial to no significant effect on rejection Beneficial to no effect on rejection Versus no units of blood transfused, increasing number of units: Non-significant effect on rejection No effect on rejection | Low Insufficient Insufficient Insufficient
1-YR GRAFT SURVIVAL: NUMBER OF TRANSFUSIONS VERSUS NO TRANSFUSION: Significant Findings Magnitude of Effect HIGHER VERSUS LOWER NUMBER OF TRANSFUSIONS: Significant Findings Magnitude of Effect NUMBER OF UNITS TRANSFUSED VERSUS NO TRANSFUSION: Significant Findings Magnitude of Effect HIGHER VERSUS LOWER NUMBER OF UNITS TRANSFUSED: Significant Findings Magnitude of Effect | 12 51 11 43 11 21 6 12 | 1–5, 5–10, or >10 transfusions versus no transfusions has a: Beneficial to no significant effect on graft survival Large beneficial impact or small impact on graft survival ≥5 vs. 1–5, ≥10 vs. 1–5, ≥10 vs. ≥5 transfusions has a: Beneficial to no significant effect on graft survival Large beneficial impact or small impact on graft survival 1–5, 5–10, or >10 transfusions versus no transfusions has a: Beneficial to no significant effect on graft survival Large beneficial impact or small impact on graft survival ≥5 vs. 1–5, ≥10 vs. 1–5, ≥10 vs. ≥5 transfusions has a: Beneficial to no significant effect on graft survival Large beneficial impact or small impact on graft survival | Low Low Low Low Low Low Low Low
MAX DURATION GRAFT SURVIVAL: NUMBER OF TRANSFUSIONS VERSUS NO TRANSFUSION: Significant Findings Magnitude of Effect HIGHER VERSUS LOWER NUMBER OF TRANSFUSIONS: Significant Findings Magnitude of Effect NUMBER OF UNITS TRANSFUSED VERSUS NO TRANSFUSION: Significant Findings Magnitude of Effect HIGHER VERSUS LOWER NUMBER OF UNITS TRANSFUSED: Significant Findings Magnitude of Effect | 9 53 10 47 16 22 12 16 | 1–5, 5–10, or >10 transfusions versus no transfusions has a: Beneficial to no significant effect on graft survival Large beneficial impact or small impact on graft survival ≥5 vs. 1–5, ≥10 vs. 1–5, ≥10 vs. ≥5 transfusions has a: Beneficial to no significant effect on graft survival Large beneficial impact or small impact on graft survival 1–5, 5–10, or >10 transfusions versus no transfusions has a: Beneficial to no significant effect on graft survival Large beneficial impact or small impact on graft survival ≥5 vs. 1–5, ≥10 vs. 1–5, ≥10 vs. ≥5 transfusions has a: Beneficial to no significant effect on graft survival Large beneficial impact or small impact on graft survival | Low Low Low Low Low Low Low Low
1-YR PATIENT SURVIVAL: NUMBER OF TRANSFUSIONS VERSUS NO TRANSFUSION: Significant Findings Magnitude of Effect HIGHER VERSUS LOWER NUMBER OF TRANSFUSIONS: Significant Findings Magnitude of Effect | 8 8 7 7 | 1–5, 5–10, or >10 transfusions versus no transfusions has a: Non-significant effect on patient survival Large beneficial impact or small impact on patient survival ≥5 vs. 1–5, ≥10 vs. 1–5, ≥10 vs. ≥5 transfusions has a: No significant effect on patient survival Small impact on patient survival | Low Low Low Low
MAX DURATION PATIENT SURVIVAL: NUMBER OF TRANSFUSIONS VERSUS NO TRANSFUSION: Significant Findings Magnitude of Effect HIGHER VERSUS LOWER NUMBER OF TRANSFUSIONS: Significant Findings Magnitude of Effect | 8 7 7 5 | 1–5, 5–10, or >10 transfusions versus no transfusions has a: Non-significant effect on patient survival Large beneficial impact or small impact on patient survival ≥5 vs. 1–5, ≥10 vs. 1–5, ≥10 vs. ≥5 transfusions has a: No significant effect on patient survival Small impact on patient survival | Low Low Low Low
MULTIVARIATE ANALYSES: Transfusion of Varying Numbers vs. No Transfusion >5 transfusions vs. 1–5 transfusions | 16 4 | Transfusion has a: Detrimental to no significant effect on rejection or graft survival Versus 1–5 transfusions, >5 transfusions has a: Detrimental to neutral effect on rejection and graft survival | Low Low
KEY QUESTION 1b iii ENDPOINTS
1-YR GRAFT SURVIVAL: LEUKOCYTE DEPLETED VS. NO TRANSFUSION Magnitude of Effect LEUKOCYTE DEPLETED VS. TRANSFUSION: Significant Findings Magnitude of Effect | 2 1 2 | Versus no transfusion, leukocyte depleted transfusion has a: Large beneficial impact on graft survival Versus transfusion, leukocyte depleted transfusion has a: Non-significant effect on graft survival Small change in graft survival | Low Insufficient Low
MAX DURATION GRAFT SURVIVAL: LEUKOCYTE DEPLETED VS. NO TRANSFUSION Magnitude of Effect LEUKOCYTE DEPLETED VS. TRANSFUSION: Significant Findings Magnitude of Effect | 2 1 2 | Versus no transfusion, leukocyte depleted transfusion has a: Large beneficial impact on graft survival Versus transfusion, leukocyte depleted transfusion has a: Non-significant effect on graft survival Large beneficial effect or small change in graft survival | Low Insufficient Low
MAX DURATION PATIENT SURVIVAL: LEUKOCYTE DEPLETED VS. NO TRANSFUSION Magnitude of Effect LEUKOCYTE DEPLETED VS. TRANSFUSION: Significant Findings Magnitude of Effect | 1 1 1 | No effect on rejection No significant effect on rejection No effect on rejection | Insufficient Insufficient Insufficient
KEY QUESTION 1b iv–v ENDPOINTS
REJECTION: Significant Findings Direction of Effect | 11 35 | Over progressive time periods transfusion has a: Up to the year 1992, transfusion had a significant beneficial to neutral effect but after 1992, it may not have this effect Up to the year 1992, transfusion had a beneficial to neutral effect but after 1992, it may not have this effect | Low Low
1-YR GRAFT SURVIVAL: Significant Findings Magnitude of Effect | 47 108 | Over progressive time periods transfusion has a: Transfusion had a significant beneficial to neutral effect Transfusion has a large beneficial impact or small impact on graft survival | Low Low
MAX DURATION GRAFT SURVIVAL: Significant Findings Magnitude of Effect | 57 119 | Over progressive time periods transfusion has a: Transfusion had a significant beneficial to neutral effect Transfusion has a large beneficial impact or small impact on graft survival | Low Low
1-YR PATIENT SURVIVAL: Significant Findings Magnitude of Effect | 17 30 | Over progressive time periods transfusion has a: Transfusion had a significant beneficial to neutral effect Transfusion has a large beneficial impact or small impact on patient survival | Low Low
MAX DURATION PATIENT SURVIVAL: Significant Findings Magnitude of Effect | 18 37 | Over progressive time periods transfusion has a: Transfusion had a significant beneficial to neutral effect Transfusion has a large beneficial impact or small impact on patient survival | Low Low
KEY QUESTION 2b ENDPOINTS
REJECTION: Significant Findings Direction of Effect | 2 2 | Lower PRA% is associated with a: Non-significant effect on rejection Directionally less rejection | Low Insufficient
1-YR GRAFT SURVIVAL: Significant Findings Direction of Effect | 8 11 | Lower PRA% is associated with a: Significant beneficial to neutral effect Large beneficial impact or small impact on graft survival | Low Low
MAX DURATION GRAFT SURVIVAL: Significant Findings Direction of Effect | 14 18 | Lower PRA% is associated with a: Significant beneficial to neutral effect on graft survival Large beneficial impact or small impact on graft survival | Low Low
MAX DURATION PATIENT SURVIVAL: Significant Findings | 2 | Lower PRA% is associated with a: Non-significant effect on patient survival | Low
MULTIVARIATE ANALYSES: Rejection Graft Survival Patient Survival | 2 7 3 | Lower PRA is: Not an independent predictor of lower rejection Significant beneficial to neutral effect of graft survival Significant beneficial to neutral effect on patient survival | Low Low Low

PRA = Panel Reactive Antibodies, YR = Year