# Background

## End Stage Renal Disease and Kidney Transplantation

Over 450,000 patients in the United States have end stage renal disease (ESRD).1 While there are important morbidity and survival advantages to receiving renal transplantation versus dialysis modalities, only 14,059 kidney transplants were performed in 2009.^2^ The Coverage and Analysis Group at the Centers for Medicare and Medicaid Services (CMS) requested a report from The Technology Assessment Program (TAP) at the Agency for Healthcare Research and Quality (AHRQ) that assessed the impact of renal transplantation on renal allograft endpoints. AHRQ assigned this report to the University of Connecticut/Hartford Hospital Evidence-based Practice Center (Contract Number: 290 2007 10067 I). The technology assessment focused on two key questions with several subparts.

Most patients with ESRD who require dialysis for four or more months qualify for Center for Medicare & Medicaid Services (CMS) coverage until dialysis ceases. Renal transplantation and subsequent care in patients with ESRD is also covered for three years after transplantation. The likelihood of transplantation within three years of ESRD registration is 17.8 percent but varies from 9.2 percent in those 60 to 69 years of age to 69.9 percent in those 0 to 19 years of age. (2003 United States Renal Data System) The incidence and prevalence of ESRD in patients covered by CMS by age category in 2006 is provided in Table 1. The use of hemodialysis, transplant, transplantation wait list, or peritoneal dialysis in patients covered by CMS in 2006 is provided in Table 2.

Table 1 Incidence and prevalence of ESRD in patients covered by CMS by age category in 2006

Age | Incidence # | Incidence % | Prevalence # | Prevalence % | Treatment Composition
0–19 | 1,303 | 1.2 | 7,465 | 1.5 | Mostly transplant
20–44 | 13,977 | 12.6 | 96,677 | 19.1 | Almost equal
45–64 | 41,729 | 37.6 | 223,374 | 44.1 | 2:1 dialysis: transplant
65–74 | 25,500 | 23.0 | 99,431 | 19.6 | Primarily dialysis
75+ | 28,342 | 25.6 | 79,308 | 15.7 | Primarily dialysis
Unknown | ------- | ------- | ------- | ------- | -------

Table 2 Therapeutic modalities for patients with ESRD covered by CMS in 2006

| New Patients 2006 | Total Patients 2006
Hemodialysis | 101,306 | 327,754
Transplant | 2,635 | 151,502
Transplant Wait List | --------- | 68,576
Peritoneal Dialysis | 6,725 | 26,082

## Autorecognition

Human leukocyte antigens (HLA) are a set of human major histocompatibility complex derived glycoproteins that are expressed on cell surfaces and allow for discrimination of self from non-self.1 HLA have been classified into two major groups, Class I (HLA-A, HLA-B, and HLA-C) and Class II (HLA-DP, HLA-DQ, and HLA-DR).Class I HLA molecules are expressed on the surface of all nucleated cells and are recognized by cytotoxic T cells (CD8+). Cytotoxic T cells promote target cell destruction through apoptosis and release of cytotoxic proteins. Class II HLA molecules are expressed solely on the surfaces of antigen- presenting cells (APCs). APCs include dendritic cells, macrophages, and activated B lymphocytes. APCs are vital in initiating the immune response and stimulating helper T cells (CD4+). Some T helper cells secrete cytokines that recruit cytotoxic T cells, B lymphocytes, or APCs while others secrete cytokines which attenuate the immune response. When a B lymphocyte binds to an antigen and receives a cytokine signal from a helper T cell, it can differentiate into a plasma B cell or a memory B cell. Plasma B cells secrete antibodies which can destroy target antigens while memory B cells cause long term immunity and rapidly activate the immune system upon subsequent exposure to the target antigen.1

## Allorecognition

Recognition of the antigens displayed by the transplanted organ (alloantigen) is the prime event initiating the immune response against an allograft.1 In the direct pathway, donor APCs migrate to the recipient’s lymph nodes and present donor HLA glycoproteins to T cells. In the indirect pathway, recipient APCs migrate into the allograft and phagocytize alloantigens. The HLA glycoproteins are then presented to recipient T cells in the lymph nodes. Regardless of whether the alloantigen is presented via the direct or indirect pathway (referred to as Signal 1), a second costimulatory signal (referred to as Signal 2) must also take place for T cell activation. This is an interaction between one of several costimulatory receptors and paired ligands on the surfaces of APCs and T cells.1

## Allograft Rejection

### Hyperacute Rejection

Hyperacute rejection is an immediate recipient immune response against an allograft due to preformed recipient antibodies directed against the Donor’s HLA.1 Those at highest risk have HLA or ABO blood group antibodies including patients with a history of previous organ transplantation, multiple blood transfusions, and mothers receiving organs from their children.1

### Acute Rejection

Acute rejection is a cell mediated process that generally occurs within 5 to 90 days after a transplant, although it can occur after this time.1 Unlike the B lymphocyte mediated hyperacute rejection, this reaction is mediated through alloreactive T cells. Activated cytotoxic T cells infiltrate the graft and trigger an immune response. They can induce graft injury by inducing apoptosis and by secreting cytotoxic proteins (perforin and ganzyme B). Pretransplant assessment for the presence or absence of alloantibodies and T cell activities to HLA antigens is touted to reduce the risk of acute rejection. Clinical symptoms associated with acute rejection of a renal allograft include fever, allograft tenderness, decreased urine output, malaise, hypertension, weight gain, and edema. Clinical signs include increases in serum creatinine, blood urea nitrogen, leukocyte concentrations, allograft swelling, and a positive renal biopsy for lymphocyte infiltration.1

### Humoral Rejection

Outside of the hyperacute rejection state, humoral rejection can still occur although less frequently than cell mediated acute rejection.3 Humoral rejection is characterized by B lymphocytes injuring the allograft through immunoglobulin and complement activities.1

### Chronic Rejection

The definition of chronic rejection is ambiguous, and is sometimes recognized as chronic allograft nephropathy or any immunological responses that results in slow loss of graft function with histopathological processes: tubular atrophy, interstitial fibrosis, and fibrous intimal thickening of arteries.4

## Immunosuppression Therapy in Renal Allografts

There have been major advances in immunosuppressive therapy.1Immunosuppressive therapy is broken into three categories: induction therapy, maintenance therapy, and treatment of acute rejection episodes.1

### Induction Therapy

Induction therapy is usually initiated intraoperatively or immediately after the transplant and continues for 7 to 10 days.1 Induction agents include basiliximab, daclizumab, antithymocyte globulin equine, antithymocyte globulin rabbit, and muromonab-CD3, and alemtuzumab. Induction therapy is not a uniformly used but is often considered for those with preformed antibodies, history of previous organ transplantation, multiple HLA mismatches, or transplantation of organs with prolonged cold ischemic time, or from expanded criteria donors. These therapies are not without the potential for harms resulting from opportunistic infections and malignancy.1

### Maintenance Therapy

Maintenance therapy is routinely provided to patients and available classes include: calcineurin inhibitors (cyclosporine and tacrolimus), antiproliferatives (azathioprine and mycophenylate acid derivatives), target of Rapamycin inhibitors (sirolimus) and corticosteroids (prednisolone and dexamethasone).1 Maintenance therapy is generally achieved by selecting two or more medications from different classes to maximize efficacy while minimizing adverse effects.1

## Evolution of Transfusion in Renal Transplantation

High-volume therapeutic use of blood transfusion was originally used in attempts to maintain ESRD patients who were anemic with red cell mass ranges of 20–25 percent. Due to concerns with transfusion-induced infections such as hepatitis and the production of anti-HLA antibodies resulting from the exposure to blood products, efforts were made in the 1970s to avoid the use of blood transfusions in renal transplant recipients.3 During the pre-cyclosporine era, studies suggested that non-transfused renal graft recipients were at higher risk for graft rejection as compared to those transfused recipients.5,6 Subsequently, many studies attempted to define the optimal dose and timing for the transfusion effect. With the introduction of cyclosporine in the early 1980s, leading to improved renal graft and patient survival, the beneficial role of blood transfusions and HLA matching was again being questioned. Meanwhile, some preliminary trials had shown the use of per-protocol transfusion: matched pretransplant blood transfusion (mPTFs) or donor-specific transfusion (DST) to be beneficial. The evidence supporting the effects (positive, negative, neutral) of pretransplant blood transfusion, regardless of therapeutic or protocol transfusion, in renal transplantation is still not well-established. It is unclear whether the benefits, if any, of pretransplant blood transfusion may be due to the modulation of immune response in which tolerance is induced.

## Key Questions

The following key questions were formulated to evaluate current literature on the impact of pre-transplant red blood cell transfusion in renal allograft outcomes:

### Key Question 1

1a) Do red blood cell transfusions prior to renal transplant impact allograft rejection/survival and what is the magnitude of that effect relative to other factors (e.g., pregnancy, prior transplantation?)
1b) Is any such impact of red blood cell transfusions on renal transplant outcomes altered by variables such as:
  i. planned DST vs. therapeutic transfusions
  ii. the number of transfusions, the number of units of blood, and/or the number of donors
  iii. the use of leukocyte depleted blood
  iv. changes in immune-suppression regimens (pre-cyclosporine, cyclosporine, later multi-drug regimens)
  v. other changes in management over time

### Key Question 2

2a) How have panel reactive antibody (PRA) assays changed over time? Do all PRA assays measure the same things? What things contribute to intra-assay variability (e.g., time, when during the dialysis cycle the sample was obtained, statin use)? How correlative or independent of one another are these measures?
2b) How useful are PRA assays in predicting sensitization from blood transfusions, donor specific antigen (DSA) sensitization, and renal transplant rejection/survival—especially in the setting of Q2a?