# Sensitization Tables

Other results depicting the impact of sensitization on eligibility for transplantation in transfused patients

Study, Year (N=) | Type of transfusion | Number of transfused patients (N_T_=) | Assessment | Number of transfused patients who were sensitized Ns/N_T_ (%) | Number of sensitized patients who were transplanted with planned kidney n/Ns (%) | Number of sensitized patients who were not transplanted with planned kidney n/Ns (%) | Comments
Eisenberger U, 2009 (N=138) | DST | 69 | PRA >0% | 4/69 (5.8) | 4/4 (100) | 0/4 (0) | All patients included in the were transplanted study
Tang H, 2008 (N=2,882) | NR | NR | Peak PRA level | NR | NR | NR | NA
Waanders MM, 2008 (N=118) | HLA-DR matched transfusion | 49 | PRA: highest recent and most | NR | NR | NR | NA
El-Husseini AA, 2005 (N=282) | RT | 166 | Lymphocytotoxic crossmatch | NR | NR | NR | Patients with positive lymphocytotoxic crossmatches were considered as sensitized, and thus excluded from the study
Opelz G, 2005 (N= 164,534) | RT | NR | Preformed antibodies defined as PRA 1–50% or > 50% | NR | NR | NR | NA
Higgins RM, 2004 (N=265) | RT | NR | NR | NR | NR | NR | NA
Park YH, 2004 (N=77) | RT | 14 | NR | NR | NR | NR | NA
Bunnapradist S, 2003 (N=7,079) | RT | NR | PRA 0–10 PRA 11–30 PRA > 30% | NR | NR | NR | NA
Herget-Rosenthal S, 2003 (N=40) | RT | NR | NR | NR | NR | NR | NA
Lietz K, 2003 (N=502) | RT | NR | PRA - maximum, minimum, and reactivity at the time of transplantation | NR | NR | NR | NA
Agarwal SK, 2002 (N=144) | RT | NR | NR | NR | NR | NR | NA
Barbari A, 2001 (N=84) | DST | 64 | Crossmatch | NR | NR | NR | NA
Hiesse C, 2001 (N=144) | HLA-DR matched or mismatched transfusion | 97 | Lymphocytotoxic anti-HLA antibodies (IgG anti-T cells) | 1/70 (1.0)^*^ | 1/1 (100) | 0/1 (0) | Cytotoxicity not reported in 27 patients, who were not transplanted at the end of study period
Poli L, 2001 (N=514) | RT | 223 | Crossmatch and PRA | NR | NR | NR | PRA and Crossmatch were both negative at the time of transplant
Montagnino G, 2000 (N=143) | RT | NR | PRA >50% | NR | NR | NR | NA
Alexander JW, 1999 (N=212) | DST | 115 | Peak PRA; positive T-cell crossmatch | NR | NR | NR | NA
de Mattos AM, 1999 (N=108) | RT | 84 | Peak PRA> 2%; crossmatch | NR | NR | NR | NA
Padányi A, 1998 (N=57) | DST | 13 | Anti-HLA cytotoxic antibody | NR | NR | NR | NA
Chavers BM, 1997 (N=4015) | RT | 2844 | NR | NR | NR | NR | NA
Galvao M, 1997 (N=60) | DST | 37 | PRA and crossmatch | NR | NR | NR | NA
Opelz G, 1997 (N=654) | RT | 321 | Lymphocytotoxic antibodies: >11% of test panel | 13/205 (6.3)^*^ | 13/13 (100) | 0/13 (0) | 162 patients still waiting at the end of study period, 10 (6%) of them (transfusion status unknown) had PRA >10%
Sharma RK, 1997 (N=30) | DST | 15 | Lymphocytotoxic crossmatch against T, B, and T+B cells before transplant, before DST, 7 days & 4 weeks post-transplant | 1/15 (6.7) | 1/1 (100) | 0/1 (0) | All patients included in the study were transplanted
Inoue S, 1996 (N=115) | DST | 43 | Crossmatches with the direct donor’s B and T lymphocytes | NR | NR | NR | Patients were transplanted if crossmatch remained negative throughout the DST sessions.
Jin DC, 1996 (N=680) | DST | 152 | Cytotoxicity test | NR | NR | NR | NA
Peters TG, 1995 (N=17,937) | RT | NR | PRA >60% | NR | NR | NR | NA
Poli F, 1995 (N=416) | RT | 204 | PRA >0% | NR | NR | NR | NA
Barber WH, 1994 (N=598) | DST | 288 | NR | NR | NR | NR | NA
Kahn D, 1994 (N=52) | DST | 33 | Crossmatch | NR | NR | NR | NA
Sautner T, 1994 (N=146) | RT | NR | PRA 0 PRA 1–40 PRA > 40 | NR | NR | NR | NA
Egidi MF, 1993 (N=284) | RT | 236 | NR | NR | NR | NR | NA
Basri N, 1992 (N=53) | DST | 28 | Crossmatch | NR | NR | NR | NA
Vathsala A, 1992 (N=116) | RT | NR | PRA > 60%; crossmatch | NR | NR | NR | NA
Velidedeoglu E, 1992 (N=437) | DST | 344 | Formation of antibodies against donor lymphocytes; crossmatch | NR | NR | NR | Patients were not transplanted with a positive crossmatch
Xiao X, 1992 (N=201) | RT | 152 | Lymphocytotoxic crossmatch | NR | NR | NR | NA
Garcia LF, 1991 (N=NR) | DST DST+RT RT | 28 51 RT | Crossmatch | 4/28 (14.3) 23/51 (45.1) NR | NR | NR | NA
Kerman RH, 1991 (N=365) | RT | 242 | Crossmatch; PRA against panel of 60 | 0/242 (0) | NA | NA | Retrospective study included all transplant recipients who had negative crossmatch
Sanfilippo F, 1990 (N=2138) | DST RT | 430 315 | PRA ≥ 60% | NR | NR | NR | NA
Kasai I, 1989 (N=26) | DST^†^ | 19 | Crossmatch | NR | NR | NR | NA
Pfaff WW, 1989 a^‡^ | PT | 373 | PRA 11–99% | 33/373 (8.8) | NR | NR | NA
Pfaff WW, 1989 b^‡^ (N=797) | PT | 150 | PRA 11–99% | 53/150 (35.3) | NR | NR | NA
Yamauchi J, 1989 (N=28) | DST | 19 | Crossmatch | 6/19 (31.6) | 6/6 (100) | 0/6 (0) | NA
Albrechtsen D, 1988 (N=701) | RT | 476 | Crossmatch | NR | NR | NR | NA
Brynger H, 1988 (N=459) | RT | 289 | Positive PRA | NR | NR | NR | NA
Bucin D, 1988 (N=116) | RT | 79 | Presence of antibodies | 30/79 (38.0) | 30/30 (100) | 0/30 (0) | NA
Kerman RH, 1988 (N=320) | RT | 220 | Highest PRA | NR | NR | NR | NA
Madrenas J, 1988 (N=287) | RT | 233 | PRA >50% | NR | NR | NR | NA
Takiff H, 1988 (N=NR) | RT | NR | Current, peak PRA | NR | NR | NR | NA
Alarif L, 1987 (N=126) | RT | 126 | PRA ≥ 10 % | 16/126 (12.7) | 16/16 (100) | 0/16 (0) | NA
Garcia VD, 1987 (N=104) | DST | 35 | T-warm or B-warm donor specific crossmatches | NR (29.8) | NR | NR | NA
Ho-Hsieh H, 1987 (N=51) | RT | 33 | NR | NR | NR | NR | NA
Melzer JS, 1987 (N=212) | RT | 163 | Peak PRA >50% | 12/163 (7.4) | 12/12 (100) | 0/12 (0) | NA
Salvatierra O, 1987 b^§^ | DST | 302 | A positive T warm crossmatch or a positive B warm crossmatch with a concomitant positive fluorescence-activated cell sorter crossmatch | NR | NR | NR | NR
CMTSG, 1986 (N=291) | RT | 44 | Current cytotoxic antibody > 10% Highest cytotoxic antibody > 50% | NR | NR | NR | NA
Norman DJ, 1986 (N=43) | RT | 25 | Crossmatch | NR | NR | NR | NA
Sanfilippo F, 1986 (N=3,628) | RT | NR | Peak and current PRA levels | NR | NR | NR | NA
Sabbaga E, 1985 (N=40) | DST | 20 | Crossmatch | NR | NR | NR | NA
Sanfilippo F, 1985 (N=107) | LP PRC Mixed | 45 42 20 | PRA ≥ 20% | NR NR NR | NR NR NR | NR NR NR | NA NA NA
d’Apice AJ, 1984 (N=337) | RT | 281 | Presensitization: peak reactivity > 25% of panel | NR | NR | NR | NA
Flechner SM, 1984 (N=36) | RT | 21 | NR | NR | NR | NR | NA
Guillou PJ, 1984 (N=116) | RT | 64 | NR | NR | NR | NR | NA
Jeffery JR, 1984 (N=NR) | RT | 33 | Cytotoxic antibodies | NR | NR | NR | NA
Ting A, 1984 (N=298) | RT | 170 | NR | NR | NR | NR | NA
Velasco N, 1984 (N=96) | RT | NR | NR | NR | NR | NR | NA
Cheigh JS, 1983 (N=62) | RT | 47 | Percent lymphocytotoxicity | NR | NR | NR | NA
Cho SI, 1983 (N=178) | RT | 159 | PRA ≥ 10% | 57/159 (35.8) | 57/57 (100) | 0/57 (0) | Immunization status was retrospectively evaluated in the included patients who had already received transplantation
Garvin PJ, 1983 (N=92) | RT | 71 | PRA > 10% | NR | NR | NR | NA
Kerman RH, 1983 (N=104) | RT | NR | Crossmatch | NR | NR | NR | NA
Madsen M, 1983 (N=158) | RT | 142 | Crossmatch | NR | NR | NR | NA
Muller GA, 1983 (N=80) | RT | NR | Crossmatch | NR | NR | NR | NA
Myburgh JA, 1983 (N=262) | RT | 193 | Crossmatch | NR | NR | NR | NA
Okiye SE, 1983 (N=165) | RT | 130 | Preformed antibodies >5% | NR | NR | NR | NA
Rao KV, 1983 (N=300) | RT | 251 | Cytotoxic antibodies >50% assessed at time of transplant | NR | NR | NR | NA
Richie RE, 1983 (N=389) | RT | 284 | NR | NR | NR | NR | NA
Spees EK, 1983 (N=3,042) | RT | 2473 | Percent reactive antibody: cytotoxicity against a panel | NR | NR | NR | NA
Zeichner WD, 1983 (N=77) | PT | 61 | Cytotoxic antibody levels >10%: screened against panel | 4/59 (6.8) | 4/4 (100) | 0/4 (0) | Immunization status was retrospectively evaluated in the included patients who had already received transplantation
Betuel H, 1982 (N=246) | PT RT | 165 81 | Anti-HLA antibodies | 67/165 (40.6) 27/81 (33.3) | 67/67 (100) 27/27 (100) | 0/67 (0) 0/27 (0) | Immunization status was retrospectively evaluated in the included patients who had already received transplantation
Chu D, 1982 (N=32) | RT | 22 | Pretransplant antibody level; crossmatch | NR | NR | NR | NA
Dewar PJ, 1982 (N=357) | LD: RT CD: RT | 77 188 | Lymphocytotoxic crossmatch | NR | NR | NR | NA
Fehrman I, 1982 (N=130) | RT | 85 | Crossmatch | NR | NR | NR | NA
Flechner SM, 1982 (N=100) | RT | 89 | Preformed antibody >10%: assessed against random panel of lymphocytes; crossmatch | NR | NR | NR | NA
Fradet Y, 1982 (N=121) | RT | 93 | Lymphocytotoxic antibodies, pre- and post-transplant | NR | NR | NR | NA
Frisk B, 1982 (N=347) | PT RT | 116 191 | Cytotoxic antibody | NR | NR | NR | NA
Fuller TC, 1982 (N=156) | RT | 135 | >10% panel alloantibody reactive | 42/135 (31.1) | 42/42 (100) | 0/42 (0) | All patients received transplant
Glass NR, 1982 (N=94) | RT | 45 | NR | NR | NR | NR | NA
Kovithavongs T, 1982 a^‖^ (N=48) | RT | 25 | Lymphocyte mediated cytotoxicity assessed | NR | NR | NR | NR
Kovithavongs T, 1982b^‖^ (N=48) | RT | 15 | Lymphocyte mediated cytotoxicity assessed | 4/7 (57.1) | 4/4 (100) | 0/4 (0) | Immunization status was retrospectively evaluated in the included patients who had already received transplantation
Mendez R, 1982 (N=67) | RT | 54 | Preformed lymphocytotoxins | 18/49 (36.7) | 18/18 (100) | 0/18 (0) | Preformed lymphocytotoxins was not assessed in 5 transfused and transplanted patients
Sirchia G, 1982 (N=65) | RT | 65 | Lymphocytotoxic antibodies; crossmatch | NR | NR | NR | NA
Walker JF, 1982 (N=204) | RT | 137 | NR | NR | NR | NR | NA
Feduska, 1981a^¶^ (N= 732) | RT | 517 | Percent of cytotoxic antibodies >10% | 32/517 (6.2) | 32/32 (100) | 0/32 (0) | All patients included in this subgroup received transplantation
Feduska, 1981b^¶^ (N= 977) | RT | 666 | Percent of cytotoxic antibodies >10% | 57/666 (8.6) | 35/57 (56.1) | 25/25 (100) | All patients in this subgroup were on hemodialysis, and transplantations were not offered
Hurst PE, 1981 (N=168) | RT | 109 | NR | NR | NR | NR | NA
Persijn GG, 1981 (N=52) | LP/LDP | 52 | Lymphocytotoxic antibodies: against a panel of 50 antigens; crossmatch | NR | NR | NR | NA
Sirchia G, 1981 (N=484) | RT | 325 | Presence of lymphocytotoxic antibodies, positive B cell crossmatch | NR | NR | NR | NA
Thorsby E, 1981 (N=129) | RT | 73 | Crossmatch | NR | NR | NR | NA
Van Es A, 1981 (N=269) | RT | 244 | NR | NR | NR | NR | NA
Corry RJ, 1980 (N=94) | RT | 45 | NR | NR | NR | NR | NA
Fehrman I, 1980 (N=229) | RT | 159 | HLA antibodies | 28/159 (17.6) | 28/28 (100) | 0/28 (0) | Immunization status was retrospectively evaluated in the included patients who had already received transplantation
Jakobsen A, 1980 (N=301) | RT | 157 | NR | NR | NR | NR | NA
Spees EK, 1980 (N=995) | RT | 829 | Current and Peak PRA levels: data provided (0, >0) | 427/829 (51.5) [Peak >0] | 427/427 (100) | 0/427 (0) | Immunization status was retrospectively evaluated in the included patients who had already received transplantation
Andrus C, 1979 (N=55) | RT | NR | Antibody incidence | NR | NR | NR | NA
Fauchet R, 1979 (N=71) | RT | 45 | HLA presensitization | NR | NR | NR | NA
Hourmant M, 1979 (N=163) | RT | 121 | NR | NR | NR | NR | NA
Oei LS, 1979 (N=86)^#^ | RT | 69 | NR | NR | NR | NR | NA
Sengar D, 1979 (N=117) | RT | 78 | Lymphocytotoxic antibodies | 8/78 (10.3) | 8/8 (100) | 0/8 (0) | Immunization status was retrospectively evaluated in the included patients who had already received transplantation
Werner-Favre C, 1979a^**^ | RT | 167 | Highest level of anti-PBL antibodies | 58/167 (34.7) [anti-PBL antibodies ≥5%] | NR | NR | NR
Werner-Favre C, 1979b^**^ (N=101) | RT | 87 | Highest level of anti-PBL antibodies | 19/71 (26.8) [anti-PBL antibodies ≥5%] | 19/19 (100) | 0/19 (0) | Anti-PBL antibodies results not reported in 16 transfused and transplanted patients
Blamey RW, 1978 (N=32) | RT | 10 | NR | NR | NR | NR | NA
Briggs JD, 1978 a^††^ | RT | 68 | HLA antibodies | NR | NR | NR | NA
Briggs JD, 1978 b^††^ (N=159) | RT | 63 | HLA antibodies | 16/63 (25.4) | NR | NR | NA
Jeffrey JR, 1978 (N=44) | RT | 20 | NR | NR | NR | NR | NA
Jeffery JR, 1978 (N=48) | RT | 24 | Maximum cytotoxic antibody levels | 12/24 (50.0), [max level≥5%] | 12/12 (100) | 0/12 (0) | Immunization status was retrospectively evaluated in the included patients who had already received transplantation
Stiller CR, 1978 (N=32) | RT | 14 | NR | NR | NR | NR | NA
Brynger H, 1977 a^‡‡^ | RT | 144 | HLA-antibodies | NR | NR | NR | Immunization status was retrospectively evaluated in the
Brynger H, 1977 b^‡‡^ (N=244) | RT | 42 | HLA-antibodies | 3/42 (7.1) | 3/3 (100) | 0/3 (0) | included patients who had already received transplantation
Fuller TC, 1977 (N=90) | RT | 80 | >20% cytotoxicity with 2 or more cells in panel | 16/80 (20.0) | 16/16 (100) | 0/16 (0) | Immunization status was retrospectively evaluated in the included patients who had already received transplantation
Husberg BO, 1977 (N=95) | RT | 65 | Lymphocytotoxic antibodies | 17/65 (21.5) | 17/17 (100) | 0/17 (0) | Immunization status was retrospectively evaluated in the included patients who had already received transplantation
Joysey VC, 1977 (N=272) | RT | 162 | Cytotoxic antibodies | NR | NR | NR | NA
Perkins HA, 1977 (N=126) | RT | 99 | NR | NR | NR | NR | NA
Persijn GG, 1977 (N=622) | RT | 589 | Cytotoxic antibodies | NR | NR | NR | NA
Polesky HF, 1977 (N=281) | Mixed | 248 | NR | NR | NR | NR | NA
Sachs JA, 1977 (N=524) | RT | 358 | Cytotoxic antibodies | NR | NR | NR | NA
Säfwenberg J, 1977 (N=117) | Mixed | 65 | HLA antibodies | 21/63 (33.3) | 21/21 (100) | 0/21 (0) | Immunization status was retrospectively evaluated in the included patients who had already received transplantation
Walter S, 1977 (N=88) | RT | 65 | NR | NR | NR | NR | NA
Opelz G, 1974 (N=290) | RT | 228 | NR | NR | NR | NR | NA
Opelz G, 1973 (N=148) | RT | 123 | Cytotoxic antibodies | NR | NR | NR | NA
Opelz, 1972 (N= 829) | NR | NR | Cytotoxins | NR | NR | NR | NA

* Results were not reported for the entire transfused population, only for the population who were transfused and transplanted

† Analysis was evaluated using the subgroup population (i.e. Cyclosporine groups)

‡ Pfaff 1989a included nonparous subgroup, and Pfaff 1989b included parous subgroup

§ Salvatierra 1987b included the entire transfused population

‖ Kovithavongs 1982a included patients who received HLA haploidentical transplant, and Kovithavongs 1982b included patients with HLA identical transplant

¶ Feduska 1981a included patients who received deceased donor graft, and Feduska 1981b included patients who were still waiting for transplantation

# Only results of living donor transplant recipients was included in the analysis, overlapping information with Corry RJ et al, 1980 for the cadaver transplant recipients, and thus not included in this analysis

** Werner-Favre 1979a included the entire study population, and Wener-Favre 1979b included subgroup patients who were screened for anti-PBL antibodies, and were transfused and transplanted.

†† Briggs 1978a included cadaver transplant recipients, and Briggs 1978b included patients receiving hemodialysis.

‡‡ Brynger 1977a included cadaveric renal transplant recipients, and Brynger 1977b included living donor transplant recipients.

Anti-PBL=antiperipheral blood lymphocytes, CD=cadaveric donor transplantation, CMTSG=Canadian Multicenter Transplant Group, DST=donor specific transfusion, HLA=human leukocyte antigen, LD=living donor transplantation, LP=leukocyte-poor transfusions, mPTF=matched pretransplant transfusion, PRC=packed red cell transfusion, PT=protocol transfusion, RT=random transfusion, NA=not applicable, N=Total number of study population, n=number of patients in the subgroup, NR=not reported, NT=Number of transfused patients, Ns=number of sensitized patients,