# Strength of Evidence Tables

Appendix Table 1 Strength of evidence for the impact of transfusion (any kinds) on renal allograft outcomes in kidney (with or without pancreas) transplant recipients (KQ1a)

| | | Quality | | Assessment | | Summary of Findings
Outcome | Number of Analyses | Study Design | Risk of Bias | Consistency | Directness | Precision | Quality
Significant impact on any rejection | 25 | 4 CCT 1 POBS 16 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Direction of impact on any rejection^*^ | 47 | 8 CCT 1 POBS 26 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Insufficient
Significant impact on 1-year graft survival | 55 | 4 CCT 6 POBS 38 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Magnitude of impact on 1-year graft survival | 132 | 9 CCT 9 POBS 72 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Significant impact on max duration graft survival | 65 | 4 CCT 6 POBS 44 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Magnitude of impact on max duration graft survival | 146 | 10 CCT 11 POBS 80 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Significant impact on 1-year patient survival | 16 | 2 CCT 1 POBS 10 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Magnitude of impact on 1-year patient survival | 35 | 7 CCT 1 POBS 19 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Significant impact on max duration patient survival | 18 | 1 CCT 2 POBS 13 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Magnitude of impact on max duration patient survival | 41 | 7 CCT 2 POBS 23 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low

* Insufficient data since it was difficult to gauge the magnitude of the effect from the available data

CCT=clinical controlled trials, NA=not applicable, POBS=prospective observational studies, ROBS=retrospective observational studies

Appendix Table 2 Strength of evidence for the impact of therapeutic transfusion (excluding donor-specific transfusion analyses) on renal allograft outcomes (KQ1a)

| | | Quality | | Assessment | | Summary of Findings
Outcome | Number of Analyses | Study Design | Risk of Bias | Consistency | Directness | Precision | Quality
Significant impact on any rejection | 14 | 1 CCT 0 POBS 12 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Direction of impact on any rejection^*^ | 20 | 1 CCT 0 POBS 14 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Insufficient
Significant impact on 1-year graft survival | 43 | 3 CCT 4 POBS 32 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Magnitude of impact on 1-year graft survival | 99 | 5 CCT 7 POBS 60 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Significant impact on max duration graft survival | 47 | 3 CCT 4 POBS 34 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Magnitude of impact on max duration graft survival | 105 | 5 CCT 9 POBS 63 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Significant impact on 1-year patient survival | 12 | 1 CCT 0 POBS 9 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Magnitude of impact on 1-year patient survival | 20 | 2 CCT 0 POBS 13 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Significant impact on max duration patient survival | 12 | 0 CCT 0 POBS 11 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Magnitude of impact on max duration patient survival | 23 | 2 CCT 1 POBS 14 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low

* Insufficient data since it was difficult to gauge the magnitude of the effect from the available data

CCT=clinical controlled trials, NA=not applicable, POBS=prospective observational studies, ROBS=retrospective observational studies

Appendix Table 3 Strength of evidence for the impact of donor-specific transfusion versus therapeutic transfusion on renal allograft outcomes in kidney transplant recipients (KQ 1bi)

| | | Quality | | Assessment | | Summary of Findings
Outcome | Number of Analyses | Study Design | Risk of Bias | Consistency | Directness | Precision | Quality
Significant impact on any rejection | 3 | 0 CCT 0 POBS 3 ROBS | Serious limitation | Serious inconsistency | No indirectness | NA | Low
Direction of impact on any rejection^*^ | 7 | 0 CCT 0 POBS 6 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Insufficient
Significant impact on 1-year graft survival | 4 | 0 CCT 0 POBS 4 ROBS | Serious limitation | Serious inconsistency | No indirectness | NA | Low
Magnitude of impact on 1-year graft survival | 16 | 0 CCT 1 POBS 9 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Significant impact on max duration graft survival | 5 | 0 CCT 0 POBS 5 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Magnitude of impact on max duration graft survival | 17 | 0 CCT 1 POBS 10 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Significant impact on 1-year patient survival | 2 | 0 CCT 0 POBS 2 ROBS | Serious limitation | Serious inconsistency | No indirectness | NA | Insufficient
Magnitude of impact on 1-year patient survival | 4 | 0 CCT 0 POBS 3 ROBS | Serious limitation | Serious inconsistency | No indirectness | NA | Low
Significant impact on max duration patient survival | 2 | 0 CCT 0 POBS 2 ROBS | Serious limitation | Serious inconsistency | No indirectness | NA | Insufficient
Magnitude of impact on max duration patient survival | 4 | 0 CCT 0 POBS 3 ROBS | Serious limitation | Serious inconsistency | No indirectness | NA | Low

* Insufficient data since it was difficult to gauge the magnitude of the effect from the available data

CCT=clinical controlled trials, NA=not applicable, POBS=prospective observational studies, ROBS=retrospective observational studies

Appendix Table 4 Strength of evidence for the impact of number of transfusion on renal allograft outcomes in kidney transplant recipients (KQ 1bii)

| | | Quality | | Assessment | | Summary of Findings
Outcome | Number of Analyses | Study Design | Risk of Bias | Consistency | Directness | Precision | Quality
Any versus Any number of transfusion
Significant impact on any rejection | 5 | 0 CCT 0 POBS 2 ROBS | Serious limitation | Very Serious inconsistency | No indirectness | NA | Low
Direction of impact on any rejection^*^ | 18 | 0 CCT 0 POBS 4 ROBS | Very Serious limitation | Very serious inconsistency | No indirectness | NA | Insufficient
Any number vs. no transfusion
Significant impact on 1-year graft survival | 12 | 0 CCT 0 POBS 6 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Magnitude of impact on 1-year graft survival | 51 | 1 CCT 1 POBS 16 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Significant impact on max duration graft survival | 9 | 0 CCT 0 POBS 6 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Magnitude of impact on max duration graft survival | 53 | 1 CCT 1 POBS 17 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Significant impact on 1-year patient survival | 8 | 0 CCT 0 POBS 3 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Magnitude of impact on 1-year patient survival | 8 | 0 CCT 0 POBS 3 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Significant impact on max duration patient survival | 8 | 0 CCT 0 POBS 3 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Magnitude of impact on max duration patient survival | 7 | 0 CCT 0 POBS 3 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Higher versus lower transfusion intensity
Significant impact on 1-year graft survival | 11 | 0 CCT 0 POBS 6 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Magnitude of impact on 1-year graft survival | 43 | 1 CCT 1 POBS 18 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Significant impact on max duration graft survival | 9 | 1 CCT 0 POBS 6 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Magnitude of impact on max duration graft survival | 47 | 2 CCT 1 POBS 21 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Significant impact on 1-year patient survival | 7 | 0 CCT 0 POBS 3 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Magnitude of impact on 1-year patient survival | 7 | 0 CCT 0 POBS 3 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Significant impact on max duration patient survival | 7 | 0 CCT 0 POBS 3 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Magnitude of impact on max duration patient survival | 5 | 0 CCT 0 POBS 3 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low

* Insufficient data since it was difficult to gauge the magnitude of the effect from the available data

CCT=clinical controlled trials, NA=not applicable, POBS=prospective observational studies, ROBS=retrospective observational studies

Appendix Table 5 Strength of evidence for the impact of unit of transfusion on renal allograft outcomes in kidney transplant recipients (KQ 1bii)

| | | Quality | | Assessment | | Summary of Findings
Outcome | Number of Analyses | Study Design | Risk of Bias | Consistency | Directness | Precision | Quality
Any versus any transfusion units
Significant impact on any rejection | 1 | 1 CCT 0 POBS 0 ROBS | Very serious limitation | NA | No indirectness | NA | Insufficient
Direction of impact on any rejection^*^ | 1 | 1 CCT 0 POBS 0 ROBS | Very serious limitation | NA | No indirectness | NA | Insufficient
Any units versus no transfusion
Significant impact on 1-year graft survival | 11 | 0 CCT 0 POBS 4 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Magnitude of impact on 1-year graft survival | 21 | 1 CCT 0 POBS 8 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Significant impact on max duration graft survival | 16 | 1 CCT 0 POBS 6 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Magnitude of impact on max duration graft survival | 22 | 1 CCT 1 POBS 8 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Significant impact on 1-year patient survival | 0 | --- | --- | --- | --- | --- | Insufficient
Magnitude of impact on 1-year patient survival | 0 | --- | --- | --- | --- | --- | Insufficient
Significant impact on max duration patient survival | 0 | --- | --- | --- | --- | --- | Insufficient
Magnitude of impact on max duration patient survival | 0 | --- | --- | --- | --- | --- | Insufficient
Higher versus lower transfusion units
Significant impact on 1-year graft survival | 6 | 0 CCT 0 POBS 3 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Magnitude of impact on 1-year graft survival | 12 | 1 CCT 0 POBS 7 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Significant impact on max duration graft survival | 12 | 1 CCT 0 POBS 5 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Magnitude of impact on max duration graft survival | 16 | 1 CCT 0 POBS 9 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Significant impact on 1-year patient survival | 0 | --- | --- | --- | --- | --- | Insufficient
Magnitude of impact on 1-year patient survival | 0 | --- | --- | --- | --- | --- | Insufficient
Significant impact on max duration patient survival | 0 | --- | --- | --- | --- | --- | Insufficient
Magnitude of impact on max duration patient survival | 0 | --- | --- | --- | --- | --- | Insufficient

* Insufficient data since it was difficult to gauge the magnitude of the effect from the available data

CCT=clinical controlled trials, NA=not applicable, POBS=prospective observational studies, ROBS=retrospective observational studies

Appendix Table 6 Strength of evidence for the impact of number of donors on renal allograft outcomes in kidney transplant recipients (KQ 1bii)

| | | Quality | | Assessment | | Summary of Findings
Outcome | Number of Analyses | Study Design | Risk of Bias | Consistency | Directness | Precision | Quality
Significant impact on any rejection | 0 | --- | --- | --- | --- | --- | Insufficient
Direction of impact on any rejection | 0 | --- | --- | --- | --- | --- | Insufficient
Significant impact on 1-year graft survival | 0 | --- | --- | --- | --- | --- | Insufficient
Magnitude of impact on 1-year graft survival | 0 | --- | --- | --- | --- | --- | Insufficient
Significant impact on max duration graft survival | 0 | --- | --- | --- | --- | --- | Insufficient
Magnitude of impact on max duration graft survival | 0 | --- | --- | --- | --- | --- | Insufficient
Significant impact on 1-year patient survival | 0 | --- | --- | --- | --- | --- | Insufficient
Magnitude of impact on 1-year patient survival | 0 | --- | --- | --- | --- | --- | Insufficient
Significant impact on max duration patient survival | 0 | --- | --- | --- | --- | --- | Insufficient
Magnitude of impact on max duration patient survival | 0 | --- | --- | --- | --- | --- | Insufficient

Appendix Table 7 Strength of evidence for the impact of leukocyte-depleted transfusion on renal allograft outcomes in kidney transplant recipients (KQ 1biii)

| | | Quality | | Assessment | | Summary of Findings
Outcome | Number of Analyses | Study Design | Risk of Bias | Consistency | Directness | Precision | Quality
Leukocyte depleted blood versus no transfusions
Significant impact on any rejection | 0 | --- | --- | --- | --- | --- | Insufficient
Direction of impact on any rejection | 0 | --- | --- | --- | --- | --- | Insufficient
Significant impact on 1-year graft survival | 0 | --- | --- | --- | --- | --- | Insufficient
Magnitude of impact on 1-year graft survival | 2 | 0 CCT 1 POBS 1 ROBS | Serious limitation | Serious inconsistency | No indirectness | NA | Low
Significant impact on max duration graft survival | 0 | --- | --- | --- | --- | --- | Insufficient
Magnitude of impact on max duration graft survival | 2 | 0 CCT 1 POBS 1 ROBS | Serious limitation | Serious inconsistency | No indirectness | NA | Low
Significant impact on 1-year patient survival | 0 | --- | --- | --- | --- | --- | Insufficient
Magnitude of impact on 1-year patient survival | 0 | --- | --- | --- | --- | --- | Insufficient
Significant impact on max duration patient survival | 1 | 0 CCT 1 POBS 0 ROBS | Serious limitation | NA | No indirectness | NA | Insufficient
Magnitude of impact on max duration patient survival | 1 | 0 CCT 1 POBS 0 ROBS | Serious limitation | NA | No indirectness | NA | Insufficient
Leukocyte depleted versus therapeutic transfusions
Significant impact on any rejection | 0 | --- | --- | --- | --- | --- | Insufficient
Direction of impact on any rejection | 0 | --- | --- | --- | --- | --- | Insufficient
Significant impact on 1-year graft survival | 1 | 0 CCT 1 POBS 0 ROBS | Serious limitation | NA | No indirectness | NA | Insufficient
Magnitude of impact on 1-year graft survival | 2 | 0 CCT 1 POBS 1 ROBS | Serious limitation | Serious inconsistency | No indirectness | NA | Low
Significant impact on max duration graft survival | 1 | 0 CCT 1 POBS 0 ROBS | Serious limitation | NA | No indirectness | NA | Insufficient
Magnitude of impact on max duration graft survival | 2 | 0 CCT 1 POBS 1 ROBS | Serious limitation | Serious inconsistency | No indirectness | NA | Low
Significant impact on 1-year patient survival | 0 | --- | --- | --- | --- | --- | Insufficient
Magnitude of impact on 1-year patient survival | 0 | --- | --- | --- | --- | --- | Insufficient
Significant impact on max duration patient survival | 1 | 0 CCT 1 POBS 0 ROBS | Serious limitation | NA | No indirectness | NA | Insufficient
Magnitude of impact on max duration patient survival | 1 | 0 CCT 1 POBS 0 ROBS | Serious limitation | NA | No indirectness | NA | Insufficient

CCT=clinical controlled trials, LDT=leukocyte depleted transfusion, NA=not applicable, POBS=prospective observational studies, ROBS=retrospective observational studies, Txn=transfusion

Appendix Table 8 Strength of evidence for the impact of transfusion over different time periods on renal allograft outcomes in kidney transplant recipients (KQ 1biv-v)

| | | Quality | | Assessment | | Summary of Findings
Outcome | Number of Analyses | Study Design | Risk of Bias | Consistency | Directness | Precision | Quality
Significant impact on any rejection | 11 | 1 CCT 0 POBS 8 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Direction of impac on any rejection^*^ | 35 | 7 CCT 0 POBS 20 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Significant impact on 1-year graft survival | 47 | 3 CCT 5 POBS 34 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Magnitude of impact on 1-year graft survival | 108 | 8 CCT 7 POBS 66 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Significant impact on max duration graft survival | 57 | 3 CCT 5 POBS 40 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Magnitude of impact on max duration graft survival | 119 | 8 CCT 9 POBS 73 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Significant impact on 1-year patient survival | 17 | 2 CCT 1 POBS 10 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Magnitude of impact on 1-year patient survival | 30 | 6 CCT 1 POBS 17 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Significant impact on max duration patient survival | 18 | 1 CCT 1 POBS 14 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Magnitude of impact on max duration patient survival | 37 | 6 CCT 2 POBS 22 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low

* Insufficient data since it was difficult to gauge the magnitude of the effect from the available data

CCT=clinical controlled trials, NA=not applicable, POBS=prospective observational studies, ROBS=retrospective observational studies

Appendix Table 9 Strength of evidence for the impact of PRA assays in predicting renal allograft outcomes in kidney (with or without pancreas) transplant recipients (KQ2b)

| | | Quality | | Assessment | | Summary of Findings
Outcome | Number of Analyses | Study Design | Risk of Bias | Consistency | Directness | Precision | Quality
Significant impact on 1-year rejection | 1 | 1 CCT | Serious limitation | NA | No indirectness | NA | Low
Significant impact on max duration rejection | 2 | 1 CCT 1 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Direction of impact on 1-year rejection^*^ | 1 | 1 CCT | Serious limitation | NA | No indirectness | NA | Insufficient
Direction of impact on max duration rejection^*^ | 2 | 1 CCT 1 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Insufficient
Significant impact on 1-year graft survival | 5 | 1 CCT 3 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Significant impact on max duration graft survival | 9 | 1 CCT 6 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Direction of impact on 1-year graft survival | 8 | 1 CCT 6 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Direction of impact on max duration graft survival | 14 | 1 CCT 10 ROBS | Serious limitation | Very serious inconsistency | No indirectness | NA | Low
Significant impact on 1-year patient Survival | 2 | 1 ROBS | Serious limitation | NA | No indirectness | NA | Low
Significant impact on Max duration patient survival | 2 | 1 ROBS | Serious limitation | NA | No indirectness | NA | Low
Direction of impact on 1-year patient survival | 2 | 1 ROBS | Serious limitation | NA | No indirectness | NA | Low
Magnitude of impact on max duration patient survival | 2 | 1 ROBS | Serious limitation | NA | No indirectness | NA | Low

* Insufficient data since it was difficult to gauge the magnitude of the effect from the available data

CCT=clinical controlled trials, NA=not applicable, PRA = Panel Reactive Antibodies, ROBS=retrospective observational studies