# Demographics Table

Characteristics of Unique Studies Included for Evaluations

Study, Year (N=) | Study Design | Study Period | Population | Transfusion type^*^ Exp (%) Control (%) | Type of control groups | Accounted for confounding | Demographic data in both †groups | Validity of the study
Jovicic S, 2010 (N=159) | ROBS | 1990–2000 | Patients receiving living donor renal transplants | DST (9) RBT (83) NT (8) | Concurrent | Yes | Yes | Fair
Aalten J, 2009 (N=859) | ROBS | 1996–2006 | Female patients receiving primary renal transplants | DST (6) PT (8) RBT (42) NT (44) | Concurrent | Yes | Yes | Fair
Eisenberger U, 2009 (N=138) | ROBS | 1990–2005 | Patients receiving living donor renal transplants | DST (50) NT (50) | Historical | No | Yes | Poor
Tang H, 2008 (N=2,882) | ROBS | 1995–2002 | Patients with ESRD caused by SLE undergoing renal transplant | RBT (63) NT (37) | Concurrent | Yes | No | Poor
Waanders MM, 2008 (N=118) | ROBS | 1996–2005 | Patients receiving simultaneous pancreas-renal transplants | PT (42) NT (58) | Concurrent | Yes | Yes | Fair
Marti HP, 2006 (N=110) | CCT | 1993–2003 | Patients receiving living renal transplants | DST (50) NT (50) | Concurrent | Yes | Yes | Good
El-Husseini AA, 2005 (N=284) | ROBS | 1976–2004 | Patients (≤ 20 years) receiving living donor renal transplants | RBT (58) NT (42) | Concurrent | Yes | No | Poor
Opelz G, 2005 (N= 164,534) | ROBS | 1982–2002 | Patients receiving renal transplants, who were included in the international Collaborative Transplant Study | NR | Concurrent | Yes | No | Poor
Higgins RM, 2004 (N=265) | ROBS | 1994–2002 | Patients receiving renal transplants, treated with CyA or Tac | RBT ≥ 3 (54) RBT 0–2 (46)^‡^ | Concurrent | Yes | No | Poor
Park YH, 2004 (N=77) | ROBS | 1991–2003 | Patients receiving living-related renal transplants | RBT (18) NT (82) | Concurrent | Yes | No | Poor
Bunnapradist S, 2003 (N=7079) | ROBS | 1988–1999 | Patients receiving cadaver renal transplants, treated with CyA-MMF or Tac-MMF | NR | Concurrent | Yes | Yes | Fair
Herget-Rosenthal S, 2003 (N=NR) | POBS | 1990-NR | Renal transplant recipients with serum ferritin levels above 1,100 ng/mL | NR | Concurrent | Yes | No | Poor
Lietz K, 2003 (N=267) | ROBS | 1990–1997 | Patients receiving renal transplants whose graft survived > 6 months | RBT (78) NT (22) | Concurrent | Yes | No | Poor
Agarwal SK, 2002 (N=144) | ROBS | 1980–1989 | Patients receiving living-related renal transplants | NR | Concurrent | Yes | No | Poor
Barbari A, 2001 (N=84) | ROBS | NR | Patients receiving renal transplants | DST (76) NT (24) | Concurrent | No | No | Poor
Hiesse C, 2001 (N=106) | CCT | 1992–1996 | Transfusion naïve cadaverrenal transplant recipients | PT (66) NT (34) | Concurrent | Yes | Yes | Good
Poli L, 2001 (N=514) | ROBS | 1967–2000 | Patients receiving living donor renal transplants | RBT (43) NT (57) | Concurrent | No | No | Poor
Montagnino G, 2000 (N=143) | Pooled analysis of CCT | NR | Patients receiving primary renal transplants | NR | NR | Yes | No | Poor
Alexander JW, 1999 (N=212) | CCT | 1992–1996 | Patients receiving non-HLA identical living renal transplants | DST (54) NT (46) | Concurrent | Yes | Yes | Good
de Mattos AM, 1999 (N=107) | ROBS | 1977–1993 | Patients receiving HLA-identical sibling renal transplants | RBT (79) NT (21) | Concurrent | No | No | Poor
Padányi A, 1998 (N=57) | ROBS | NR | Patients receiving living-related renal transplants | DST (23) RBT (77) | Concurrent | No | No | Poor
Chavers BM, 1997 (N=4015) | ROBS | 1987–1995 | Pediatric patients (<18 years old) receiving renal transplants | RBT (71) NT (29) | Concurrent | No | No | Poor
Galvao M, 1997 (N=60) | ROBS | 1983-NR | Patients receiving living, unrelated renal transplants | DST (62) NT (38) | Concurrent | No | Yes | Poor
Opelz G, 1997 (N=423) | CCT | 1987–1994 | Patients receiving primary cadaver renal transplants | RBT (48) NT (52) | Concurrent | Yes | Yes | Good
Sharma RK, 1997 (N=30) | CCT | 1992–1993 | Patients receiving living-related renal transplants | DST (50) NT (50) | Concurrent | Yes | Yes | Good
Inoue S, 1996 (N=115) | ROBS | 1982–1993 | Patients receiving living donor renal transplants | DST (37) NT (63) | Concurrent | Yes | No | Poor
Jin DC, 1996 (N=680) | ROBS | 1969–1994 | Patients receiving primary living-donor transplants, treated with CyA | DST (22) NT (78) | Concurrent | Yes | No | Poor
Peters TG, 1995 (N=17,937) | ROBS | 1982–1991 | Patients receiving cadaver renal transplants | RBT (NR) NT (NR) | NR | Yes | No | Poor
Poli F, 1995 (N=416) | ROBS | 1989–1993 | Patients receiving cadaver renal transplants | RBT (51) NT (49) | Concurrent | Yes | No | Poor
Barber WH, 1994 (N=598) | ROBS | 1981–1987 | Patients receiving one-haplotype matched living-related renal transplants | DST (48) NT (52) | Concurrent | No | No | Poor
Kahn D, 1994 (N=49) | ROBS | 1970–1988 | Patients receiving 1-haplotype matched, living-related renal transplants | DST (61) NT (39) | Concurrent | No | No | Poor
Sautner T, 1994 (N=73) | ROBS | 1982–1991 | Grafts with primary non-function, with data required from both kidneys of each donor | RBT (81) NT (19) | Concurrent | Yes | No | Poor
Egidi MF, 1993 (N=248) | ROBS | 1984–1990 | Patients receiving primary renal transplants, treated with CyA | RBT (83) NT (17) | Concurrent | No | Yes | Poor
Basri N, 1992 (N=53) | POBS | 1988–1990 | Patients receiving haploidentical living-related renal transplants | DST (53) NT (47) | Concurrent | No | No | Poor
Sakagami K, 1992 (N=109) | ROBS | 1974–1991 | Patients receiving haploidentical living-related donor renal transplants | DST (49) NT (51) | Concurrent | No | Yes | Poor
Vathsala A, 1992 (N=116) | ROBS | 1984–1990 | Patients receiving cadaver renal transplants | RBT >7 (37) RBT <7 (63)^‡^ | Concurrent | No | Yes | Poor
Velidedeoglu E, 1992 (N=437) | ROBS | 1985–1990 | Patients receiving ABO-compatible, living donor renal transplants | DST (79) NT (21) | Concurrent | Yes | Yes | Fair
Xiao X, 1992 (N=201) | ROBS | 1977–1990 | Patients receiving cadaver renal transplants | RBT (76) NT (23) | Concurrent | No | No | Poor
Garcia LF, 1991 (N=NR) | ROBS | 1982-NR | Patients receiving haploidentical living-related donor renal transplants | DST (n=NR) RBT(n=NR) NT (n=13) | Historical | No | No | Poor
Kerman RH, 1991 (N=324) | ROBS | NR | Patients receiving primary cadaver renal transplants, treated with CyA | RBT (62) NT (38) | Concurrent | No | No | Poor
Potter DE, 1991 (N=634) | ROBS | 1983–1989 | Patients (adults and children) receiving primary cadaver renal transplants | RBT (71) NT (29) | Concurrent | No | No | Poor
Reed A, 1991 (N=119) | ROBS | 1986–1989 | Patients receiving renal transplants living-related | DST (56) RBT (44) | Concurrent | Yes | Yes | Fair
Salvatierra O, 1991 (N=118) | ROBS | 1986–1990 | Patients with 1- and 2-haplotype mismatches with living donor renal transplants | DST (60) NT (40) | Concurrent | No | No | Poor
Sanfilippo F, 1990 (N=2138) | POBS | 1983–1988 | Patients receiving primary living donor renal transplants | DST (68) NT (32) | Concurrent | No | No | Poor
Kasai I, 1989 (N=26) | ROBS | NR | Patients receiving living-related renal transplants | DST (73) NT (27) | Concurrent | No | No | Poor
Pfaff WW, 1989 (N=392) | POBS | 1980–1987 | Patients receiving primary renal transplant | PT (83) NT(17) | Concurrent | No | No | Poor
Sells RA, 1989 (N=134) | ROBS | NR | Patients receiving HLA mismatched living-related renal transplants | DST (60) NT (40) | Concurrent | No | No | Poor
Yamauchi J, 1989 (N=28) | ROBS | 1984–1988 | Patients receiving HLA haploidentical living-related renal transplants | DST (68) NT (32) | Concurrent | No | No | Poor
Albrechtsen D, 1988 (N=701) | CCT | 1982–1985 | Patients receiving renal transplants | RBT (68) NT (32) | Concurrent | No | Yes | Fair
Brynger H, 1988 (N=459) | CCT | 1985–1987 | Patients receiving primary cadaver renal transplants | RBT (63) NT (37) | Concurrent | No | No | Poor
Bucin D, 1988 (N=116) | ROBS | 1979–1982 | Patients receiving renal transplants | RBT (68) NT (32) | Concurrent | No | Yes | Poor
Kerman RH, 1988 (N=320) | ROBS | NR | Patients receiving primary cadaver renal transplants | RBT (69) NT (31) | Concurrent | No | No | Poor
Madrenas J, 1988 (N=287) | ROBS | 1975–1985 | Patients receiving renal transplants | RBT (81) NT (19) | Concurrent | Yes | No | Poor
Takiff H, 1988 (N=NR) | ROBS | 1974–1986 | Patients receiving primary cadaveric renal transplants | RBT (NR) NT (NR) | Concurrent | No | No | Fair^§^
Alarif 1987 (N=121) | ROBS | 1984–1985 | Patients receiving renal transplants | RBT (100) | NR | No | No | Poor
Casadei DH, 1987 (N=42) | ROBS | 1978–1985 | Patients receiving haploidentical or histoidentical renal transplants | DST+RBT (52) RBT (48) | Historical | No | No | Poor
Cheigh JS, 1987 (N=90) | POBS | NR | Patients receiving one-haplotype mismatched living-related renal transplants | DST (44) NT (56) | Historical | No | No | Poor
Garcia VD, 1987 (N=89) | ROBS | 1982–1986 | Patients receiving living-donor renal transplants | DST (39) NT (61) | Concurrent | No | Yes | Poor
Ho-Hsieh H, 1987 (N=51) | ROBS | 1963–1984 | Patients with ADPKD receiving renal transplants | RBT (65) NT (35) | Historical | No | No | Poor
Huprikar AG, 1987 (N=66) | ROBS | 1983–1986 | Patients (age=12–60 years) receiving primary renal transplants | DST (50) RBT(50) | Concurrent | No | No | Poor
Melzer JS, 1987 (N=212) | ROBS | 1983–1985 | Patients receiving primary cadaver renal transplants | RBT (77) NT (23) | Concurrent | No | Yes | Poor
Salvatierra O, 1987 (N=230) | ROBS | 1978–1986 | Patients receiving HLA-identical renal transplants | DST (17) NT (83) | Concurrent | No | No | Poor
Takahashi K, 1987 (N=290) | ROBS | 1983–1987 | Patients receiving living-related renal transplants | DST (59) RBT(41) | Concurrent | No | No | Poor
Leivestad T, 1986 (N=74) | ROBS | 1980–1984 | Potential primary graft recipients of a haploidentical living-related renal transplant | DST (43) NT (57) | Concurrent | No | No | Poor
CMTSG, 1986 (N=291) | CCT | 1980–1985 | Patients receiving cadaveric renal transplants | NR | Concurrent | Yes | No | Fair
Norman DJ, 1986 (N=43) | ROBS | 1980–1984 | Patients receiving HLA-identical sibling renal transplants | RBT (58) NT (42) | Concurrent | No | No | Poor
Sanfilippo F, 1986 (N=3,628) | ROBS | 1977–1982 | Patients receiving cadaver renal transplants | RBT (NR) NT (NR) | NR | Yes | No | Poor
Glass NR, 1985 (N=206) | ROBS | 1980–1984 | Patients receiving living-donor transplants | DST (64) RBT(36) | Concurrent | No | Yes | Poor
Sabbaga E, 1985 (N=40) | ROBS | 1971–1983 | Patients receiving living non-related donor transplants | DST (50) NT (50) | Concurrent | No | Yes | Poor
Sanfilippo F, 1985 (N=87) | CCT | 1980–1982 | Potential candidates for cadaver renal transplants | LT (52) RBT (48) | Concurrent | Yes | No | Poor
Sommer BG, 1985 (N=27) | CCT | NR | Patients receiving living-related renal transplants | DST (37) NT (63) | Concurrent | Yes | Yes | Fair
Akiyama N, 1984 (N=19) | ROBS | 1977–1982 | Patients receiving 1-haplotype mismatched living-related renal transplants | DST (58) RBT(42) | Concurrent | No | No | Poor
d’Apice AJ, 1984 (N=337) | CCT | 1979–1981 | Patients receiving renal transplants | RBT (83) NT (17) | Concurrent | Yes | No | Fair
Flechner SM, 1984 (N=36) | ROBS | 1981–1983 | Patients receiving haplotype-matched living-related renal transplants | RBT (58) NT (42) | Historical | No | No | Poor
Gardner B, 1984 (N=100) | ROBS | NR | Patients receiving renal transplants, treated with CyA | RBT (75) NT (25) | Concurrent | No | No | Poor
Guillou PJ, 1984 (N=114) | ROBS | 1981–1984 | Patients receiving cadaver renal transplants | RBT(56) NT (44) | Concurrent | No | Yes | Poor
Jeffery JR, 1984 (N=NR) | ROBS | 1975–1979? | Patients receiving renal transplants | RBT (NR) NT (NR) | Concurrent | No | No | Poor
Sijpkens YWJ, 1984 (N=59) | POBS | 1979–1981 | Patients receiving living-related renal transplants | DST (56) NT (44) | Historical | No | Yes | Fair
Ting A, 1984 (N=298) | ROBS | 1975–1983 | Patients receiving primary cadaver renal transplant | RBT (57) NT (43) | Concurrent | No | No | Poor
Velasco N, 1984 (N=91) | ROBS | 1975–1982 | Patients receiving cadaver renal transplants | RBT ≥5 (69) RBT<5 (31)^‡^ | Concurrent | No | No | Poor
Cheigh JS, 1983 (N=62) | ROBS | 1975–1982 | Patients receiving cadaver renal transplant | RBT (24) NT (76) | Concurrent | No | No | Poor
Cho SI, 1983 (N=NR) | ROBS | 1976–1981 | Patients receiving primary cadaver renal transplants | RBT (NR) NT (NR) | Concurrent | No | No | Poor
Garvin PJ, 1983 (N=92) | ROBS | 1977–1981 | Patients receiving living-donor and cadaver renal transplants | RBT (77) NT (23) | Concurrent | No | No | Poor
Kerman RH, 1983 (N=104) | ROBS | NR | Patients receiving cadaver renal transplants | RBT >5 (49) RBT <5 (51)^‡^ | Concurrent | No | No | Poor
Madsen M, 1983 (N=158) | POBS | 1978–1982 | Patients receiving cadaver renal transplants | RBT (90) NT (10) | Concurrent | No | No | Poor
Muller GA, 1983 (N=80) | ROBS | NR | Patients receiving cadaver renal transplants | RBT ≥4 (41) RBT 0–3 (59)^‡^ | Concurrent | No | No | Poor
Myburgh JA, 1983 (N=262) | ROBS | 1966–1982 | Patients receiving cadaver renal transplants | RBT (74) NT (26) | Concurrent | No | Yes | Poor
Nubé MJ, 1983 (N=55) | POBS | 1972–1981 | Patients receiving primary cadaver renal transplants | LT (27) RBT (47) NT (25) | Historical | No | Yes | Poor
Okiye SE, 1983 (N=165) | ROBS | 1968–1981 | Patients receiving primary renal transplants | RBT (79) NT (21) | Concurrent | No | No | Poor
Rao KV, 1983 (N=300) | ROBS | 1965–1980 | Patients receiving renal transplants | NR | Concurrent | Yes | No | Poor
Richie RE, 1983 (N=452) | ROBS | 1977–1981 | Patients receiving cadaver or living-donor renal transplants | RBT (63) NT (37) | Concurrent | No | No | Poor
Spees EK, 1983 (N=2,406) | ROBS | 1977–1982 | Patients receiving cadaver renal transplants | RBT (80) NT (20) | Concurrent | No | No | Poor
Zeichner WD, 1983 (N=77) | ROBS | NR | Patients receiving primary cadaver renal transplants | RBT (79) NT (21) | Concurrent | No | No | Poor
Betuel H, 1982 (N=54) | ROBS | 1977–1981 | Patients receiving primary cadaver renal transplants | RBT (74) NT (26) | Concurrent | No | No | Poor
Chu D, 1982 (N=32) | POBS | 1977-after | Patients receiving renal transplants | RBT (69) NT (31) | Concurrent | No | No | Poor
d’Apice 1982 (N=54) | ROBS | 1977–1980 | Dialysis patients who had not received transplants prior to study | PT (100) | Concurrent | No | No | Poor
Dewar PJ, 1982 (N=276) | ROBS | 1969–1980 | Patients receiving primary cadaver renal transplants | RBT (68) NT (32) | Concurrent | No | No | Poor
Fehrman I, 1982 (N=130) | ROBS | 1970–1981 | Patients receiving living-related renal transplants | RBT (65) NT (35) | Concurrent | No | No | Poor
Flechner SM, 1982 (N=384) | ROBS | 1976–1979 | Patients receiving primary cadaver renal transplants | RBT (66) NT (34) | Concurrent | No | No | Poor
Fradet Y, 1982 (N=121) | ROBS | 1973–1980 | Patients receiving primary cadaver renal transplants | RBT (77) NT (23) | Concurrent | No | Yes | Poor
Frisk B, 1982 (N=237) | ROBS | 1977–1981 | Patients receiving primary, 1-haplotype-matched cadaver renal transplants | PT (33) RBT (62) NT (5) | Concurrent | No | No | Poor
Fuller TC, 1982 (N=156) | ROBS | 1976–1981 | Patients receiving primary cadaver or HLA haploidentical living-related renal transplants | RBT (87) NT (13) | Historical | No | No | Poor
Glass NR, 1982 (N=94) | ROBS | 1975–1980 | Patients receiving primary cadaver renal transplants | RBT (48) NT (52) | Concurrent | No | Yes | Poor
Kovithavongs T, 1982 (N=28) | ROBS | NR | Patients receiving living-related, HLA haploidentical renal transplants | RBT (89) NT (11) | Concurrent | No | No | Poor
Mendez R, 1982 (N=67) | POBS | 1978–1980 | Patients receiving primary cadaver renal transplants | PT (28) RBT (36) PT + RBT (16) NT (19) | Concurrent | No | No | Poor
Sirchia G, 1982 (N=45) | POBS | 1981-NR | Patients, treated with periodic hemodialysis, suffering from end-stage renal failure, on admission to the waiting list for primary cadaver renal transplant | PT(76) NT(24) | Historical | No | No | Poor
Takahashi I, 1982 (N=39) | POBS | 1979–1981 | Patients receiving 1-haplotype mismatched living donor renal transplants | DST (59) NT (41) | Concurrent | Yes | No | Poor
Walker JF, 1982 (N=204) | ROBS | 1969–1979 | Patients receiving HD or PD prior to receiving cadaver renal transplants | RBT (67) NT (33) | Concurrent | No | No | Poor
Feduska, 1981 (N= 732) | ROBS | 1970–1980 | Patients receiving primary cadaveric renal transplants | RBT (71) NT (29) | Concurrent | No | No | Poor
Hurst PE, 1981 (N=168) | ROBS | 1967–1978 | Patients receiving cadaver renal transplants | RBT (65) NT (35) | Concurrent | No | Yes | Poor
Persijn GG, 1981 (N=52) | POBS | 1977-NR | Patients receiving cadaver renal transplants | LT (77) LF (23) | Concurrent | No | Yes | Fair
Sirchia G, 1981 (N=484) | ROBS | 1972–1977 | Patients receiving cadaver renal transplants | RBT (67) NT (33) | Concurrent | No | No | Poor
Thorsby E, 1981 (N=129) | ROBS | NR | Patients receiving primary cadaver renal transplants | RBT (57) NT (43) | Concurrent | No | No | Poor
Van Es A, 1981 (N=124) | ROBS | 1966–1980 | Patients receiving primary cadaver renal transplants | RBT (80) NT (20) | Concurrent | No | No | Poor
Corry RJ, 1980 (N=94) | ROBS | 1973–1980 | Patients receiving primary cadaver renal transplants | RBT (45) NT (49) | Concurrent | No | No | Poor
Fehrman I, 1980 (N=229) | ROBS | 1970–1978 | Patients receiving primary cadaver renal transplants | RBT (69) NT (31) | Concurrent | No | Yes | Poor
Jakobsen A, 1980 (N=301) | ROBS | 1965–1977 | Renal transplant recipients with polycystic renal diseases | RBT (52) NT(48) | Concurrent | No | No | Poor
Salvatierra O, 1980 (N=57) | ROBS | NR | Patients receiving one-haplotype matched living-related donor renal transplants | DST (40) NT (60) | Concurrent | No | Yes | Poor
Solheim BG, 1980 (N=191) | ROBS | 1969–1977 | Patients receiving primary living-related renal transplants | RBT (45) NT (55) | Concurrent | No | Yes | Poor
Solheim BG, 1980 (N=348) | ROBS | 1969–1978 | Patients receiving primary cadaver renal transplants | RBT (47) NT (53) | Concurrent | No | Yes | Poor
Spees EK, 1980 (N=995) | ROBS | 1977–1979 | Patients receiving cadaver renal transplants | RBT (83) NT (17) | Concurrent | No | Yes | Poor
Andrus C, 1979 (N=55) | ROBS | 1971–1974 | Patients receiving well-matched cadaver renal transplants | RBT > 5 (73) RBT < 5(27)^‡^ | Concurrent | No | No | Poor
Fauchet R, 1979 (N=66) | ROBS | 1972–1977 | Patients receiving renal transplants | RBT (61) NT (39) | Concurrent | No | Yes | Poor
Hourmant M, 1979 (N=163) | ROBS | NR | Patients receiving cadaver renal transplants | RBT (74) NT (26) | Concurrent | No | No | Poor
Oei LS, 1979^¶^ (N=86) | ROBS | 1973–1979 | Patients receiving living-related renal transplants | RBT (80) NT (20) | Concurrent | No | No | Poor
Sengar D, 1979 (N=117) | ROBS | 1969-NR | Patients receiving primary cadaver renal transplant | RBT (67) NT (33) | Concurrent | No | No | Poor
Werner-Favre C, 1979 (N=101) | POBS | 1976–1978 | Patients receiving primary cadaver renal transplants | RBT (86) NT (14) | Concurrent | No | No | Poor
Blamey RW, 1978 (N=32) | ROBS | 1974–1977 | Patients receiving primary cadaver renal transplants | RBT (31) NT (69) | Concurrent | No | No | Poor
Briggs JD, 1978 (N=83) | ROBS | 1969–1975 | Patients receiving cadaver renal transplants | RBT (82) NT (18) | Concurrent | No | No | Poor
Jeffery JR, 1978 (N=48) | ROBS | 1975–1977 | Patients receiving primary cadaver renal transplant | RBT (50) NT (50) | Concurrent | No | Yes | Poor
Jeffrey JR, 1978 (N=44) | ROBS | NR | Patients receiving primary cadaver renal transplant | RBT (45) NT (55) | Concurrent | No | No | Poor
Stiller CR, 1978 (N=32) | ROBS | NR | Patients receiving cadaver renal transplants | RBT (44) NT (56) | Concurrent | No | No | Poor
Brynger H, 1977 (N=244) | ROBS | 1966–1976 | Patients receiving primary renal transplants | RBT (76) NT (24) | Concurrent | No | Yes | Poor
Fuller TC, 1977 (N=90) | ROBS | 1969–1975 | Patients receiving primary cadaver renal transplants | RBT (89) NT (11) | Concurrent | No | No | Poor
Husberg BO, 1977 (N=95) | ROBS | 1968–1976 | Non-diabetic patients receiving primary cadaver renal transplants | RBT (68) NT (32) | Historical | No | No | Poor
Joysey VC, 1977 (N=272) | ROBS | 1965–1976 | Patients receiving primary cadaver renal transplants | RBT (60) NT (40) | Concurrent | No | No | Poor
Perkins HA, 1977 (N=126) | ROBS | NR | Patients on chronic dialysis, receiving primary renal transplant | RBT (79) NT (21) | Concurrent | No | No | Poor
Persijn GG, 1977 (N=622) | ROBS | 1967–1975 | Patients receiving primary cadaver renal transplant | RBT (95) NT (5) | Concurrent | No | Yes | Poor
Polesky HF, 1977 (N=77) | ROBS | 1973–1976 | Patients receiving primary renal transplant | RBT (52) LT (17) NT (31) | Concurrent | No | No | Poor
Sachs JA, 1977 (N=524) | POBS | 1969–1976 | Patients receiving HLA-matched cadaver renal transplants | RBT (68) NT (32) | Concurrent | No | No | Poor
Säfwenberg J, 1977 (N=115) | ROBS | NR | Patients receiving primary cadaver renal transplant | RBT (55) NT (45) | Concurrent | No | No | Poor
Walter S, 1977 (N=88) | ROBS | 1970–1976 | Patients receiving primary cadaver renal transplant | RBT (74) NT (26) | Concurrent | No | No | Poor
Opelz G, 1974 (N=290) | ROBS | 1970–1974 | Patients receiving primary cadaver renal transplant | RBT (79) NT (21) | Concurrent | No | No | Poor
Opelz G, 1973 (N=148) | ROBS | 1969–1971 | Patients receiving cadaver renal transplants | RBT (83) NT (17) | Concurrent | No | No | Poor
Oplez G, 1973 (N= 144) | ROBS | NR | Patients receiving cadaveric renal transplants | NR | NR | No | No | Poor
Opelz, 1972 (N= 829) | ROBS | NR | Patients receiving primary cadaveric renal transplants | NR | NR | No | No | Poor

* Transfusion data included experimental group(s) versus control group used in the analyses of this report

† Demographic data in relation to the transfusion populations.

‡ Different number/units of transfusions were evaluated in the analyses

§ The validity of the study was graded as fair quality due to the extended followup time period (10 years) and included a large population from the UCLA transplant registry.

‖ Repeated transfusion group versus control group

¶ Analysis only reported results of living-related donor renal transplants, results of cadaveric donor transplants were not evaluated due to overlapping population with Corry RJ et al, 1980.

ADPKD=autosomal dominant polycystic kidney disease, CCT=clinical controlled trial, CyA=cyclosporine, DST=donor specific transfusion, ESRD=end stage renal disease, HD=hemodialysis, HLA=human leukocyte antigen, LT=leukocyte-depleted transfusion, LF=leukocyte-free transfusion, MMF=mycophenolatemofetil, MV=multivariate analysis, N=total number of patients included in the analyses of the study, NR=not reported, NT=no transfusion, PD=peritoneal dialysis, POBS=prospective observational study, PT=protocol transfusion, RBT= random blood transfusion, ROBS=retrospective observational study, SLE=systemic lupus erythematosus, Tac=tacrolimus.