# Embase Search Strategy

No. | Query | Results
#23 | #21 NOT #20 AND ([controlled clinical trial]/lim OR [randomized controlled trial]/lim) AND [embase]/lim | 7
#22 | #21 NOT #20 | 390
#21 | #11 AND #18 AND [humans]/lim | 7480
#20 | #11 AND #18 AND [humans]/lim AND [english]/lim AND [embase]/lim | 7090
#19 | #11 AND #18 | 9010
#18 | #12 OR #13 OR #14 OR #15 OR #16 OR #17 | 143022
#17 | random AND ('transfusion'/exp OR transfusion) AND [embase]/lim | 1212
#16 | 'donor'/exp OR donor AND specific AND ('transfusion'/exp OR transfusion) AND [embase]/lim | 4032
#15 | pretransplant AND ('transfusion'/exp OR transfusion) AND [embase]/lim | 1099
#14 | red AND ('blood'/exp OR blood) AND ('cell'/exp OR cell) AND ('transfusion'/exp OR transfusion) AND [embase]/lim | 14227
#13 | 'blood'/exp OR blood AND ('transfusion'/exp OR transfusion) AND [embase]/lim | 140653
#12 | 'erythrocyte'/exp OR erythrocyte AND ('transfusion'/exp OR transfusion) AND [embase]/lim | 38988
#11 | #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 | 124632
#10 | renal AND recipients AND [embase]/lim | 19546
#9 | 'kidney'/exp OR kidney AND recipients AND [embase]/lim | 24190
#8 | renal AND graft AND [embase]/lim | 42244
#7 | 'kidney'/exp OR kidney AND graft AND [embase]/lim | 54612
#6 | renal AND ('allograft'/exp OR allograft) AND [embase]/lim | 14954
#5 | 'kidney'/exp OR kidney AND ('allograft'/exp OR allograft) AND [embase]/lim | 17271
#4 | renal AND transplant AND [embase]/lim | 52527
#3 | 'kidney'/exp OR kidney AND transplant AND [embase]/lim | 66160
#2 | renal AND ('transplantation'/exp OR transplantation) AND [embase]/lim | 80779
#1 | 'kidney'/exp OR kidney AND ('transplantation'/exp OR transplantation) AND [embase]/lim | 108266