# Ovid MEDLINE Search Strategy

1. Kidney Transplantation/ (68861)
2. (kidney adj2 transplant$).mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] (71289)
3. (renal adj2 transplant$).mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] (32401)
4. (kidney adj2 allograft$).mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] (2226)
5. (renal adj2 allograft$).mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] (9486)
6. (kidney adj3 recipient$).mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] (5604)
7. (renal adj3 recipient$).mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] (11515)
8. kidney graft$.mp. (2474)
9. renal graft$.mp. (2074)
10. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 (76294)
11. erythrocyte transfusion$.mp. or Erythrocyte Transfusion/ (5064)
12. ((donor specific adj2 transfusion$) or DST).mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] (2700)
13. ((pretransplant adj2 transfusion$) or PTF).mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] (596)
14. ((red adj2 cell transfusion$) or RBC transfusion$).mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] (2547)
15. ((random adj3 transfusion$) or rPTF).mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] (164)
16. ((matched adj3 transfusion$) or mPTF).mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] (175)
17. blood transfusion$.tw. (24574)
18. 11 or 12 or 13 or 14 or 15 or 16 or 17 (33059)
19. 10 and 18 (1421)
20. limit 19 to humans (1276)
21. limit 20 to "review articles" (94)
22. 20 not 21 (1182)