# Peer Reviewers

We wish to acknowledge individuals listed below for their review of this report. This report has been reviewed in draft form by individuals chosen for their expertise and diverse perspectives. The purpose of the review was to provide candid, objective, and critical comments for consideration by the EPC in preparation of the final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers.

- Maria Francesca Egidi, MD
  Professor of Medicine
  Medical University of South Carolina
  Charleston, SC
- Fred Sanfilippo, MD, PhD
  Director, Healthcare Innovation Program; Professor of Pathology & Laboratory Medicine, Health Policy & Management, and Business Administration
  Emory University
  Atlanta, GA
- Dorry Segev, MD, PhD
  Associate Professor of Surgery and Epidemiology
  Johns Hopkins University
  Baltimore, MD
- Alan Wilkinson, MD, FRCP
  Professor of Medicine, Director Kidney and Pancreas Transplantation
  David Geffen School of Medicine at UCLA
  Los Angeles, California