# References

1 Gabardi S, Olyaei AJ. Chisolm-Burns MA, editor. Solid organ transplantation, chapter 55. Pharmacotherapy Principles and Practice. NY. McGraw-Hill NY. Second Edition. 2010:939-964.
2 The Organ Procurement and Transplant Network (OPTN). Accessed: July 6, 2010. Available at: http://optn.transplant.hrsa.gov/latestdata/viewdatareports.asp.
3 Opelz G, Sengar DP, Mickey MR, et al. Effect of blood transfusions on subsequent kidney transplants. TRANSPLANT PROC. 1973;5:253-259. PMID: 4572098. [pmid: 4572098].
4 Halloran PF. Call for revolution: a new approach to describing allograft deterioration. Am J Transplant. 2002;2:195-200. PMID: 12096779. [pmid: 12096779].
5 Opelz G, Terasaki PI. Improvement of kidney-graft survival with increased numbers of blood transfusions. N Engl J Med. 1978;299:799-803. PMID: 357971. [pmid: 357971].
6 Fuller TC, Delmonico FL, Cosimi B, et al. Impact of blood transfusion on renal transplantation. Ann Surg. 1978;187:211-218. PMID: 343736. [pmid: 343736].
7 Zhou YC, Cecka JM. Sensitization in renal transplantation. Clin Transpl. 1991:313-323. PMID: 1820127. [pmid: 1820127].
8 Hardy S, Lee SH, Terasaki PI. Sensitization 2001. Clin Transpl. 2001:271-278. PMID: 12211790. [pmid: 12211790].
9 Katznelson S, Bhaduri S, Cecka JM. Clinical aspects of sensitization. Clin Transpl. 1997:285-296. PMID: 9919412. [pmid: 9919412].
10 Ahmed Z, Pi T. Effect of transfusions. Clin Transpl. 1991:305-312. PMID: 1820125. [pmid: 1820125].
11 Cecka JM. The UNOS Scientific Renal Transplant Registry--2000. Clin Transpl. 2000:1-18. PMID: 11512303. [pmid: 11512303].
12 Cecka JM, Cho L. Sensitization. Clin Transpl. 1988:365-373. PMID: 3154486. [pmid: 3154486].
13 Collins AJ, Foley RN, Herzog C, et al. US Renal Data System 2010 Annual Data Report. Am J Kidney Dis. 2011;57(1 Suppl 1):e311-e324.
14 Marti HP, Henschkowski J, Laux G, et al. Effect of donor-specific transfusions on the outcome of renal allografts in the cyclosporine era. Transpl Int. 2006;19:19-26. PMID: 16359373. [pmid: 16359373].
15 Hiesse C, Busson M, Buisson C, et al. Multicenter trial of one HLA-DR-matched or mismatched blood transfusion prior to cadaveric renal transplantation. Kidney Int. 2001;60:341-349. PMID: 11422770. [pmid: 11422770].
16 Alexander JW, Light JA, Donaldson LA, et al. Evaluation of pre- and posttransplant donor-specific transfusion/cyclosporine A in non-HLA identical living donor kidney transplant recipients. Cooperative Clinical Trials in Transplantation Research Group. Transplantation. 1999;68:1117-1124. PMID: 10551639. [pmid: 10551639].
17 Opelz G, Vanrenterghem Y, Kirste G, et al. Prospective evaluation of pretransplant blood transfusions in cadaver kidney recipients. Transplantation. 1997;63:964-967. PMID: 9112348. [pmid: 9112348].
18 Sharma RK, Rai PK, Kumar A, et al. Role of preoperative donor-specific transfusion and cyclosporine in haplo-identical living related renal transplant recipients. Nephron. 1997;75:20-24. PMID: 9031265. [pmid: 9031265].
19 Aalten J, Bemelman FJ, van den Berg-Loonen EM, et al. Pre-kidney-transplant blood transfusions do not improve transplantation outcome: a Dutch national study. Nephrol Dial Transplant. 2009;24:2559-2566. PMID: 19474284. [pmid: 19474284].
20 Albrechtsen D, Flatmark A, Brynger H, et al. Impact of blood transfusions and HLA matching on national kidney transplant programs: the first Swedish-Norwegian Study of cyclosporine. Transplant Proc. 1988;20:257-260. PMID: 3291252. [pmid: 3291252].
21 Barbari A, Stephan A, Masri MA, et al. Donor specific transfusion in kidney transplantation: effect of different immunosuppressive protocols on graft outcome. Transplant Proc. 2001;33:2787-2788. PMID: 11498161. [pmid: 11498161].
22 Barber WH. Donor-specific transfusions in renal transplantation. Clin Transplant. 1994;8:204-206. PMID: 8019037. [pmid: 8019037].
23 Basri N, Nezamuddin N, Aman H, et al. Donor-specific transfusion in living-related renal transplants. Transplant Proc. 1992;24:1746. PMID: 1412822. [pmid: 1412822].
24 Betuel H, Touraine JL, Malik MC, et al. Kidney transplantation in patients submitted to deliberate transfusions, to random transfusions, and to thoracic duct drainage. Transplant Proc. 1982;14:276-278. PMID: 7051466. [pmid: 7051466].
25 Blamey RW, Knapp MS, Burden RP, et al. Blood transfusion and renal allograft survival. Br Med J. 1978;1:138-140. PMID: 339996. [pmid: 339996].
26 Briggs JD, Canavan JS, Dick HM, et al. Influence of HLA matching and blood transfusion on renal allograft survival. Transplantation. 1978;25:80-85. PMID: 341429. [pmid: 341429].
27 Brynger H, Frisk B, Ahlmen J, et al. Graft survival and blood transfusion. Proc Eur Dial Transplant Assoc. 1977;14:290-295. PMID: 341128. [pmid: 341128].
28 Brynger H, Persson H, Flatmark A, et al. No effect of blood transfusions or HLA matching on renal graft success rate in recipients treated with cyclosporine-prednisolone or cyclosporine-azathioprine-prednisolone: the Scandinavian experience. Transplant Proc. 1988;20:261-263. PMID: 3291253. [pmid: 3291253].
29 Bucin D. Adverse effect of blood transfusion on the long-term outcome of kidney transplantation. Exp Clin Immunogenet. 1988;5:39-47. PMID: 3272814. [pmid: 3272814].
30 Cheigh JS, Suthanthiran M, Stubenbord WT, et al. Optimization of donor specific blood transfusion in kidney transplantation. Transplant Proc. 1987;19:2250-2251. PMID: 2978891. [pmid: 2978891].
31 Chu DZ, Chatterjee SN, Blaisdell FW. A prospective study of pretransplant and operative day blood transfusion on renal allograft recipients. Curr Surg. 1982;39:24-26. PMID: 7037317. [pmid: 7037317].
32 Cochrum K, Hanes D, Potter D, et al. Improved graft survival with donor-specific transfusion pretreatment. Transplant Proc. 1981;13:190-193. PMID: 7022820. [pmid: 7022820].
33 Corry RJ, West JC, Hunsicker LG, et al. Effect of timing of administration and quantity of blood transfusion on cadaver renal transplant survival. Transplantation. 1980;30:425-428. PMID: 7008290. [pmid: 7008290].
34 d'Apice AJ, Sheil AG, Tait BD, et al. A prospective randomized trial of matching for HLA-A and B versus HLA-DR in renal transplantation. Transplantation. 1984;38:37-41. PMID: 6377610. [pmid: 6377610].
35 de Mattos AM, Bennett WM, Barry JM, et al. HLA-identical sibling renal transplantation--a 21-yr single-center experience. Clin Transplant. 1999;13:158-167. PMID: 10202612. [pmid: 10202612].
36 Dewar PJ, Wilkinson R, Elliott RW, et al. Superiority of B locus matching over other HLA matching in renal graft survival. Br Med J (Clin Res Ed). 1982;284:779-782. PMID: 6802225.
37 Egidi MF, Scott DH, Corry RJ. The effect of transfusions on renal allograft survival in the cyclosporine era: a single center report. Clin Transplant. 1993;7:240-244. PMID: 10148843. [pmid: 10148843].
38 Eisenberger U, Seifried A, Patey N, et al. FoxP3 positive T cells in graft biopsies from living donor kidney transplants after donor-specific transfusions. Transplantation. 2009;87:138-142. PMID: 19136904. [pmid: 19136904].
39 El-Husseini AA, Foda MA, Shokeir AA, et al. Determinants of graft survival in pediatric and adolescent live donor kidney transplant recipients: a single center experience. Pediatr Transplant. 2005;9:763-769. PMID: 16269048. [pmid: 16269048].
40 Fauchet R, Wattelet J, Genetet B, et al. Role of blood transfusions and pregnancies in kidney transplantation. Vox Sang. 1979;37:222-228. PMID: 386612. [pmid: 386612].
41 Feduska NJ, Amend WJ, Vincenti F, et al. Graft survival with high levels of cytotoxic antibodies. Transplant Proc. 1981;13:73-80. PMID: 7022910. [pmid: 7022910].
42 Fehrman I. Pretransplant blood transfusions and related kidney allograft survival. Transplantation. 1982;34:46-49. PMID: 6214879. [pmid: 6214879].
43 Fehrman I, Groth CG, Lundgren G, et al. Improved renal graft survival in transfused uremics. A result of a number of interacting factors. Transplantation. 1980;30:324-327. PMID: 7006164. [pmid: 7006164].
44 Flechner SM, Kerman RH, Van Buren C, et al. Successful transplantation of cyclosporine-treated haploidentical living-related renal recipients without blood transfusions. Transplantation. 1984;37:73-76. PMID: 6229913. [pmid: 6229913].
45 Flechner SM, Novick AC, Steinmuller D, et al. Determinants of allograft survival in 100 consecutive cadaver kidney transplants. J Urol. 1982;127:1084-1086. PMID: 7045404. [pmid: 7045404].
46 Fonseca HE, Chiba AK, Junior AF, et al. Anti-N-like and anti-Form red cell antibodies in chronic hemodialysis patients. Ren Fail. 2004;26:553-556. PMID: 15526914. [pmid: 15526914].
47 Garcia VD, Kraemer ES, Prompt CA, et al. Donor specific blood transfusions do not improve graft survival in living related donor transplantation. Transplant Proc. 1987;19:2271-2273. PMID: 3274507. [pmid: 3274507].
48 Fuller TC, Delmonico FL, Cosimi AB, et al. Effects of virus types of RBC transfusions on HLA alloimmunization and renal allograft survival. Transplant Proc. 1977;9:117-119. PMID: 325743. [pmid: 325743].
49 Fuller TC, Burroughs JC, Delmonico FL, et al. Influence of frozen blood transfusions on renal allograft survival. Transplant Proc. 1982;14:293-295. PMID: 7051469. [pmid: 7051469].
50 Galvao MM, Peixinho ZF, Mendes NF, et al. Stored blood--an effective immunosuppressive method for transplantation of kidneys from unrelated donors. An 11-year follow-up. Braz J Med Biol Res. 1997;30:727-734. PMID: 9292109. [pmid: 9292109].
51 Garcia LF, Arango AM, Rezonzew R, et al. Donor-specific and random transfusions in HLA-haploidentical kidney transplantation. Transplant Proc. 1991;23:1744-1746. PMID: 2053141. [pmid: 2053141].
52 Gardner B, Harris KR, Tate DG, et al. The effect of pretransplant blood transfusions on renal allograft survival in patients on cyclosporine. Transplant Proc. 1984;16:1172-1173. PMID: 6385368. [pmid: 6385368].
53 Garvin PJ, Castaneda M, Codd JE, et al. Recipient race as a risk factor in renal transplantation. Arch Surg. 1983;118:1441-1444. PMID: 6360077. [pmid: 6360077].
54 Glass NR, Felsheim G, Miller DT, et al. Influence of pre- and perioperative blood transfusions on renal allograft survival. Transplantation. 1982;33:430-431. PMID: 7041369. [pmid: 7041369].
55 Guillou PJ, Will EJ, Davison AM, et al. CAPD--a risk factor in renal transplantation?. Br J Surg. 1984;71:878-880. PMID: 6388721. [pmid: 6388721].
56 Ho-Hsieh H, Novick AC, Steinmuller D, et al. Renal transplantation for end-stage polycystic kidney disease. Urology. 1987;30:322-326. PMID: 3310365. [pmid: 3310365].
57 Hourmant M, Soulillou JP, Bui-Quang D. Beneficial effect of blood transfusion. Role of the time interval between the last transfusion and transplantation. Transplantation. 1979;28:40-43. PMID: 377593. [pmid: 377593].
58 Hurst PE, Brockis JG, Dawkins RL, et al. Renal transplantation. 12-Year experience. Med J Aust. 1981;1:123-126. PMID: 7012562. [pmid: 7012562].
59 Inoue S, Aikawa M, Dobashi Y, et al. Donor-specific transfusion for kidney transplantation in the cyclosporine era. Transplant Proc. 1996;28:1220-1221. PMID: 8658633. [pmid: 8658633].
60 Jakobsen A, Birkeland SA, Gabel H, et al. Renal transplantation in polycystic renal disease--a joint Scandinavian report. Scand J Urol Nephrol Suppl. 1980;54:71-75. PMID: 7013048. [pmid: 7013048].
61 Jeffery JR, Cheung K, Masniuk J, et al. Mixed lymphocyte culture responses. Lack of correlation with cadaveric renal allograft survival and blood transfusions. Transplantation. 1984;38:42-45. PMID: 6234685. [pmid: 6234685].
62 Jeffery JR, Downs A, Grahame JW, et al. Failure of blood transfusions to improve cadaveric renal allograft survival. Transplantation. 1978;25:344-345. PMID: 351896. [pmid: 351896].
63 Jeffery JR, Downs AR, Grahame JW, et al. Operation-day blood-transfusion and renal transplantation. Lancet. 1978;1:662. PMID: 76196. [pmid: 76196].
64 Jin DC, Yoon YS, Kim YS, et al. Factors on graft survival of living donor kidney transplantation in a single center. Clin Transplant. 1996;10:471-477. PMID: 8996765. [pmid: 8996765].
65 Jovicic S, Lezaic V, Simonovic R, et al. Beneficial effects of donor-specific transfusion on renal allograft outcome. Clin Transplant. 2010. [Epub ahead of print]: PMID: 20331687.
66 Joysey VC, Roger JH, Evans DB, et al. Differential kidney graft survival associated with interaction between recipient ABO group and pretransplant blood transfusion. Transplantation. 1977;24:371-376. PMID: 335591. [pmid: 335591].
67 Kahn D, Pontin AR, Pike R, et al. The first 100 kidney transplants from living related donors at Groote Schuur Hospital. SAMJ, S Afr med j. 1994;84:138-141. PMID: 7740348.
68 Kasai I, Kumano K, Iwamura M, et al. Comparative analysis of DST alone and DST with intermittent coverage by cyclophosphamide. Transplant Proc. 1989;21:1837-1838. PMID: 2652598. [pmid: 2652598].
69 Kovithavongs T, Schlaut J, Marchuk L, et al. Beneficial effect of blood transfusion in HLA identical and haploidentical renal allografts. Transplant Proc. 1982;14:690-692. PMID: 6762727. [pmid: 6762727].
70 Leivestad T, Albrechtsen D, Flatmark A, et al. Renal transplants from HLA-haploidentical living-related donors. The influence of donor-specific transfusions and different immunosuppressive regimens. Transplantation. 1986;42:35-38. PMID: 3523880. [pmid: 3523880].
71 Lietz K, Lao M, Paczek L, et al. The impact of pretransplant erythropoietin therapy on late outcomes of renal transplantation. Ann Transplant. 2003;8:17-24. PMID: 14626572. [pmid: 14626572].
72 Madsen M, Graugaard B, Fjeldborg O, et al. The impact of HLA-DR antigen matching on the survival of cadaveric renal allografts. A prospective one-center analysis. Transplantation. 1983;36:379-383. PMID: 6353704. [pmid: 6353704].
73 Melzer JS, Husing RM, Feduska NJ, et al. The beneficial effect of pretransplant blood transfusions in cyclosporine-treated cadaver renal allograft recipients. Transplantation. 1987;43:61-64. PMID: 3541325. [pmid: 3541325].
74 Mendez R, Iwaki Y, Mendez R, et al. Effect of deliberate blood transfusions in cadaveric kidney allografts at a single center. J Urol. 1982;127:427-429. PMID: 7038148. [pmid: 7038148].
75 Myburgh JA, Botha JR, Meyers AM, et al. The treatment of end-stage renal disease at the Johannesburg Hospital: a 17-year experience. Part II. The role of transplantation. SAMJ, S Afr med j. 1983;64:522-527. PMID: 6353617.
76 Norman DJ, Barry JM, Fischer S. The beneficial effect of pretransplant third-party blood transfusions on allograft rejection in HLA-identical sibling kidney transplants. Transplantation. 1986;41:125-126. PMID: 3510484. [pmid: 3510484].
77 Nube MJ, Persijn GG, van Es A, et al. Beneficial effect of HLA-A and B matched pretransplant blood transfusions on primary cadaveric kidney graft survival. Transplantation. 1983;35:556-561. PMID: 6346596. [pmid: 6346596].
78 Oei LS, Thompson JS, Corry RJ. Effect of blood transfusions on survival of cadaver and living related renal transplants. Transplantation. 1979;28:482-484. PMID: 390787. [pmid: 390787].
79 Okiye SE, Zincke H, Engen DE, et al. Splenectomy in high-risk primary renal transplant recipients. Am J Surg. 1983;146:594-601. PMID: 6356949. [pmid: 6356949].
80 Opelz G, Terasaki PI. Poor kidney-transplant survival in recipients with frozen-blood transfusions or no transfusions. Lancet. 1974;2:696-698. PMID: 4142966. [pmid: 4142966].
81 Persijn GG, van Hooff JP, Kalff MW, et al. Effect of blood transfusions and HLA matching on renal transplantation in the Netherlands. Transplant Proc. 1977;9:503-505. PMID: 325789. [pmid: 325789].
82 Pfaff WW, Howard RJ, Scornik JC, et al. Incidental and purposeful random donor blood transfusion. Sensitization and transplantation. Transplantation. 1989;47:130-133. PMID: 2643223. [pmid: 2643223].
83 Polesky HF, McCullough JJ, Yunis E, et al. The effects of transfusion of frozen-thawed deglycerolized red cells on renal graft survival. Transplantation. 1977;24:449-452. PMID: 339441. [pmid: 339441].
84 Poli F, Mascaretti L, Pappalettera M, et al. HLA-DRB1 compatibility in cadaver kidney transplantation: correlation with graft survival and function. Transpl Int. 1995;8:91-95. PMID: 7766303. [pmid: 7766303].
85 Poli L, Pretagostini R, Rossi M, et al. Effect of HLA compatibility, pregnancies, blood transfusions, and taboo mismatches in living unrelated kidney transplantation. Transplant Proc. 2001;33:1136-1138. PMID: 11267225. [pmid: 11267225].
86 Potter DE, Portale AA, Melzer JS, et al. Are blood transfusions beneficial in the cyclosporine era?. Pediatr Nephrol. 1991;5:168-172. PMID: 2025530. [pmid: 2025530].
87 Rao KV, Andersen RC, O'Brien TJ. Factors contributing for improved graft survival in recipients of kidney transplants. Kidney Int. 1983;24:210-221. PMID: 6355614. [pmid: 6355614].
88 Richie RE, Niblack GD, Johnson HK, et al. Factors influencing the outcome of kidney transplants. Ann Surg. 1983;197:672-677. PMID: 6344816. [pmid: 6344816].
89 Sabbaga E, Ianhez LE, Chocair PR, et al. Kidney transplants from living nonrelated donors: an analysis of 87 cases, including 20 cases with specific blood transfusions from the donor. Transplant Proc. 1985;17:1741-1745. PMID: 3885517. [pmid: 3885517].
90 Sachs JA, Festenstein H, Tuffnell VA, et al. Collaborative scheme for tissue typing and matching in renal transplantation. IX. Effect of HLA-A, -B, and -D locus matching, pretransplant transfusion, and other factors on 612 cadaver renal grafts. Transplant Proc. 1977;9:483-486. PMID: 325785. [pmid: 325785].
91 Safwenberg J, Backman-Bave U, Hogman CF. The effect of blood transfusions on cadaver kidney transplants--an analysis of patients transplanted in Uppsala. Scand J Urol Nephrol Suppl. 1977:59-61. PMID: 356223. [pmid: 356223].
92 Sakagami K, Saito S, Shiozaki S, et al. Renal transplantation from HLA-haploidentical living-related donors: the effects of donor-specific blood transfusions and different immunosuppressive regimens. Acta Med Okayama. 1992;46:1-5. PMID: 1561899. [pmid: 1561899].
93 Salvatierra O Jr, Melzer J, Vincenti F, et al. Donor-specific blood transfusions versus cyclosporine--the DST story. Transplant Proc. 1987;19:160-166. PMID: 3547813. [pmid: 3547813].
94 Salvatierra O Jr, Vincenti F, Amend W, et al. Deliberate donor-specific blood transfusions prior to living related renal transplantation. A new approach. Ann Surg. 1980;192:543-552. PMID: 6448588. [pmid: 6448588].
95 Salvatierra O, McVicar J, Melzer J, et al. Improved results with combined donor-specific transfusion (DST) and sequential therapy protocol. Transplant Proc. 1991;23:1024-1026. PMID: 1989146. [pmid: 1989146].
96 Sanfilippo F, Thacker L, Vaughn WK. Living-donor renal transplantation in SEOPF. The impact of histocompatibility, transfusions, and cyclosporine on outcome. Transplantation. 1990;49:25-29. PMID: 2301022. [pmid: 2301022].
97 Sells RA, Scott MH, Prieto M, et al. Early rejection following donor-specific transfusion prior to HLA-mismatched living related renal transplantation. Transplant Proc. 1989;21:1173-1174. PMID: 2650088. [pmid: 2650088].
98 Sengar DP, Rashid A, Jindal SL. Effect of blood transfusions on renal allograft survival. Transplant Proc. 1979;11:179-181. PMID: 377627. [pmid: 377627].
99 Sijpkens YW, Koep LJ, Persijn GG, et al. Pros and cons of donor-specific blood transfusions in living related kidney transplantation. Neth J Med. 1984;27:1-5. PMID: 6231486. [pmid: 6231486].
100 Sirchia G, Mercuriali F, Pizzi C, et al. Blood transfusion and kidney transplantation: effect of small doses of blood on kidney graft function and survival. Transplant Proc. 1982;14:263-271. PMID: 7051464. [pmid: 7051464].
101 Sirchia G, Mercuriali F, Scalamogna M, et al. Evaluation of the blood transfusion policy of the north Italy transplant program. Transplantation. 1981;31:388-394. PMID: 7015627. [pmid: 7015627].
102 Solheim BG, Flatmark A, Halvorsen S, et al. The effect of blood transfusions on renal transplantation. Studies of 395 patients registered for transplantation with a first cadaveric kidney. Tissue Antigens. 1980;16:377-386. PMID: 7008257. [pmid: 7008257].
103 Solheim BG, Flatmark A, Halvorsen S, et al. Effect of blood transfusions on renal transplantation: study of 191 consecutive first transplants from living related donors. Transplantation. 1980;30:281-284. PMID: 6449767. [pmid: 6449767].
104 Sommer BG, Ferguson RM. Mismatched living, related donor renal transplantation: a prospective, randomized study. Surgery. 1985;98:267-274. PMID: 3895539. [pmid: 3895539].
105 Spees EK, Vaughn WK, McDonald JC, et al. Why do secondary cadaver renal transplants succeed? Results of the South-Eastern Organ Procurement Foundation prospective study, 1977–1982. J Urol. 1983;129:484-488. PMID: 6339749. [pmid: 6339749].
106 Spees EK, Vaughn WK, Williams GM, et al. Effects of blood transfusion on cadaver renal transplantation: the Southeastern Organ Procurement Foundation prospective study (1977 to 1979). Transplantation. 1980;30:455-463. PMID: 7008295. [pmid: 7008295].
107 Stiller CR, Lockwood BL, Sinclair NR, et al. Beneficial effect of operation-day blood-transfusions on human renal-allograft survival. Lancet. 1978;1:169-170. PMID: 74601. [pmid: 74601].
108 Takahashi I, Otsubo O, Nishimura M, et al. Prolonged graft survival by donor-specific blood transfusion (DSBT). Transplant Proc. 1982;14:367-369. PMID: 7051481. [pmid: 7051481].
109 Takiff H, Cook DJ, Himaya NS, et al. Dominant effect of histocompatibility on ten-year kidney transplant survival. Transplantation. 1988;45:410-415. PMID: 3278435. [pmid: 3278435].
110 Thorsby E, Moen T, Solheim BG, et al. Influence of HLA matching in cadaveric renal transplantation: experience from one Scandiatransplant center. Tissue Antigens. 1981;17:83-90. PMID: 7018015. [pmid: 7018015].
111 Ting A, Morris PJ. The influence of HLA-A,B and -DR matching and pregraft blood transfusions on graft and patient survival after renal transplantation in a single centre. Tissue Antigens. 1984;24:256-264. PMID: 6393428. [pmid: 6393428].
112 Velidedeoglu E, Tokyay R, Haberal M. Effect of donor-specific blood transfusions on graft outcome in live donor renal transplantations. Transplant Proc. 1992;24:2752-2753. PMID: 1465927. [pmid: 1465927].
113 Waanders MM, Roelen DL, de Fijter JW, et al. Protocolled blood transfusions in recipients of a simultaneous pancreas-kidney transplant reduce severe acute graft rejection. Transplantation. 2008;85:1668-1670. PMID: 18551077. [pmid: 18551077].
114 Walker JF, Oreopoulos DG, Uldall PR, et al. The effect of pre-transplant blood transfusion on graft outcome in patients on peritoneal dialysis prior to renal transplantation. Transplant Proc. 1982;14:687-689. PMID: 6762726. [pmid: 6762726].
115 Walter S, Poulsen LR, Friedberg M, et al. The effect of blood-transfusions on renal allograft survival. Scand J Urol Nephrol Suppl. 1977:62-64. PMID: 356225. [pmid: 356225].
116 Werner-Favre C, Jeannet M, Harder F, et al. Blood transfusions, cytotoxic antibodies, and kidney graft survival. Preliminary results of a systematic transfusion protocol. Transplantation. 1979;28:343-346. PMID: 388766. [pmid: 388766].
117 Xiao X, Li Y, Ao J, et al. Analysis of prognostic factors affecting renal allograft survival. Transpl Int. 1992;5:226-230. PMID: 1418314. [pmid: 1418314].
118 Yamauchi J, Akiyama N, Sugimoto H, et al. Uselessness of donor-specific transfusions or prophylactic ALG with therapeutic cyclosporine doses in living related renal transplantation between one-haplotype matched pairs. Transplant Proc. 1989;21:1663-1666. PMID: 2652545. [pmid: 2652545].
119 Zeichner WD, Toledo-Pereyra LH, Whitten J, et al. Lack of correlation between cadaver kidney transplant survival and the number of pretransplant transfusions. Transplantation. 1983;35:500-501. PMID: 6342229. [pmid: 6342229].
120 Frisk B, Brynger H, Sandberg L. Two random transfusions before primary renal transplantation--four years' experience from a single center. Transplant Proc. 1982;14:386-388. PMID: 7051484. [pmid: 7051484].
121 Solheim BG, Flatmark A, Halvorsen S, et al. Effect of pre-transplant blood transfusions and haemodialysis on the survival of first kidney grafts from living related donors. Scand J Urol Nephrol Suppl. 1980;54:63-66. PMID: 7013047. [pmid: 7013047].
122 Reed A, Pirsch J, Armbrust MJ, et al. Multivariate analysis of donor-specific versus random transfusion protocols in haploidentical living-related transplants. Transplantation. 1991;51:382-384. PMID: 1994532. [pmid: 1994532].
123 Sanfilippo F, Vaughn WK, LeFor WM, et al. Multivariate analysis of risk factors in cadaver donor kidney transplantation. Transplantation. 1986;42:28-34. PMID: 3523879. [pmid: 3523879].
124 Tang H, Chelamcharla M, Baird BC, et al. Factors affecting kidney-transplant outcome in recipients with lupus nephritis. Clin Transplant. 2008;22:263-272. PMID: 18482047. [pmid: 18482047].
125 Peters TG, Shaver TR, Ames JE 4th, et al. Cold ischemia and outcome in 17,937 cadaveric kidney transplants. Transplantation. 1995;59:191-196. PMID: 7839440. [pmid: 7839440].
126 Sautner T, Gruenberger T, Barlan M, et al. Immunological risk factors are solely responsible for primary non-function of renal allografts. Transpl Int. 1994;7:S294-S297. PMID: 11271229. [pmid: 11271229].
127 Madrenas J, Newman S, McGregor JR, et al. An alternative approach for statistical analysis of kidney transplant data: multivariate analysis of single-center experience. Am J Kidney Dis. 1988;12:524-530. PMID: 3057883. [pmid: 3057883].
128 A randomized clinical trial of cyclosporine in cadaveric renal transplantation. Analysis at three years. The Canadian multicentre transplant study group. N Engl J Med. 1986;314:1219-1225. PMID: 2871486. [pmid: 2871486].
129 Nube MJ, Persijn GG, Kalff MW, et al. Transplant survival and clinical course after pretransplant HLA-A and B matched blood transfusions: a single centre study. Proc Eur Dial Transplant Assoc. 1983;19:445-452. PMID: 6348745. [pmid: 6348745].
130 Brynger H, Frisk B, Ahlmen J, et al. Blood transfusion and primary graft survival in male recipients. Scand J Urol Nephrol Suppl. 1977:76-78. PMID: 356229. [pmid: 356229].
131 Akiyama N, Otsubo O, Yamauchi J, et al. Effects of donor-specific blood transfusion on the survival of living related renal grafts. Jpn J Exp Med. 1984;54:225-227. PMID: 6398837. [pmid: 6398837].
132 Huprikar AG, Arora N, Bulchand S. Donor specific transfusions in renal transplantation. J Assoc Physicians India. 1987;35:577-579. PMID: 3320025. [pmid: 3320025].
133 Glass NR, Miller DT, Sollinger HW, et al. A four-year experience with donor blood transfusion protocols for living-donor renal transplantation. Transplantation. 1985;39:615-619. PMID: 3890291. [pmid: 3890291].
134 Padanyi A, Horuzsko A, Gyodi E, et al. Long-term related kidney graft survival in high-risk patients after monitored donor-specific transfusion protocol. Transpl Int. 1998;11:S110-S114. PMID: 9664958. [pmid: 9664958].
135 Takahashi K, Yagisawa T, Tanabe I, et al. Outcome of kidney transplantation in highly sensitized patients after donor-specific blood transfusion. Transplant Proc. 1987;19:3655-3660. PMID: 2960043. [pmid: 2960043].
136 Casadei DH, Cambariere R, Leanza H, et al. Donor specific blood transfusion in renal transplantation: analysis of 22 cases. Transplant Proc. 1987;19:2274-2275. PMID: 3079079. [pmid: 3079079].
137 Andrus CH, Betts RF, May AG, et al. Cytomegalovirus infection blocks the beneficial effect of pretransplant blood transfusion on renal allograft survival. Transplantation. 1979;28:451-456. PMID: 229593. [pmid: 229593].
138 Chavers BM, Sullivan EK, Tejani A, et al. Pre-transplant blood transfusion and renal allograft outcome: a report of the North American Pediatric Renal Transplant Cooperative Study. Pediatr Transplant. 1997;1:22-28. PMID: 10084783. [pmid: 10084783].
139 Fradet Y, Roy R, Lachance JG, et al. Kidney graft survival: role of blood transfusions and lymphocytotoxic antibodies. Clin Nephrol. 1982;18:69-73. PMID: 6754190. [pmid: 6754190].
140 Husberg B, Lindergard B, Lindholm T, et al. Blood transfusion and kidney transplantation. Scand J Urol Nephrol Suppl. 1977:73-75. PMID: 356228. [pmid: 356228].
141 Kerman RH, Kimball PM, Van Buren CT, et al. Possible contribution of pretransplant immune responder status to renal allograft survival differences of black versus white recipients. Transplantation. 1991;51:338-342. PMID: 1825242. [pmid: 1825242].
142 Kerman RH, Van Buren CT, Lewis RM, et al. Impact of blood transfusions and HLA on cyclosporine-treated renal transplant recipients. Transplant Proc. 1988;20:264-269. PMID: 3291254. [pmid: 3291254].
143 Kerman RH, Van Buren CT, Payne W, et al. The influence on pretransplant blood transfusions from random donors on immune parameters affecting cadaveric allograft survival. Transplantation. 1983;36:50-54. PMID: 6223421. [pmid: 6223421].
144 Muller GA, Muller C, Bockhorn H, et al. HLA-DR-MT matching improves graft survival rate in cadaver kidney transplantation. A prospective multicenter analysis of the South German Cooperative Study Group for Kidney Transplantation. Klin Wochenschr. 1983;61:17-23. PMID: 6187967. [pmid: 6187967].
145 van Es A, Persijn GG, van Hooff-Eijkenboom YE, et al. Blood transfusions, HLA-A and B, DR matching, graft survival, and clinical course after cadaveric kidney transplantation. Transplant Proc. 1981;13:172-174. PMID: 7022816. [pmid: 7022816].
146 Velasco N, Catto GR, Edward N, et al. The effect of the dosage of steroids on the incidence of cytomegalovirus infections in renal transplant recipients. J Infect. 1984;9:69-78. PMID: 6094670. [pmid: 6094670].
147 Perkins HA, Salvatierra O. Correlation of renal allograft survival with previous blood transfusions. Transplant Proc. 1977;9:209-210. PMID: 324050. [pmid: 324050].
148 Cheigh JS, Saal SD, Suthanthiran M, et al. Natural history of cadaveric kidney transplants in the absence of early acute rejection. Nephron. 1983;35:6-10. PMID: 6193438. [pmid: 6193438].
149 Cho SI, Bradley JW, Carpenter CB, et al. Antithymocyte globulin, pretransplant blood transfusion, and tissue typing in cadaver kidney transplantation. Am J Surg. 1983;145:464-471. PMID: 6340551. [pmid: 6340551].
150 Vathsala A, Tan S, Woo KT, et al. The impact of HLA match transfusions and presensitization on renal transplantation in the cyclosporine era. Ann Acad Med Singapore. 1992;21:364-367. PMID: 1416786. [pmid: 1416786].
151 Higgins RM, Raymond NT, Krishnan NS, et al. Acute rejection after renal transplantation is reduced by approximately 50% by prior therapeutic blood transfusions, even in tacrolimus-treated patients. Transplantation. 2004;77:469-471. PMID: 14966430. [pmid: 14966430].
152 Park YH, Min SK, Lee JN, et al. Risk factors on graft survival of living donor kidney transplantation. Transplant Proc. 2004;36:2023-2025. PMID: 15518732. [pmid: 15518732].
153 Bunnapradist S, Daswani A, Takemoto SK. Graft survival following living-donor renal transplantation: a comparison of tacrolimus and cyclosporine microemulsion with mycophenolate mofetil and steroids. Transplantation. 2003;76:10-15. PMID: 12865780. [pmid: 12865780].
154 Agarwal SK, Dash SC, Mehta SN, et al. Results of renal transplantation on conventional immunosuppression in second decade in India: a single centre experience. J Assoc Physicians India. 2002;50:532-536. PMID: 12164404. [pmid: 12164404].
155 Montagnino G, Tarantino A, Maccario M, et al. Long-term results with cyclosporine monotherapy in renal transplant patients: a multivariate analysis of risk factors. Am J Kidney Dis. 2000;35:1135-1143. PMID: 10845828. [pmid: 10845828].
156 Herget-Rosenthal S, Gerken G, Philipp T, et al. Serum ferritin and survival of renal transplant recipients: a prospective 10-year cohort study. Transpl Int. 2003;16:642-647. PMID: 12732929. [pmid: 12732929].
157 Sanfilippo FP, Bollinger RR, MacQueen JM, et al. A randomized study comparing leukocyte-depleted versus packed red cell transfusions in prospective cadaver renal allograft recipients. Transfusion. 1985;25:116-119. PMID: 3885483. [pmid: 3885483].
158 Persijn GG, van Leeuwen A, Parlevliet J, et al. Two major factors influencing kidney graft survival in Eurotransplant: HLA-DR matching and blood transfusion(s). Transplant Proc. 1981;13:150-154. PMID: 7022812. [pmid: 7022812].
159 Cecka JM. Calculated PRA (CPRA): the new measure of sensitization for transplant candidates. Am J Transplantation. 2010;10:26-29. PMID: 19958328.
160 Hajeer AH. Panel reactive antibody test (PRA) in renal transplantation. Saudi J Kidney Dis Transplant. 2006;17:1-4. PMID: 17297529.
161 Worthington JE, Robson AJ, Sheldon S, et al. A comparison of enzyme-linked immunoabsorbent assays and flow cytometry techniques for the detection of HLA specific antibodies. Hum Immunol. 2001;62:1178-1184. PMID: 11600227. [pmid: 11600227].
162 Harmer AW, Heads AJ, Vaughan RW. Detection of HLA class I and class II specific antibodies by flow cytometry and PRA-Stat screening in renal transplant recipients. Transplantation. 1997;63:1828-1832. PMID: 9210512. [pmid: 9210512].
163 Buelow R, Mercier I, Glanville L, et al. Detection of panel-reactive anti-HLA class I antibodies by enzyme-linked immunosorbent assay or lymphcytotoxicity: results of a blinded, controlled multicenter study. Hum Immunol. 1995;44:1-11. PMID: 8522449. [pmid: 8522449].
164 Kerman RH, Susskind B, Beulow R, et al. Correlation of ELISA-detected igG and IgA anti-HLA antibodies in pretransplant sera with renal allograft rejection. Transplantation. 1996;62:201-205. PMID: 8755816. [pmid: 8755816].
165 Bryan CF, Baier KA, Flora-Ginter G, et al. Detection of HLA IgG antibodies by two enzyme-linked immunoassays, solubilized HLA class I and PRA-STAT: comparison with the AHG PRA. Transplantation. 1995;6260:1588-1594. PMID: 8545895. [pmid: 8545895].
166 Vieira CA, Agarwal A, Book BK, et al. Rituximab for reduction of anti-HLA antibodies in patients awaiting renal transplantation: safety, pharmacodynamics, and pharmacokinetics. Transplantation. 2004;77:542-548. PMID: 15084932. [pmid: 15084932].
167 Vo AA, Lukovsky M, Wang J, et al. Rituximab and intravenous immune globulin for desensitization during renal transplantation. N Engl J Med. 2008;359:242-251. PMID: 18635429. [pmid: 18635429].
168 Muhmoud KM, Sobh MA, el Shenawy F, et al. Management of sensitized patients awaiting renal transplantation: does sequential therapy with intravenous immunoglobulin and simvastatin offer a solution. Eur J Cancer Clin Oncol. 2007;56:202-205. PMID: 17296177.
169 Nurhan-Ozdemir F, Akcay A, Sezer S, et al. Effect of simvastatin in the treatment of highly sensitized dialysis patients: the pre and post-renal transplantation follow-up outcomes. Transplant immunology. 2004;13:39-42. PMID: 15203127. [pmid: 15203127].
170 Alarabi A, Backman-Bave U, Wikstrom B, et al. Plasmapheresis in HLA-immunosensitized patients prior to kidney transplantation. Int J Artificial Organs. 1997;201:51-56. PMID: 9062832.
171 Akcay A, Ozdemir FN, Atac FB, et al. Angiotensin-Converting Enzyme genotype is a predictive factor in the peak panel-reactive antibody response. Transplant Proc. 2004;36:35-37. PMID: 15013293. [pmid: 15013293].
172 Buscaroli A, nanni-Costa A, Iannelli Sea. Value of panel reactive antibodies (PRA) as a guide to the treatment of hyperimmunized patients in renal transplant. Transpl Int. Suppl 1. 1992;5:s54-s57. PMID: 14621731. [pmid: 14621731].
173 d'Apice AJ, Tait BD. An elective transfusion policy: sensitization rates, patient transplantability, and transplant outcome. Transplantation. 1982;33:191-195. PMID: 7036472. [pmid: 7036472].
174 Opelz G, Mickey MR, Terasaki PI. Responsiveness to HL-A as studied by monitoring blood transfusions and kidney transplants. Proc Eur Dial Transplant Assoc. 1973;10:471-474. PMID: 4607029. [pmid: 4607029].
175 Albrechtsen D, Flatmark A, Lundgren G, et al. Renal transplantation from HLA-haploidentical living related donors: the Scandinavian multicenter study of the effects of cyclosporine immunosuppression. Clinical transplantation. 1987;1:104-107.
176 Opelz G, Terasaki P. Histocompatibility matching utilizing responsiveness as a new dimension. TRANSPLANT-PROC. 1972;4:433-437. PMID: 4566783. [pmid: 4566783].
177 Opelz G. Collaborative Transplant Study. Non-HLA transplantation immunity revealed by lymphocytotoxic antibodies. Lancet. 2005;365:1570-1576. PMID: 15866311. [pmid: 15866311].
178 Terasaki PI, Perdue ST, Sasaki N, et al. Improving success rates of kidney transplantation. JAMA. 1983;250:1065-108. PMID: 6348321. [pmid: 6348321].