# About the Author

Dr. Laura Dean is a Visiting Research Fellow at the National Center for Biotechnology Information (NCBI), which is part of the National Library of Medicine (NLM) at the National Institutes of Health (NIH). Laura graduated as a medical doctor from the University of Cambridge in 2000. Since that time she has completed a medical and surgical rotation in the UK and written two textbooks ("The Genetic Landscape of Diabetes" and "Blood Groups and Red Cell Antigens") and over 20 online articles for the NCBI.